# Appendix 16 Illustration of the Change in Model-Estimated Outcomes With Delays in Screening Initiation and Repeat Screening for Sample Strategies With Screening Starting at Age 45

Appendix Table 16.1 Illustration of the Changes in Estimated Outcomes From Adherence to Screening Initiation for Sample Strategies With Screening Beginning at Age 45, by Model^*^

The potential changes in outcomes with delayed screening initiation and with extended intervals (representing delays in repeat screening) are presented in Tables 13 and 14, relative to strategies with screening beginning at age 50. Appendix Tables 16.1 and 16.2 show the changes for the same strategies, but with screening beginning at age 45.

Strategy by model | Outcomes and change in outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | DLG
Strategy by model | Stool tests | SIGs | CTCs | COLs | Compli-cations | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
Colonoscopy (COL)
SimCRC
COL 45-75, 10 | 0 | 0 | 0 | 4212 | 16 | 14 | 3 | 369 | 347 | 135
Delay start by 5y | 0 | 0 | 0 | −798 | −2 | +4 | +2 | −34 | −33 | −12
Delay start by 10y | 0 | 0 | 0 | −1060 | 0 | +8 | +3 | −72 | −71 | −26
CRC-SPIN
COL 45-75, 10 | 0 | 0 | 0 | 4300 | 17 | 12 | 4 | 340 | 321 | 124
Delay start by 5y | 0 | 0 | 0 | −800 | −2 | +3 | +1 | −32 | −30 | −12
Delay start by 10y | 0 | 0 | 0 | −1085 | −1 | +7 | +3 | −62 | −60 | −23
MISCAN
COL 45-75, 10 | 0 | 0 | 0 | 4232 | 15 | 34 | 8 | 301 | 272 | 110
Delay start by 5y | 0 | 0 | 0 | −756 | −2 | +2 | +1 | −16 | −15 | −6
Delay start by 10y | 0 | 0 | 0 | −1051 | 0 | +3 | +1 | −38 | −37 | −14
Sigmoidoscopy (SIG)
SimCRC
SIG 45-75, 5 | 0 | 4846 | 0 | 1720 | 10 | 25 | 8 | 309 | 289 | 113
Delay start by 5y | 0 | −788 | 0 | −176 | 0 | +3 | +1 | −30 | −29 | −11
Delay start by 10y | 0 | −1543 | 0 | −362 | 0 | +8 | +3 | −67 | −65 | −24
CRC-SPIN
SIG 45-75, 5 | 0 | 4935 | 0 | 1680 | 12 | 24 | 9 | 280 | 264 | 102
Delay start by 5y | 0 | −801 | 0 | −170 | 0 | +2 | +1 | −24 | −22 | −9
Delay start by 10y | 0 | −1571 | 0 | −355 | −1 | +6 | +2 | −51 | −49 | −19
MISCAN
SIG 45-75, 5 | 0 | 4389 | 0 | 2119 | 12 | 39 | 11 | 269 | 241 | 98
Delay start by 5y | 0 | −743 | 0 | −192 | 0 | +1 | 0 | −13 | −12 | −5
Delay start by 10y | 0 | −1429 | 0 | −407 | 0 | +3 | +1 | −35 | −34 | −13
Sigmoidoscopy with interval fecal immunochemical testing (SIG+FIT)
SimCRC
SIG+FIT 45-75, 10_1 | 16648 | 2568 | 0 | 2102 | 11 | 18 | 4 | 363 | 338 | 133
Delay start by 5y | −3112 | −469 | 0 | −263 | −1 | +4 | +1 | −33 | −32 | −12
Delay start by 10y | −5997 | −738 | 0 | −453 | 0 | +8 | +3 | −73 | −71 | −27
CRC-SPIN
SIG+FIT 45-75, 10_1 | 16322 | 2525 | 0 | 2237 | 14 | 15 | 5 | 330 | 309 | 120
Delay start by 5y | −3018 | −458 | 0 | −265 | 0 | +3 | +1 | −29 | −27 | −11
Delay start by 10y | −5846 | −716 | 0 | −496 | −1 | +7 | +3 | −61 | −59 | −22
MISCAN
SIG+FIT 45-75, 10_1 | 15466 | 2393 | 0 | 2331 | 13 | 37 | 9 | 304 | 272 | 111
Delay start by 5y | −3109 | −493 | 0 | −284 | −1 | +2 | +1 | −17 | −17 | −6
Delay start by 10y | −5841 | −662 | 0 | −461 | 0 | +3 | +1 | −41 | −39 | −15
Computed tomographic colonography (CTC)
SimCRC
CTC 45-75, 5 | 0 | 0 | 4804 | 1788 | 11 | 18 | 5 | 355 | 332 | 130
Delay start by 5y | 0 | 0 | −798 | −164 | 0 | +3 | +1 | −31 | −30 | −11
Delay start by 10y | 0 | 0 | −1559 | −341 | 0 | +8 | +3 | −72 | −70 | −26
CRC-SPIN
CTC 45-75, 5 | 0 | 0 | 4893 | 1791 | 13 | 18 | 6 | 313 | 294 | 114
Delay start by 5y | 0 | 0 | −805 | −165 | 0 | +2 | +1 | −26 | −24 | −9
Delay start by 10y | 0 | 0 | −1573 | −351 | −1 | +6 | +2 | −56 | −54 | −20
MISCAN
CTC 45-75, 5 | 0 | 0 | 4881 | 1672 | 10 | 42 | 11 | 283 | 251 | 103
Delay start by 5y | 0 | 0 | −806 | −153 | 0 | +1 | +0 | −14 | −14 | −5
Delay start by 10y | 0 | 0 | −1572 | −322 | 0 | +3 | +1 | −38 | −36 | −14
Fecal immunochemical testing (FIT)
SimCRC
FIT 45-75, 1 | 19680 | 0 | 0 | 1602 | 10 | 26 | 6 | 348 | 321 | 127
Delay start by 5y | −3520 | 0 | 0 | −179 | 0 | +4 | +1 | −33 | −32 | −12
Delay start by 10y | −6889 | 0 | 0 | −370 | 0 | +9 | +3 | −74 | −72 | −27
CRC-SPIN
FIT 45-75, 1 | 18950 | 0 | 0 | 1824 | 13 | 20 | 6 | 314 | 293 | 115
Delay start by 5y | −3387 | 0 | 0 | −205 | 0 | +3 | +1 | −29 | −28 | −11
Delay start by 10y | −6608 | 0 | 0 | −430 | −1 | +8 | +3 | −64 | −62 | −23
MISCAN
FIT 45-75, 1 | 19607 | 0 | 0 | 1620 | 10 | 46 | 10 | 291 | 256 | 106
Delay start by 5y | −3510 | 0 | 0 | −175 | 0 | +1 | +1 | −17 | −16 | −6
Delay start by 10y | −6849 | 0 | 0 | −367 | 0 | +4 | +2 | −45 | −43 | −16
Multitarget stool DNA test (sDNA-FIT), 1-year interval
SimCRC
sDNA-FIT 45-75, 1 | 13888 | 0 | 0 | 2462 | 12 | 19 | 4 | 363 | 337 | 133
Delay start by 5y | −2425 | 0 | 0 | −305 | 0 | +4 | +1 | −33 | −32 | −12
Delay start by 10y | −4717 | 0 | 0 | −613 | 0 | +9 | +3 | −74 | −72 | −27
CRC-SPIN
sDNA-FIT 45-75, 1 | 13494 | 0 | 0 | 2617 | 14 | 15 | 5 | 331 | 309 | 121
Delay start by 5y | −2361 | 0 | 0 | −322 | 0 | +3 | +1 | −30 | −28 | −11
Delay start by 10y | −4583 | 0 | 0 | −653 | −1 | +7 | +3 | −63 | −61 | −23
MISCAN
sDNA-FIT 45-75, 1 | 13698 | 0 | 0 | 2515 | 12 | 38 | 9 | 306 | 272 | 112
Delay start by 5y | −2383 | 0 | 0 | −305 | 0 | +1 | +1 | −16 | −15 | −6
Delay start by 10y | −4608 | 0 | 0 | −618 | 0 | +4 | +2 | −43 | −41 | −16
Multitarget stool DNA test (sDNA-FIT), 3-year interval
SimCRC
sDNA-FIT 45-75, 3 | 7274 | 0 | 0 | 1582 | 9 | 30 | 7 | 335 | 308 | 122
Delay start by 5y | −1201 | 0 | 0 | −177 | 0 | +4 | +1 | −31 | −30 | −11
Delay start by 10y | −2545 | 0 | 0 | −395 | −1 | +9 | +4 | −74 | −71 | −27
CRC-SPIN
sDNA-FIT 45-75, 3 | 7105 | 0 | 0 | 1772 | 12 | 23 | 7 | 301 | 281 | 110
Delay start by 5y | −1166 | 0 | 0 | −196 | 0 | +3 | +1 | −30 | −28 | −11
Delay start by 10y | −2471 | 0 | 0 | −440 | −1 | +9 | +3 | −64 | −62 | −23
MISCAN
sDNA-FIT 45-75, 3 | 7204 | 0 | 0 | 1629 | 10 | 49 | 12 | 273 | 239 | 100
Delay start by 5y | −1199 | 0 | 0 | −179 | 0 | +1 | +1 | −16 | −15 | −6
Delay start by 10y | −2520 | 0 | 0 | −397 | −1 | +4 | +2 | −44 | −41 | −16

CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* These strategies were selected for illustration purposes. Inclusion in this table should not be interpreted as endorsement of these strategies.

† Includes deaths from complications of screening.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 16.2 Illustration of the Changes in Estimated Outcomes From Adherence to Repeat Screening for Sample Strategies With Screening Beginning at Age 45, by Model^*^

Strategy by model | Outcomes and change in outcomes per 1000 unscreened 40-year-olds free from diagnosed colorectal cancer | | | | | | | | | DLG
Strategy by model | Stool tests | SIGs | CTCs | COLs | Compli-cations | CRC cases | CRC deaths^†^ | LYG | QALYG | DLG
Colonoscopy (COL)
SimCRC
COL 45-75, 10 | 0 | 0 | 0 | 4212 | 16 | 14 | 3 | 369 | 347 | 135
Increase interval to 15y | 0 | 0 | 0 | −749 | −1 | +4 | +1 | −17 | −16 | −6
Once-only | 0 | 0 | 0 | −2526 | −10 | +32 | +13 | −123 | −114 | −45
CRC-SPIN
COL 45-75, 10 | 0 | 0 | 0 | 4300 | 17 | 12 | 4 | 340 | 321 | 124
Increase interval to 15y | 0 | 0 | 0 | −743 | −1 | +2 | +1 | −13 | −12 | −5
Once-only | 0 | 0 | 0 | −2418 | −8 | +22 | +9 | −84 | −79 | −31
MISCAN
COL 45-75, 10 | 0 | 0 | 0 | 4232 | 15 | 34 | 8 | 301 | 272 | 110
Increase interval to 15y | 0 | 0 | 0 | −699 | −1 | +3 | +1 | −20 | −19 | −7
Once-only | 0 | 0 | 0 | −2372 | −9 | +24 | +13 | −134 | −119 | −49
Sigmoidoscopy (SIG)
SimCRC
SIG 45-75, 5 | 0 | 4846 | 0 | 1720 | 10 | 25 | 8 | 309 | 289 | 113
Increase interval to 10y | 0 | −1672 | 0 | −360 | −1 | +7 | +2 | −31 | −30 | −11
Once-only | 0 | −3858 | 0 | −1220 | −7 | +39 | +17 | −171 | −158 | −62
CRC-SPIN
SIG 45-75, 5 | 0 | 4935 | 0 | 1680 | 12 | 24 | 9 | 280 | 264 | 102
Increase interval to 10y | 0 | −1765 | 0 | −269 | 0 | +2 | +1 | −12 | −12 | −4
Once-only | 0 | −3946 | 0 | −1029 | −6 | +27 | +12 | −115 | −107 | −42
MISCAN
SIG 45-75, 5 | 0 | 4389 | 0 | 2119 | 12 | 39 | 11 | 269 | 241 | 98
Increase interval to 10y | 0 | −1443 | 0 | −318 | 0 | +4 | +2 | −23 | −22 | −9
Once-only | 0 | −3400 | 0 | −1350 | −7 | +27 | +15 | −162 | −144 | −59
Sigmoidoscopy with interval fecal immunochemical testing (SIG+FIT)
SimCRC
SIG+FIT 45-75, 10_1 | 16648 | 2568 | 0 | 2102 | 11 | 18 | 4 | 363 | 338 | 133
Increase FIT interval to 2y | −6712 | +189 | 0 | −267 | −1 | +3 | +1 | −9 | −9 | −3
CRC-SPIN
SIG+FIT 45-75, 10_1 | 16322 | 2525 | 0 | 2237 | 14 | 15 | 5 | 330 | 309 | 120
Increase FIT interval to 2y | −6509 | +192 | 0 | −282 | −1 | +2 | +1 | −9 | −8 | −3
MISCAN
SIG+FIT 45-75, 10_1 | 15466 | 2393 | 0 | 2331 | 13 | 37 | 9 | 304 | 272 | 111
Increase FIT interval to 2y | −6348 | +200 | 0 | −201 | 0 | +2 | +1 | −10 | −9 | −4
Computed tomographic colonography (CTC)
SimCRC
CTC 45-75, 5 | 0 | 0 | 4804 | 1788 | 11 | 18 | 5 | 355 | 332 | 130
Increase interval to 10y | 0 | 0 | −1664 | −329 | −1 | +6 | +2 | −27 | −27 | −10
CRC-SPIN
CTC 45-75, 5 | 0 | 0 | 4893 | 1791 | 13 | 18 | 6 | 313 | 294 | 114
Increase interval to 10y | 0 | 0 | −1714 | −327 | −1 | +4 | +2 | −24 | −22 | −9
MISCAN
CTC 45-75, 5 | 0 | 0 | 4881 | 1672 | 10 | 42 | 11 | 283 | 251 | 103
Increase interval to 10y | 0 | 0 | −1717 | −356 | −1 | +8 | +3 | −48 | −46 | −18
Fecal immunochemical testing (FIT)
SimCRC
FIT 45-75, 1 | 19680 | 0 | 0 | 1602 | 10 | 26 | 6 | 348 | 321 | 127
Increase interval to 2y | −7949 | 0 | 0 | −455 | −2 | +11 | +3 | −31 | −32 | −11
Increase interval to 3y | −11205 | 0 | 0 | −685 | −3 | +19 | +5 | −63 | −63 | −23
CRC-SPIN
FIT 45-75, 1 | 18950 | 0 | 0 | 1824 | 13 | 20 | 6 | 314 | 293 | 115
Increase interval to 2y | −7530 | 0 | 0 | −463 | −2 | +8 | +3 | −33 | −32 | −12
Increase interval to 3y | −10650 | 0 | 0 | −714 | −3 | +15 | +5 | −66 | −63 | −24
MISCAN
FIT 45-75, 1 | 19607 | 0 | 0 | 1620 | 10 | 46 | 10 | 291 | 256 | 106
Increase interval to 2y | −7935 | 0 | 0 | −448 | −2 | +9 | +3 | −36 | −36 | −13
Increase interval to 3y | −11170 | 0 | 0 | −672 | −3 | +14 | +5 | −66 | −64 | −24
Multitarget stool DNA test (sDNA-FIT)
SimCRC
sDNA-FIT 45-75, 1 | 13888 | 0 | 0 | 2462 | 12 | 19 | 4 | 363 | 337 | 133
Increase interval to 2y | −4345 | 0 | 0 | −552 | −1 | +6 | +1 | −11 | −12 | −4
Increase interval to 3y | −6614 | 0 | 0 | −880 | −2 | +11 | +3 | −28 | −29 | −10
CRC-SPIN
sDNA-FIT 45-75, 1 | 13494 | 0 | 0 | 2617 | 14 | 15 | 5 | 331 | 309 | 121
Increase interval to 2y | −4196 | 0 | 0 | −528 | −1 | +4 | +1 | −12 | −12 | −4
Increase interval to 3y | −6389 | 0 | 0 | −845 | −2 | +8 | +2 | −30 | −28 | −11
MISCAN
sDNA-FIT 45-75, 1 | 13698 | 0 | 0 | 2515 | 12 | 38 | 9 | 306 | 272 | 112
Increase interval to 2y | −4263 | 0 | 0 | −561 | −1 | +5 | +1 | −14 | −15 | −5
Increase interval to 3y | −6494 | 0 | 0 | −887 | −2 | +10 | +3 | −33 | −34 | −12

COL – colonoscopy; SIG – sigmoidoscopy; CTC – computed tomographic colonography; CRC – colorectal cancer; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; DLG – days of life gained per person, compared with no screening.

* These strategies were selected for illustration purposes. Inclusion in this table should not be interpreted as endorsement of these strategies.

† Includes deaths from complications of screening.

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.