# Appendix 15 Efficiency Ratios From the Sensitivity Analysis on Colonoscopy Sensitivity

Appendix Table 15.1a Efficient Colonoscopy Screening Strategies, by Values for Colonoscopy Sensitivity for SimCRC

Strategy | Efficiency ratio (Δ COL / Δ LYG), by values of COL sensitivity
Strategy | Base-case analysis | Sensitivity analysis^†^
COL 55-70, 15 | -- | --
COL 50-70, 15 | 6^*^ | 6^*^
COL 45-70, 15 | 6 | 6
COL 45-75, 15 | 39^*^ | 38^*^
COL 45-70, 10 | 34 | 32
COL 45-75, 10 | 64 | 62
COL 45-85, 10 | 394^*^ | 357^*^
COL 45-70, 5 | 180^*^ | 141
COL 45-75, 5 | 178 | 161
COL 45-80, 5 | 428 | 398
COL 45-85, 5 | 1445 | 1324

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

† Refer to Table 7 for values used in the sensitivity analysis.

Note: Strategies that were dominated in both scenarios are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 15.1b Efficient Colonoscopy Screening Strategies, by Values for Colonoscopy Sensitivity for CRC-SPIN

Strategy | Efficiency ratio (Δ COL / Δ LYG), by values of COL sensitivity
Strategy | Base-case analysis | Sensitivity analysis^†^
COL 55-70, 15 | -- | --
COL 55-70, 10 | 17^*^ | 16^*^
COL 50-70, 15 | 8^*^ | 8^*^
COL 45-70, 15 | 7 | 7
COL 45-75, 15 | 59^*^ | 60^*^
COL 45-70, 10 | 44 | 44
COL 45-75, 10 | 112 | 108
COL 45-85, 10 | 828^*^ | 813^*^
COL 45-70, 5 | 179 | 161
COL 45-75, 5 | 344 | 349
COL 45-80, 5 | 736 | 663
COL 45-85, 5 | 2190 | 3491

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

† Refer to Table 7 for values used in the sensitivity analysis.

Note: Strategies that were dominated in both scenarios are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 15.1c Efficient Colonoscopy Screening Strategies, by Values for Colonoscopy Sensitivity for MISCAN

Strategy | Efficiency ratio (Δ COL / Δ LYG), by values of COL sensitivity
Strategy | Base-case analysis | Sensitivity analysis^†^
COL 55-70, 15 | -- | --
COL 55-70, 10 | 22^*^ | 21^*^
COL 50-70, 15 | 18 | 19
COL 45-70, 15 | 85^*^ | 169^*^
COL 50-80, 15 | 56^*^ | 54^*^
COL 50-70, 10 | 28 | 27
COL 45-75, 15 | 38^*^ | 39^*^
COL 45-70, 10 | 45 | 51^*^
COL 50-80, 10 | 86^*^ | 83^*^
COL 45-75, 10 | 52 | 50
COL 45-85, 10 | 227^*^ | 216^*^
COL 50-70, 5 | 120^*^ | 681^*^
COL 50-75, 5 | 367^*^ | 205^*^
COL 45-70, 5 | 84 | 79
COL 45-75, 5 | 116 | 111
COL 45-80, 5 | 169 | 166
COL 45-85, 5 | 926 | 822

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

† Refer to Table 7 for values used in the sensitivity analysis.

Note: Strategies that were dominated in both scenarios are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 15.2a Efficient FIT Screening Strategies, by Values for Colonoscopy Sensitivity for SimCRC

Strategy | Efficiency ratio (Δ COL / Δ LYG), by values of COL sensitivity
Strategy | Base-case analysis | Sensitivity analysis^†^
FIT 55-70, 3 | -- | --
FIT 50-70, 3 | 2 | 2
FIT 45-70, 3 | 3 | 3
FIT 45-75, 3 | 5 | 5
FIT 45-80, 3 | 7^*^ | 7
FIT 45-70, 2 | 8^*^ | 12^*^
FIT 45-85, 3 | 10^*^ | 13^*^
FIT 45-75, 2 | 7 | 7
FIT 45-80, 2 | 10 | 10
FIT 45-85, 2 | 19^*^ | 19^*^
FIT 45-70, 1 | 21^*^ | 24^*^
FIT 45-75, 1 | 16 | 17
FIT 45-80, 1 | 19 | 18
FIT 45-85, 1 | 39 | 38

COL – colonoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

† Refer to Table 7 for values used in the sensitivity analysis.

Note: Strategies that were dominated in both scenarios are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 15.2b Efficient FIT Screening Strategies, by Values for Colonoscopy Sensitivity for CRC-SPIN

Strategy | Efficiency ratio (Δ COL / Δ LYG), by values of COL sensitivity
Strategy | Base-case analysis | Sensitivity analysis^†^
FIT 55-70, 3 | -- | --
FIT 55-75, 3 | Dominated | 7^*^
FIT 50-70, 3 | 4 | 4
FIT 45-70, 3 | 5 | 5
FIT 45-75, 3 | 7^*^ | 8^*^
FIT 45-80, 3 | 8^*^ | 8^*^
FIT 45-70, 2 | 7 | 7
FIT 45-75, 2 | 9 | 10
FIT 45-80, 2 | 12 | 13
FIT 45-85, 2 | 25^*^ | 23^*^
FIT 45-70, 1 | 14 | 14
FIT 45-75, 1 | 16 | 16
FIT 45-80, 1 | 27 | 25
FIT 45-85, 1 | 43 | 45

COL – colonoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

† Refer to Table 7 for values used in the sensitivity analysis.

Note: Strategies that were dominated in both scenarios are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 15.2c Efficient FIT Screening Strategies, by Values for Colonoscopy Sensitivity for MISCAN

Strategy | Efficiency ratio (Δ COL / Δ LYG), by values of COL sensitivity
Strategy | Base-case analysis | Sensitivity analysis^†^
FIT 55-70, 3 | -- | --
FIT 55-75, 3 | 5 | 5
FIT 50-70, 3 | 6^*^ | 6^*^
FIT 55-70, 2 | 13^*^ | 14^*^
FIT 55-80, 3 | 6^*^ | 6^*^
FIT 50-75, 3 | 5 | 5
FIT 45-70, 3 | 6^*^ | 6^*^
FIT 55-85, 3 | 7^*^ | 7^*^
FIT 50-80, 3 | 6 | 6
FIT 55-75, 2 | 14^*^ | 14^*^
FIT 45-75, 3 | 7^*^ | 7^*^
FIT 50-85, 3 | 10^*^ | 10^*^
FIT 50-70, 2 | 94^*^ | 9^*^
FIT 45-80, 3 | 6 | 6
FIT 50-75, 2 | 10^*^ | 10^*^
FIT 45-85, 3 | 9^*^ | 9^*^
FIT 50-80, 2 | 8 | 8
FIT 50-85, 2 | 12^*^ | 12^*^
FIT 45-75, 2 | 9^*^ | 10^*^
FIT 45-80, 2 | 8 | 8
FIT 45-85, 2 | 12 | 12
FIT 50-75, 1 | 29^*^ | 32^*^
FIT 50-80, 1 | 18^*^ | 18^*^
FIT 50-85, 1 | 18^*^ | 18^*^
FIT 45-75, 1 | 15^*^ | 15^*^
FIT 45-80, 1 | 14 | 14
FIT 45-85, 1 | 19 | 19

COL – colonoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

† Refer to Table 7 for values used in the sensitivity analysis.

Note: Strategies that were dominated in both scenarios are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.