# Appendix 14 Model-Estimated Outcomes and Efficiency Ratios With Increasing Population Risk of Colorectal Cancer

Appendix Figure 14.1 Prevalence of Adenomas by Age From Autopsy Studies and as Estimated by SimCRC, by Risk Scenario

Models were calibrated to 3 scenarios for colorectal cancer risk: IRR of 1.19 (base-case analysis), IRR of 1 (sensitivity analysis using original models calibrated to SEER data from 1975-1979), and IRR 1.52 (sensitivity analysis with higher increase in population risk). Increased colorectal cancer risk was simulated via increased risk of adenoma onset.

Estimated adenoma prevalence for these scenarios is shown in Appendix Figure 14.1 for SimCRC, Appendix Figure 14.2 for CRC-SPIN, and Appendix Figure 14.3 for MISCAN.

Adenoma prevalence by age and risk scenario (SimCRC)

Appendix Figure 14.2 Prevalence of Adenomas by Age From Autopsy Studies and as Estimated by CRC-SPIN, by Risk Scenario

Adenoma prevalence by age and risk scenario (CRC-SPIN)

Appendix Figure 14.3 Prevalence of Adenomas by Age From Autopsy Studies and as Estimated by MISCAN, by Risk Scenario

Adenoma prevalence by age and risk scenario (MISCAN)

Appendix Figure 14.4 Prevalence of Adenomas by Age From Autopsy Studies and as Estimated by Models Calibrated to an IRR of 1, by Model

We also compare estimated prevalence across models for a given risk scenario. For the original models (IRR of 1), the comparison is in Figure 2 but is repeated here for convenience (Appendix Figure 14.4); comparisons across models for IRR of 1.19 and 1.52 are in Appendix Figures 14.5 and 14.6 below.

Adenoma prevalence by age and model (IRR=1.0)

Appendix Figure 14.5 Prevalence of Adenomas by Age From Autopsy Studies and as Estimated by Models Calibrated to an IRR of 1.19, by Model

Adenoma prevalence by age and model (IRR=1.19)

Appendix Figure 14.6 Prevalence of Adenomas by Age From Autopsy Studies and as Estimated by Models Calibrated to an IRR of 1.52, by Model

Adenoma prevalence by age and model (IRR=1.52)

Appendix Figure 14.7 Estimated Cumulative Number of Colorectal Cancer Cases and of Colorectal Cancer Deaths per 1,000 Persons From Age 40 to Age 95 in the Absence of Screening, by Model Assuming IRR = 1

Finally, we also show how the estimated cumulative probability of being diagnosed with colorectal cancer and of dying from colorectal cancer from age 40 to age 95 in the absence of screening compares across models by risk scenario. For the original models (IRR of 1), the comparison is in Figure 11 but is repeated here for convenience (Appendix Figure 14.7); comparisons across models for IRR of 1.19 and 1.52 are in Appendix Figures 14.8 and 14.9 below.

Cumulative number of colorectal cancer cases and of colorectal cancer deaths per 1000 by age (IRR = 1.0)

Appendix Figure 14.8 Estimated Cumulative Number of Colorectal Cancer Cases and of Colorectal Cancer Deaths per 1,000 Persons From Age 40 to Age 95 in the Absence of Screening, by Model Assuming IRR = 1.19

Cumulative number of colorectal cancer cases and of colorectal cancer deaths per 1000 by age (IRR = 1.19)

Appendix Figure 14.9 Estimated Cumulative Number of Colorectal Cancer Cases and of Colorectal Cancer Deaths per 1,000 Persons From Age 40 to Age 95 in the Absence of Screening, by Model Assuming IRR = 1.52

Cumulative number of colorectal cancer cases and of colorectal cancer deaths per 1000 by age (IRR = 1.52)

Appendix Table 14.1a Efficient Colonoscopy Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for SimCRC

Appendix Tables 14.1–14.7 show efficient screening strategies with estimated LYG as the measure of the benefit of screening, by IRR for each class of screening modality and model.

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
COL 55-70, 15 | -- | -- | --
COL 50-70, 15 | 7^*^ | 6^*^ | 5^*^
COL 45-70, 15 | 6 | 6 | 5
COL 45-75, 15 | 44^*^ | 39^*^ | 33^*^
COL 45-70, 10 | 39 | 34 | 29
COL 45-75, 10 | 73 | 64 | 54
COL 45-85, 10 | 427^*^ | 394^*^ | 337^*^
COL 45-70, 5 | 213^*^ | 180^*^ | 140
COL 45-75, 5 | 208 | 178 | 141
COL 45-80, 5 | 496 | 428 | 376
COL 45-85, 5 | 1614 | 1445 | 1181

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

Appendix Table 14.1b Efficient Colonoscopy Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for CRC-SPIN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
COL 55-70, 15 | -- | -- | --
COL 55-70, 10 | 17^*^ | 17^*^ | 15^*^
COL 50-70, 15 | 9^*^ | 8^*^ | 7^*^
COL 45-70, 15 | 8 | 7 | 7
COL 45-75, 15 | 68^*^ | 59^*^ | 54^*^
COL 45-70, 10 | 50 | 44 | 40
COL 45-75, 10 | 120 | 112 | 103
COL 45-85, 10 | 588^*^ | 828^*^ | 646^*^
COL 45-70, 5 | 211 | 179 | 147
COL 45-75, 5 | 367 | 344 | 306
COL 45-80, 5 | 860 | 736 | 768
COL 45-85, 5 | 2637 | 2190 | 2558

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.1c Efficient Colonoscopy Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for MISCAN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
COL 55-70, 15 | -- | -- | --
COL 55-70, 10 | 28^*^ | 22^*^ | 17^*^
COL 50-70, 15 | 19 | 18 | 15
COL 45-70, 15 | 126^*^ | 85^*^ | 77^*^
COL 50-80, 15 | 73^*^ | 56^*^ | 40^*^
COL 50-70, 10 | 35 | 28 | 20
COL 45-75, 15 | 48^*^ | 38^*^ | 30^*^
COL 45-70, 10 | 58 | 45 | 34
COL 50-80, 10 | 113^*^ | 86^*^ | 61^*^
COL 45-75, 10 | 65 | 52 | 36
COL 45-85, 10 | 314^*^ | 227^*^ | 160^*^
COL 50-70, 5 | 142^*^ | 120^*^ | 89^*^
COL 50-75, 5 | 373^*^ | 367^*^ | Dominated
COL 45-70, 5 | 106 | 84 | 61
COL 45-75, 5 | 155 | 116 | 79
COL 45-80, 5 | 234 | 169 | 119
COL 45-85, 5 | 1245 | 926 | 585

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.2a Efficient FIT and sDNA-FIT Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for SimCRC

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
FIT 55-70, 3 | -- | -- | --
FIT 50-70, 3 | 3 | 2 | 2
FIT 45-70, 3 | 4 | 3 | 3
FIT 50-75, 3 | 5^*^ | Dominated | Dominated
FIT 45-75, 3 | 6 | 5 | 5
FIT 45-80, 3 | 8 | 7^*^ | 7^*^
FIT 45-70, 2 | 15^*^ | 8^*^ | 7^*^
FIT 45-85, 3 | 14^*^ | 10^*^ | 9^*^
FIT 45-75, 2 | 8 | 7 | 6
FIT 45-80, 2 | 11 | 10 | 9
FIT 45-85, 2 | 20^*^ | 19^*^ | 18^*^
FIT 45-70, 1 | 25^*^ | 21^*^ | 18^*^
FIT 45-75, 1 | 18 | 16 | 14
FIT 45-80, 1 | 20 | 19 | 17
FIT 45-85, 1 | 44 | 39 | 36
sDNA-FIT 45-75, 2 | 104^*^ | 91^*^ | 64^*^
sDNA-FIT 45-80, 2 | 199^*^ | 176^*^ | 285^*^
sDNA-FIT 45-85, 2 | 190^*^ | 175^*^ | 106^*^
sDNA-FIT 45-70, 1 | 134^*^ | 116^*^ | Dominated
sDNA-FIT 45-75, 1 | 117^*^ | 103^*^ | 75^*^
sDNA-FIT 45-80, 1 | 91 | 81 | 63
sDNA-FIT 45-85, 1 | 108 | 95 | 87

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.2b Efficient FIT and sDNA-FIT Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for CRC-SPIN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
FIT 55-70, 3 | -- | -- | --
FIT 55-75, 3 | 7^*^ | Dominated | Dominated
FIT 50-70, 3 | 4 | 4 | 4
FIT 55-70, 2 | 5^*^ | Dominated | Dominated
FIT 50-75, 3 | 8^*^ | Dominated | Dominated
FIT 45-70, 3 | 5 | 5 | 4
FIT 50-70, 2 | 16^*^ | Dominated | Dominated
FIT 45-75, 3 | 8^*^ | 7^*^ | 7^*^
FIT 45-80, 3 | 9^*^ | 8^*^ | 8^*^
FIT 45-70, 2 | 7 | 7 | 6
FIT 45-75, 2 | 10 | 9 | 9
FIT 45-80, 2 | 16^*^ | 12 | 13^*^
FIT 45-85, 2 | 20^*^ | 25^*^ | 15^*^
FIT 45-70, 1 | 15 | 14 | 12
FIT 45-75, 1 | 17 | 16 | 15
sDNA-FIT 45-70, 2 | 69^*^ | 52^*^ | 53^*^
FIT 45-80, 1 | 30 | 27 | 24
FIT 45-85, 1 | 54 | 43 | 52^*^
sDNA-FIT 45-75, 2 | 83^*^ | 135^*^ | 253^*^
sDNA-FIT 45-80, 2 | 151^*^ | 75^*^ | 69^*^
sDNA-FIT 45-85, 2 | 107^*^ | 69^*^ | 67^*^
sDNA-FIT 45-70, 1 | 87^*^ | 62^*^ | 51^*^
sDNA-FIT 45-75, 1 | 64 | 53 | 44
sDNA-FIT 45-80, 1 | 69 | 62 | 60
sDNA-FIT 45-85, 1 | 131 | 111 | 101

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.2c Efficient FIT and sDNA-FIT Screening Strategies with Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for MISCAN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
FIT 55-70, 3 | -- | -- | --
FIT 55-75, 3 | 5 | 5 | 4
FIT 50-70, 3 | 42^*^ | 6^*^ | 5^*^
FIT 55-70, 2 | 13^*^ | 13^*^ | Dominated
FIT 55-80, 3 | 6^*^ | 6^*^ | 5^*^
FIT 50-75, 3 | 5 | 5 | 4
FIT 45-70, 3 | 7^*^ | 6^*^ | 5^*^
FIT 55-85, 3 | 8^*^ | 7^*^ | Dominated
FIT 50-80, 3 | 7 | 6 | 5^*^
FIT 55-75, 2 | 16^*^ | 14^*^ | Dominated
FIT 50-85, 3 | 11^*^ | 10^*^ | 6^*^
FIT 45-75, 3 | 7^*^ | 7^*^ | 5
FIT 50-70, 2 | 211^*^ | 94^*^ | 7^*^
FIT 55-80, 2 | 40^*^ | Dominated | Dominated
FIT 45-80, 3 | 7 | 6 | 5
FIT 50-75, 2 | 11^*^ | 10^*^ | 10^*^
FIT 45-85, 3 | 10^*^ | 9^*^ | 8^*^
FIT 45-70, 2 | 14^*^ | Dominated | Dominated
FIT 50-80, 2 | 9^*^ | 8 | 7^*^
FIT 50-85, 2 | 10^*^ | 12^*^ | 8^*^
FIT 45-75, 2 | 9^*^ | 9^*^ | 7^*^
FIT 45-80, 2 | 9 | 8 | 7
FIT 45-85, 2 | 14 | 12 | 10
FIT 50-75, 1 | 33^*^ | 29^*^ | Dominated
FIT 45-70, 1 | 38^*^ | Dominated | Dominated
FIT 50-80, 1 | 20^*^ | 18^*^ | 16^*^
FIT 50-85, 1 | 21^*^ | 18^*^ | 16^*^
FIT 45-75, 1 | 16^*^ | 15^*^ | 13^*^
FIT 45-80, 1 | 15 | 14 | 12
FIT 45-85, 1 | 23 | 19 | 15
sDNA-FIT 45-80, 2 | 31^*^ | 26^*^ | Dominated
sDNA-FIT 45-85, 2 | 2580^*^ | 375^*^ | 350^*^
sDNA-FIT 45-75, 1 | 460^*^ | 251^*^ | 191^*^
sDNA-FIT 45-80, 1 | 141^*^ | 104^*^ | 85^*^
sDNA-FIT 45-85, 1 | 125 | 94 | 76

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.3a Efficient Sigmoidoscopy Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for SimCRC

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
SIG 55-70, 10 | -- | -- | --
SIG 45-70, 10 | 5 | 4 | 4
SIG 45-75, 10 | 15^*^ | 13^*^ | 12^*^
SIG 45-85, 10 | 19^*^ | Dominated | Dominated
SIG 45-70, 5 | 12 | 11 | 10
SIG 45-75, 5 | 22 | 20 | 17
SIG 45-80, 5 | 41 | 38 | 34
SIG 45-85, 5 | 98 | 89 | 78

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; SIG – sigmoidoscopy; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.3b Efficient Sigmoidoscopy Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for CRC-SPIN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
SIG 55-70, 10 | -- | -- | --
SIG 45-70, 10 | 6 | 5 | 5
SIG 45-75, 10 | 18 | 18 | 17^*^
SIG 45-85, 10 | 74^*^ | 68^*^ | 21^*^
SIG 45-70, 5 | 23 | 20 | 16
SIG 45-75, 5 | 29 | 27 | 24
SIG 45-80, 5 | 51 | 49 | 45
SIG 45-85, 5 | 113 | 98 | 77

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; SIG – sigmoidoscopy; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.3c Efficient Sigmoidoscopy Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for MISCAN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
SIG 55-70, 10 | -- | -- | --
SIG 55-75, 10 | 16^*^ | Dominated | Dominated
SIG 50-70, 10 | 9 | 8 | 7
SIG 55-70, 5 | 13^*^ | 11^*^ | 9^*^
SIG 45-70, 10 | 263^*^ | 73^*^ | 37^*^
SIG 50-80, 10 | 26^*^ | 22^*^ | 19^*^
SIG 55-75, 5 | 193^*^ | Dominated | Dominated
SIG 45-75, 10 | 21^*^ | 18^*^ | 15^*^
SIG 50-70, 5 | 16 | 14 | 11
SIG 45-85, 10 | 25^*^ | 21^*^ | Dominated
SIG 50-75, 5 | 23^*^ | 19^*^ | 16^*^
SIG 50-80, 5 | 27^*^ | 23^*^ | 19^*^
SIG 45-70, 5 | 17 | 15 | 12
SIG 50-85, 5 | 32^*^ | 26^*^ | 21^*^
SIG 45-75, 5 | 22 | 19 | 16
SIG 45-80, 5 | 36 | 29 | 24
SIG 45-85, 5 | 101 | 78 | 64

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; SIG – sigmoidoscopy; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.4a Efficient 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for SimCRC

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
SIG+FIT 55-70, 10_2 | -- | -- | --
SIG+FIT 50-70, 10_2 | 6^*^ | 6^*^ | 5^*^
SIG+FIT 45-70, 10_2 | 6 | 5 | 5
SIG+FIT 45-75, 10_2 | 16 | 15 | 14
SIG+FIT 45-80, 10_2 | 24 | 22 | 20
SIG+FIT 45-70, 10_1 | 25^*^ | 22^*^ | 19^*^
SIG+FIT 45-85, 10_2 | 58^*^ | 54^*^ | 48^*^
SIG+FIT 45-75, 10_1 | 39^*^ | 34 | 27
SIG+FIT 45-80, 10_1 | 39 | 35 | 32
SIG+FIT 45-85, 10_1 | 87 | 81 | 70

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; SIG – sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.4b Efficient 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for CRCSPIN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
SIG+FIT 55-70, 10_2 | -- | -- | --
SIG+FIT 50-70, 10_2 | 9^*^ | 8^*^ | 7^*^
SIG+FIT 45-70, 10_2 | 8 | 7 | 6
SIG+FIT 45-75, 10_2 | 22 | 22 | 19
SIG+FIT 45-80, 10_2 | 25 | 25 | 31^*^
SIG+FIT 45-70, 10_1 | 71^*^ | 88^*^ | 31^*^
SIG+FIT 45-85, 10_2 | 63^*^ | 78^*^ | 40^*^
SIG+FIT 45-75, 10_1 | 36 | 34 | 29
SIG+FIT 45-80, 10_1 | 47 | 53 | 42
SIG+FIT 45-85, 10_1 | 93 | 64 | 68

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; SIG – sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.4c Efficient 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for MISCAN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
SIG+FIT 55-70, 10_2 | -- | -- | --
SIG+FIT 55-70, 10_1 | 17^*^ | 14^*^ | 11^*^
SIG+FIT 55-75, 10_2 | 15^*^ | 13^*^ | Dominated
SIG+FIT 55-80, 10_2 | 15^*^ | 13^*^ | Dominated
SIG+FIT 50-70, 10_2 | 10 | 9 | 7^*^
SIG+FIT 50-75, 10_2 | 11 | 9 | 7
SIG+FIT 45-70, 10_2 | 27^*^ | 24^*^ | 18^*^
SIG+FIT 50-70, 10_1 | 29^*^ | 24^*^ | 20^*^
SIG+FIT 50-80, 10_2 | 24^*^ | 20^*^ | 17^*^
SIG+FIT 50-85, 10_2 | 25^*^ | 21^*^ | 17^*^
SIG+FIT 50-75, 10_1 | 22^*^ | 18^*^ | 15^*^
SIG+FIT 45-75, 10_2 | 17^*^ | 15^*^ | 13^*^
SIG+FIT 45-80, 10_2 | 17 | 15 | 12
SIG+FIT 45-70, 10_1 | 22^*^ | 19^*^ | 14^*^
SIG+FIT 50-80, 10_1 | 24^*^ | 20^*^ | 16^*^
SIG+FIT 45-85, 10_2 | 45^*^ | 38^*^ | 31^*^
SIG+FIT 50-85, 10_1 | 26^*^ | 21^*^ | 17^*^
SIG+FIT 45-75, 10_1 | 26^*^ | 22^*^ | 16^*^
SIG+FIT 45-80, 10_1 | 25 | 21 | 16
SIG+FIT 45-85, 10_1 | 57 | 46 | 36

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; SIG – sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.5a Efficient Computed Tomographic Colonography Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for SimCRC

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
CTC 55-70, 10 | -- | -- | --
CTC 45-70, 10 | 4 | 4 | 3
CTC 45-75, 10 | 14^*^ | 13^*^ | 12^*^
CTC 45-85, 10 | 18^*^ | Dominated | Dominated
CTC 45-70, 5 | 12 | 11 | 10
CTC 45-75, 5 | 21 | 19 | 18
CTC 45-80, 5 | 42 | 38 | 35
CTC 45-85, 5 | 102 | 104 | 85

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; CTC – computed tomographic colonography; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.5b Efficient Computed Tomographic Colonography Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for CRC-SPIN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
CTC 55-70, 10 | -- | -- | --
CTC 45-70, 10 | 5 | 5 | 4
CTC 45-75, 10 | 15^*^ | 15^*^ | 13^*^
CTC 45-85, 10 | 19^*^ | 19^*^ | 17^*^
CTC 45-70, 5 | 14 | 13 | 12
CTC 45-75, 5 | 22 | 21 | 19
CTC 45-80, 5 | 39 | 37 | 32
CTC 45-85, 5 | 79 | 73 | 63

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; CTC – computed tomographic colonography; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Appendix Table 14.5c Efficient Computed Tomographic Colonography Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by IRR for MISCAN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | IRR = 1.0 | IRR = 1.19 | IRR = 1.52
CTC 55-70, 10 | -- | -- | --
CTC 55-75, 10 | 8^*^ | Dominated | Dominated
CTC 50-70, 10 | 6 | 5 | 5
CTC 55-70, 5 | 9^*^ | 8^*^ | 7^*^
CTC 50-80, 10 | 11^*^ | 10^*^ | 8^*^
CTC 45-75, 10 | 14^*^ | Dominated | Dominated
CTC 55-75, 5 | 10^*^ | 9^*^ | 7^*^
CTC 50-70, 5 | 9 | 8 | 6
CTC 55-80, 5 | 11^*^ | 10^*^ | Dominated
CTC 50-75, 5 | 10 | 9 | 7
CTC 45-70, 5 | 17^*^ | 21^*^ | 12^*^
CTC 50-80, 5 | 16^*^ | 13^*^ | 11^*^
CTC 50-85, 5 | 20^*^ | 17^*^ | 14^*^
CTC 45-75, 5 | 12 | 11 | 8
CTC 45-80, 5 | 16 | 13 | 11
CTC 45-85, 5 | 37 | 32 | 25

Note: Strategies that were dominated in all 3 risk scenarios are not shown.

COL – colonoscopy; LYG – life-years gained compared with no screening; CTC – computed tomographic colonography; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).