# Appendix 13 Efficiency Status and Efficiency Ratios With Estimated Colorectal Cancer Deaths

Appendix Table 13.1 Efficient Frontier Status for Colonoscopy Screening Strategies, According to Whether Life-Years Gained or the Number of Colorectal Cancer Deaths Averted Are Used for the Benefit of Screening

Strategy | Efficient frontier status, by model and benefit variable
Strategy | SimCRC | | CRC-SPIN | | MISCAN
Strategy | LYG | CRC deaths averted | LYG | CRC deaths averted | LYG | CRC deaths averted
COL 55-70, 15 | E | E | E | E | E | E
COL 55-70, 10 | -- | NE | NE | NE | NE | NE
COL 50-70, 15 | NE | E | NE | E | E | NE
COL 55-85, 15 | -- | NE | -- | -- | -- | NE
COL 45-70, 15 | E | -- | E | NE | NE | --
COL 55-75, 10 | -- | NE | -- | -- | -- | E
COL 50-80, 15 | -- | NE | -- | NE | NE | NE
COL 55-85, 10 | -- | -- | -- | -- | -- | NE
COL 50-70, 10 | -- | NE | -- | NE | E | NE
COL 45-75, 15 | NE | E | NE | E | NE | NE
COL 45-70, 10 | E | NE | E | NE | E | --
COL 50-80, 10 | -- | NE | -- | NE | NE | E
COL 45-75, 10 | E | E | E | E | E | NE
COL 55-75, 5 | -- | -- | -- | -- | -- | NE
COL 45-85, 10 | NE | E | NE | E | NE | NE
COL 55-80, 5 | -- | -- | -- | -- | -- | NE
COL 50-70, 5 | -- | -- | -- | -- | NE | NE
COL 55-85, 5 | -- | -- | -- | -- | -- | NE
COL 50-75, 5 | -- | -- | -- | -- | NE | NE
COL 50-80, 5 | -- | -- | -- | -- | -- | E
COL 50-85, 5 | -- | -- | -- | -- | -- | NE
COL 45-70, 5 | NE | NE | E | NE | E | NE
COL 45-75, 5 | E | NE | E | E | E | NE
COL 45-80, 5 | E | E | E | E | E | E
COL 45-85, 5 | E | E | E | E | E | E

COL – colonoscopy; E – strategy is efficient; NE – strategy is near efficient; -- indicates strategy is dominated and does not meet the criteria for near efficiency.

Note: Strategies that were dominated with both measures across all models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 13.2 Efficient Frontier Status for FIT and sDNA-FIT Screening Strategies, According to Whether Life-Years Gained or the Number of Colorectal Cancer Deaths Averted Are Used for the Benefit of Screening

Strategy | Efficient frontier status, by model and benefit variable
Strategy | SimCRC | | CRC-SPIN | | MISCAN
Strategy | LYG | CRC deaths averted | LYG | CRC deaths averted | LYG | CRC deaths averted
FIT 55-70, 3 | E | E | E | E | E | E
FIT 55-75, 3 | -- | E | -- | E | E | E
FIT 50-70, 3 | E | -- | E | NE | NE | --
FIT 55-70, 2 | -- | -- | -- | NE | NE | --
FIT 55-80, 3 | -- | E | -- | E | NE | E
FIT 45-70, 3 | E | -- | E | -- | NE | --
FIT 50-75, 3 | -- | NE | -- | NE | E | --
FIT 55-85, 3 | -- | NE | -- | NE | NE | E
FIT 55-75, 2 | -- | -- | -- | NE | NE | --
FIT 50-80, 3 | -- | E | -- | E | E | NE
FIT 50-70, 2 | -- | -- | -- | NE | NE | --
FIT 45-75, 3 | E | NE | NE | NE | NE | --
FIT 50-85, 3 | -- | E | -- | NE | NE | NE
FIT 55-80, 2 | -- | NE | -- | E | -- | NE
FIT 45-80, 3 | NE | NE | NE | NE | E | --
FIT 45-70, 2 | NE | -- | E | NE | -- | --
FIT 50-75, 2 | -- | -- | -- | NE | NE | --
FIT 45-85, 3 | NE | E | -- | E | NE | --
FIT 55-85, 2 | -- | NE | -- | NE | -- | E
FIT 55-70, 1 | -- | -- | -- | NE | -- | --
FIT 50-80, 2 | -- | NE | -- | NE | E | NE
FIT 45-75, 2 | E | -- | E | NE | NE | --
FIT 50-85, 2 | -- | NE | -- | NE | NE | E
FIT 45-80, 2 | E | NE | E | E | E | --
FIT 55-75, 1 | -- | -- | -- | NE | -- | --
FIT 45-85, 2 | NE | E | NE | E | E | NE
FIT 55-80, 1 | -- | -- | -- | -- | -- | NE
FIT 50-75, 1 | -- | -- | -- | NE | NE | --
FIT 55-85, 1 | -- | -- | -- | -- | -- | E
FIT 45-70, 1 | NE | -- | E | NE | -- | --
FIT 50-80, 1 | -- | NE | -- | NE | NE | NE
FIT 45-75, 1 | E | -- | E | NE | NE | --
FIT 50-85, 1 | -- | NE | -- | NE | NE | E
sDNA-FIT 45-80, 3 | -- | -- | -- | NE | -- | --
sDNA-FIT 45-70, 2 | -- | -- | NE | -- | -- | --
FIT 45-80, 1 | E | NE | E | NE | E | NE
sDNA-FIT 45-85, 3 | -- | -- | -- | NE | -- | --
FIT 45-85, 1 | E | E | E | E | E | E
sDNA-FIT 50-85, 2 | -- | -- | -- | -- | -- | NE
sDNA-FIT 45-75, 2 | NE | -- | NE | NE | -- | --
sDNA-FIT 45-80, 2 | NE | NE | NE | NE | NE | --
sDNA-FIT 45-85, 2 | NE | NE | NE | NE | NE | NE
sDNA-FIT 45-70, 1 | NE | -- | NE | -- | -- | --
sDNA-FIT 50-80, 1 | -- | -- | -- | -- | -- | NE
sDNA-FIT 50-85, 1 | -- | -- | -- | -- | -- | NE
sDNA-FIT 45-75, 1 | NE | -- | E | NE | NE | --
sDNA-FIT 45-80, 1 | E | NE | E | NE | NE | NE
sDNA-FIT 45-85, 1 | E | E | E | E | E | E

FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); E – strategy is efficient; NE – strategy is near efficient; -- indicates strategy is dominated and does not meet the criteria for near efficiency.

Note: Strategies that were dominated with both measures across all models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 13.3 Efficient Frontier Status for 10-Yearly Sigmoidoscopy Screening Strategies, According to Whether Life-Years Gained or the Number of Colorectal Cancer Deaths Averted Are Used for the Benefit of Screening

Strategy | Efficient frontier status, by model and benefit variable
Strategy | SimCRC | | CRC-SPIN | | MISCAN
Strategy | LYG | CRC deaths averted | LYG | CRC deaths averted | LYG | CRC deaths averted
SIG 55-70, 10 | E | E | E | E | E | E
SIG 55-75, 10 | -- | NE | -- | E | -- | E
SIG 50-70, 10 | -- | E | -- | E | E | NE
SIG 45-70, 10 | E | NE | E | NE | NE | --
SIG 55-85, 10 | -- | NE | -- | NE | -- | NE
SIG 55-70, 5 | -- | NE | -- | NE | NE | NE
SIG 50-80, 10 | -- | NE | -- | NE | NE | NE
SIG 55-75, 5 | -- | NE | -- | NE | -- | NE
SIG 45-75, 10 | NE | E | E | E | NE | NE
SIG 50-70, 5 | -- | NE | -- | NE | E | NE
SIG 45-85, 10 | -- | NE | NE | E | NE | NE
SIG 55-80, 5 | -- | NE | -- | -- | -- | E
SIG 55-85, 5 | -- | -- | -- | -- | -- | NE
SIG 50-75, 5 | -- | NE | -- | NE | NE | NE
SIG 45-70, 5 | E | NE | E | NE | E | --
SIG 50-80, 5 | -- | NE | -- | NE | NE | E
SIG 50-85, 5 | -- | NE | -- | NE | NE | E
SIG 45-75, 5 | E | E | E | NE | E | NE
SIG 45-80, 5 | E | E | E | E | E | NE
SIG 45-85, 5 | E | E | E | E | E | E

SIG – sigmoidoscopy; E – strategy is efficient; NE – strategy is near efficient; -- indicates strategy is dominated and does not meet the criteria for near efficiency.

Note: Strategies that were dominated with both measures across all models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 13.4 Efficient Frontier Status for 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies, According to Whether Life-Years Gained or the Number of Colorectal Cancer Deaths Averted Are Used for the Benefit of Screening

Strategy | Efficient frontier status, by model and benefit variable
Strategy | SimCRC | | CRC-SPIN | | MISCAN
Strategy | LYG | CRC deaths averted | LYG | CRC deaths averted | LYG | CRC deaths averted
SIG+FIT 55-70, 10_2 | E | E | E | E | E | E
SIG+FIT 55-70, 10_1 | -- | -- | -- | NE | NE | NE
SIG+FIT 55-75, 10_2 | -- | E | -- | E | NE | NE
SIG+FIT 50-70, 10_2 | NE | NE | NE | NE | E | --
SIG+FIT 55-80, 10_2 | -- | NE | -- | NE | NE | E
SIG+FIT 50-75, 10_2 | -- | E | -- | E | E | NE
SIG+FIT 45-70, 10_2 | E | -- | E | NE | NE | --
SIG+FIT 55-85, 10_2 | -- | NE | -- | NE | -- | E
SIG+FIT 55-75, 10_1 | -- | -- | -- | NE | -- | NE
SIG+FIT 50-70, 10_1 | -- | -- | -- | NE | NE | --
SIG+FIT 50-80, 10_2 | -- | E | -- | NE | NE | NE
SIG+FIT 55-80, 10_1 | -- | -- | -- | NE | -- | NE
SIG+FIT 50-85, 10_2 | -- | NE | -- | NE | NE | E
SIG+FIT 45-75, 10_2 | E | NE | E | NE | NE | NE
SIG+FIT 55-85, 10_1 | -- | -- | -- | -- | -- | NE
SIG+FIT 50-75, 10_1 | -- | -- | -- | NE | NE | NE
SIG+FIT 45-80, 10_2 | E | E | E | E | E | NE
SIG+FIT 45-70, 10_1 | NE | -- | NE | NE | NE | --
SIG+FIT 50-80, 10_1 | -- | -- | -- | NE | NE | NE
SIG+FIT 45-85, 10_2 | NE | E | NE | E | NE | NE
SIG+FIT 50-85, 10_1 | -- | NE | -- | NE | NE | E
SIG+FIT 45-75, 10_1 | E | NE | E | NE | NE | NE
SIG+FIT 45-80, 10_1 | E | NE | E | NE | E | NE
SIG+FIT 45-85, 10_1 | E | E | E | E | E | E

SIG – sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; E – strategy is efficient; NE – strategy is near efficient; -- indicates strategy is dominated and does not meet the criteria for near efficiency.

Note: Strategies that were dominated with both measures across all models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 13.5 Efficient Frontier Status for Computed Tomographic Colonography Screening Strategies, According to Whether Life-Years Gained or the Number of Colorectal Cancer Deaths Averted Are Used for the Benefit of Screening

Strategy | Efficient frontier status, by model and benefit variable
Strategy | SimCRC | | CRC-SPIN | | MISCAN
Strategy | LYG | CRC deaths averted | LYG | CRC deaths averted | LYG | CRC deaths averted
CTC 55-70, 10 | E | E | E | E | E | E
CTC 55-75, 10 | -- | NE | -- | E | -- | E
CTC 50-70, 10 | -- | E | -- | NE | E | --
CTC 45-70, 10 | E | -- | E | NE | -- | --
CTC 55-70, 5 | -- | -- | -- | NE | NE | NE
CTC 55-85, 10 | -- | -- | -- | NE | -- | E
CTC 50-80, 10 | -- | NE | -- | NE | NE | NE
CTC 55-75, 5 | -- | -- | -- | NE | NE | NE
CTC 45-75, 10 | NE | E | NE | E | -- | --
CTC 50-70, 5 | -- | NE | -- | NE | E | --
CTC 55-80, 5 | -- | -- | -- | NE | NE | E
CTC 45-85, 10 | -- | NE | NE | E | -- | --
CTC 55-85, 5 | -- | -- | -- | NE | -- | E
CTC 50-75, 5 | -- | NE | -- | NE | E | --
CTC 45-70, 5 | E | NE | E | NE | NE | --
CTC 50-80, 5 | -- | NE | -- | NE | NE | NE
CTC 50-85, 5 | -- | NE | -- | NE | NE | E
CTC 45-75, 5 | E | NE | E | NE | E | --
CTC 45-80, 5 | E | E | E | E | E | NE
CTC 45-85, 5 | E | E | E | E | E | E

CTC – computed tomographic colonography; E – strategy is efficient; NE – strategy is near efficient; -- indicates strategy is dominated and does not meet the criteria for near efficiency.

Note: Strategies that were dominated with both measures across all models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 13.6 Efficient Colonoscopy Screening Strategies With the Estimated Number of Colorectal Cancer Deaths Averted as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ CRC deaths averted)
Strategy | SimCRC | CRC-SPIN | MISCAN
COL 55-70, 15 | -- | -- | --
COL 55-70, 10 | N/A^*^ | 423^*^ | N/A^*^
COL 50-70, 15 | 258 | 227 | N/A^*^
COL 55-85, 15 | 659^*^ | Dominated | 529^*^
COL 45-70, 15 | Dominated | 2115^*^ | Dominated
COL 55-75, 10 | 725^*^ | Dominated | 429
COL 50-80, 15 | 346^*^ | 545^*^ | 515^*^
COL 55-85, 10 | Dominated | Dominated | 844^*^
COL 50-70, 10 | 380^*^ | 579^*^ | 712^*^
COL 45-75, 15 | 320 | 423 | 13793^*^
COL 45-70, 10 | 480^*^ | 2029^*^ | Dominated
COL 50-80, 10 | 2418^*^ | 693^*^ | 526
COL 45-75, 10 | 625 | 801 | 2712^*^
COL 55-75, 5 | Dominated | Dominated | 1099^*^
COL 45-85, 10 | 1277 | 2341 | 1539^*^
COL 55-80, 5 | Dominated | Dominated | 7788^*^
COL 50-70, 5 | Dominated | Dominated | 6254^*^
COL 55-85, 5 | Dominated | Dominated | 5972^*^
COL 50-75, 5 | Dominated | Dominated | 1838^*^
COL 50-80, 5 | Dominated | Dominated | 1489
COL 50-85, 5 | Dominated | Dominated | 3178^*^
COL 45-70, 5 | 31880^*^ | 4594^*^ | 2374^*^
COL 45-75, 5 | 3172^*^ | 3258 | 2431^*^
COL 45-80, 5 | 2817 | 3392 | 1495
COL 45-85, 5 | 4268 | 8623 | 3351

COL – colonoscopy; CRC – colorectal cancer; N/A – not applicable; the efficiency ratio cannot be calculated because there is no efficient strategy with fewer colorectal cancer deaths averted; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and averting the fewest colorectal cancer deaths).

* Near efficient (i.e., within 0.75 colorectal cancer deaths averted per 1000 of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 13.7 Efficient Sigmoidoscopy Strategies With the Estimated Number of Colorectal Cancer Deaths Averted as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ CRC deaths averted)
Strategy | SimCRC | CRC-SPIN | MISCAN
FIT 55-70, 3 | -- | -- | --
FIT 55-75, 3 | 37 | 54 | 35
FIT 50-70, 3 | Dominated | 425^*^ | Dominated
FIT 55-70, 2 | Dominated | 69^*^ | Dominated
FIT 55-80, 3 | 42 | 58 | 36
FIT 50-75, 3 | 52^*^ | 89^*^ | Dominated
FIT 55-85, 3 | 59^*^ | 75^*^ | 46
FIT 55-75, 2 | Dominated | 73^*^ | Dominated
FIT 50-80, 3 | 57 | 73 | 826^*^
FIT 50-70, 2 | Dominated | 104^*^ | Dominated
FIT 45-75, 3 | 84^*^ | 216^*^ | Dominated
FIT 50-85, 3 | 59 | 85^*^ | 123^*^
FIT 55-80, 2 | 166^*^ | 82 | 122^*^
FIT 45-80, 3 | 167^*^ | 133^*^ | Dominated
FIT 45-70, 2 | Dominated | 272^*^ | Dominated
FIT 50-75, 2 | Dominated | 159^*^ | Dominated
FIT 45-85, 3 | 75 | 99 | Dominated
FIT 55-85, 2 | 151^*^ | 102^*^ | 86
FIT 55-70, 1 | Dominated | 210^*^ | Dominated
FIT 50-80, 2 | 178^*^ | 110^*^ | 271^*^
FIT 45-75, 2 | Dominated | 116^*^ | Dominated
FIT 50-85, 2 | 123^*^ | 115^*^ | 119
FIT 45-80, 2 | 115^*^ | 103 | Dominated
FIT 55-75, 1 | Dominated | 186^*^ | Dominated
FIT 45-85, 2 | 104 | 113 | 210^*^
FIT 55-80, 1 | Dominated | Dominated | 257^*^
FIT 50-75, 1 | Dominated | 1296^*^ | Dominated
FIT 55-85, 1 | Dominated | Dominated | 171
FIT 45-70, 1 | Dominated | 934^*^ | Dominated
FIT 50-80, 1 | 531^*^ | 317^*^ | 344^*^
FIT 45-75, 1 | Dominated | 249^*^ | Dominated
FIT 50-85, 1 | 339^*^ | 282^*^ | 174
sDNA-FIT 45-80, 3 | Dominated | 369^*^ | Dominated
FIT 45-80, 1 | 241^*^ | 217^*^ | 308^*^
sDNA-FIT 45-85, 3 | Dominated | 317^*^ | Dominated
FIT 45-85, 1 | 223 | 216 | 294
sDNA-FIT 50-85, 2 | Dominated | Dominated | 466^*^
sDNA-FIT 45-75, 2 | Dominated | 335^*^ | Dominated
sDNA-FIT 45-80, 2 | 390^*^ | 305^*^ | Dominated
sDNA-FIT 45-85, 2 | 2427^*^ | 1019^*^ | 1049^*^
sDNA-FIT 50-80, 1 | Dominated | Dominated | 2068^*^
sDNA-FIT 50-85, 1 | Dominated | Dominated | 3337^*^
sDNA-FIT 45-75, 1 | Dominated | 1276^*^ | Dominated
sDNA-FIT 45-80, 1 | 1384^*^ | 851^*^ | 2699^*^
sDNA-FIT 45-85, 1 | 1066 | 783 | 1295

COL – colonoscopy; CRC – colorectal cancer; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and averting the fewest colorectal cancer deaths).

* Near efficient (i.e., within 0.75 colorectal cancer deaths averted per 1000 of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 13.8 Efficient Sigmoidoscopy Strategies With the Estimated Number of Colorectal Cancer Deaths Averted as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ CRC deaths averted)
Strategy | SimCRC | CRC-SPIN | MISCAN
SIG 55-70, 10 | -- | -- | --
SIG 55-75, 10 | 77^*^ | 103 | 89
SIG 50-70, 10 | 70 | 122 | 419^*^
SIG 45-70, 10 | 89^*^ | 301^*^ | Dominated
SIG 55-85, 10 | 93^*^ | 226^*^ | 184^*^
SIG 55-70, 5 | 313^*^ | 460^*^ | 207^*^
SIG 50-80, 10 | 110^*^ | 154^*^ | 151^*^
SIG 55-75, 5 | 146^*^ | 448^*^ | 149^*^
SIG 45-75, 10 | 106 | 125 | 245^*^
SIG 50-70, 5 | 1415^*^ | 220^*^ | 221^*^
SIG 45-85, 10 | 185^*^ | 252 | 229^*^
SIG 55-80, 5 | 151^*^ | Dominated | 148
SIG 55-85, 5 | Dominated | Dominated | 301^*^
SIG 50-75, 5 | 153^*^ | 194^*^ | 350^*^
SIG 45-70, 5 | 171^*^ | 2946^*^ | Dominated
SIG 50-80, 5 | 156^*^ | 726^*^ | 235
SIG 50-85, 5 | 170^*^ | 1530^*^ | 294
SIG 45-75, 5 | 144 | 323^*^ | 395^*^
SIG 45-80, 5 | 171 | 294 | 500^*^
SIG 45-85, 5 | 297 | 396 | 440

COL – colonoscopy; CRC – colorectal cancer; SIG – sigmoidoscopy; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and averting the fewest colorectal cancer deaths).

* Near efficient (i.e., within 0.75 colorectal cancer deaths averted per 1000 of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 13.9 Efficient 10-Yearly Sigmoidoscopy Plus Interval FIT Strategies With the Estimated Number of Colorectal Cancer Deaths Averted as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ CRC deaths averted)
Strategy | SimCRC | CRC-SPIN | MISCAN
SIG+FIT 55-70, 10_2 | -- | -- | --
SIG+FIT 55-70, 10_1 | Dominated | 189^*^ | 162^*^
SIG+FIT 55-75, 10_2 | 91 | 135 | 89^*^
SIG+FIT 50-70, 10_2 | 101^*^ | 159^*^ | Dominated
SIG+FIT 55-80, 10_2 | 112^*^ | 158^*^ | 88
SIG+FIT 50-75, 10_2 | 94 | 148 | 1234^*^
SIG+FIT 45-70, 10_2 | Dominated | 337^*^ | Dominated
SIG+FIT 55-85, 10_2 | 161^*^ | 207^*^ | 162
SIG+FIT 55-75, 10_1 | Dominated | 279^*^ | 438^*^
SIG+FIT 50-70, 10_1 | Dominated | 458^*^ | Dominated
SIG+FIT 50-80, 10_2 | 131 | 179^*^ | 195^*^
SIG+FIT 55-80, 10_1 | Dominated | 156027^*^ | 405^*^
SIG+FIT 50-85, 10_2 | 179^*^ | 186^*^ | 183
SIG+FIT 45-75, 10_2 | 170^*^ | 169^*^ | 475^*^
SIG+FIT 55-85, 10_1 | Dominated | Dominated | 258^*^
SIG+FIT 50-75, 10_1 | Dominated | 271^*^ | 634^*^
SIG+FIT 45-80, 10_2 | 147 | 168 | 342^*^
SIG+FIT 45-70, 10_1 | Dominated | 286^*^ | Dominated
SIG+FIT 50-80, 10_1 | Dominated | 262^*^ | 369^*^
SIG+FIT 45-85, 10_2 | 211 | 290 | 476^*^
SIG+FIT 50-85, 10_1 | 336^*^ | 275^*^ | 312
SIG+FIT 45-75, 10_1 | 950^*^ | 1456^*^ | 1256^*^
SIG+FIT 45-80, 10_1 | 658^*^ | 504^*^ | 3232^*^
SIG+FIT 45-85, 10_1 | 488 | 455 | 522

COL – colonoscopy; CRC – colorectal cancer; SIG – sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and averting the fewest colorectal cancer deaths).

* Near efficient (i.e., within 0.75 colorectal cancer deaths averted per 1000 of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 13.10 Efficient Computed Tomographic Colonography Strategies With the Estimated Number of Colorectal Cancer Deaths Averted as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ CRC deaths averted)
Strategy | SimCRC | CRC-SPIN | MISCAN
CTC 55-70, 10 | -- | -- | --
CTC 55-75, 10 | 74^*^ | 90 | 45
CTC 50-70, 10 | 64 | 209^*^ | Dominated
CTC 45-70, 10 | Dominated | 113^*^ | Dominated
CTC 55-70, 5 | Dominated | 240^*^ | 587^*^
CTC 55-85, 10 | Dominated | 188^*^ | 77
CTC 50-80, 10 | 107^*^ | 127^*^ | 78^*^
CTC 55-75, 5 | Dominated | 161^*^ | 83^*^
CTC 45-75, 10 | 105 | 114 | Dominated
CTC 50-70, 5 | 151^*^ | 156^*^ | Dominated
CTC 55-80, 5 | Dominated | 167^*^ | 78
CTC 45-85, 10 | 186^*^ | 182 | Dominated
CTC 55-85, 5 | Dominated | 178^*^ | 116
CTC 50-75, 5 | 207^*^ | 549^*^ | Dominated
CTC 45-70, 5 | 276^*^ | 483^*^ | Dominated
CTC 50-80, 5 | 193^*^ | 266^*^ | 212^*^
CTC 50-85, 5 | 207^*^ | 267^*^ | 171
CTC 45-75, 5 | 169^*^ | 210^*^ | Dominated
CTC 45-80, 5 | 169 | 202 | 1355^*^
CTC 45-85, 5 | 324 | 281 | 325

COL – colonoscopy; CRC – colorectal cancer; CTC – computed tomographic colonography; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and averting the fewest colorectal cancer deaths).

* Near efficient (i.e., within 0.75 colorectal cancer deaths averted per 1000 of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.