# Appendix 12 Efficiency Ratios With Estimated QALYG vs. Estimated LYG as the Measure of the Benefit of Screening

Appendix Table 12.1 Efficient Colonoscopy Screening Strategies, by Model and Benefit Variable (LYG, QALYG

Strategy | Efficiency ratio, by model and benefit variable
Strategy | SimCRC | | CRC-SPIN | | MISCAN
Strategy | Δ COL / Δ LYG | Δ COL / Δ QALYG | Δ COL / Δ LYG | Δ COL / Δ QALYG | Δ COL / Δ LYG | Δ COL / Δ QALYG
COL 55-70, 15 | -- | -- | -- | -- | -- | --
COL 55-70, 10 | Dominated | Dominated | 17^*^ | 18^*^ | 22^*^ | 19^*^
COL 50-70, 15 | 6^*^ | 6^*^ | 8^*^ | 8^*^ | 18 | 17
COL 45-70, 15 | 6 | 6 | 7 | 8 | 85^*^ | 46^*^
COL 50-80, 15 | Dominated | Dominated | Dominated | Dominated | 56^*^ | 71^*^
COL 50-70, 10 | Dominated | Dominated | Dominated | Dominated | 28 | 30
COL 45-75, 15 | 39^*^ | 44^*^ | 59^*^ | 66^*^ | 38^*^ | 41^*^
COL 45-70, 10 | 34 | 36 | 44 | 48 | 45 | 38
COL 50-80, 10 | Dominated | Dominated | Dominated | Dominated | 86^*^ | 107^*^
COL 45-75, 10 | 64 | 72 | 112 | 127 | 52 | 61
COL 45-85, 10 | 394^*^ | 627^*^ | 828^*^ | 1470^*^ | 227^*^ | 352^*^
COL 50-70, 5 | Dominated | Dominated | Dominated | Dominated | 120^*^ | 151^*^
COL 50-75, 5 | Dominated | Dominated | Dominated | Dominated | 367^*^ | Dominated
COL 45-70, 5 | 180^*^ | 184 | 179 | 198 | 84 | 86
COL 45-75, 5 | 178 | 198 | 344 | 447 | 116 | 137
COL 45-80, 5 | 428 | 585 | 736 | 1388 | 169 | 211
COL 45-85, 5 | 1445 | 7114 | 2190 | Dominated | 926 | 2285

COL – colonoscopy; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest LYG/QALYG).

* Near efficient (i.e., within 3 (quality-adjusted) days of life gained per person of the efficient frontier).

Note: Strategies that were dominated with both measures across all 3 models are not shown. Conclusions about efficiency and efficiency ratios were similar across the two measures of the benefit of screening. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 12.2 Efficient FIT and sDNA-FIT Strategies, by Model and Benefit Variable (LYG, QALYG)

Strategy | Efficiency ratio, by model and benefit variable
Strategy | SimCRC | | CRC-SPIN | | MISCAN
Strategy | Δ COL / Δ LYG | Δ COL / Δ QALYG | Δ COL / Δ LYG | Δ COL / Δ QALYG | Δ COL / Δ LYG | Δ COL / Δ QALYG
FIT 55-70, 3 | -- | -- | -- | -- | -- | --
FIT 55-75, 3 | Dominated | Dominated | Dominated | Dominated | 5 | 6^*^
FIT 50-70, 3 | 2 | 2 | 4 | 4 | 6^*^ | 6^*^
FIT 55-70, 2 | Dominated | Dominated | Dominated | Dominated | 13^*^ | 7^*^
FIT 55-80, 3 | Dominated | Dominated | Dominated | Dominated | 6^*^ | 7^*^
FIT 45-70, 3 | 3 | 4 | 5 | 5 | 6^*^ | 6^*^
FIT 50-75, 3 | Dominated | Dominated | Dominated | Dominated | 5 | 5
FIT 55-85, 3 | Dominated | Dominated | Dominated | Dominated | 7^*^ | Dominated
FIT 55-75, 2 | Dominated | Dominated | Dominated | Dominated | 14^*^ | 14^*^
FIT 50-80, 3 | Dominated | Dominated | Dominated | Dominated | 6 | 8^*^
FIT 50-70, 2 | Dominated | Dominated | Dominated | Dominated | 94^*^ | 8^*^
FIT 45-75, 3 | 5 | 6 | 7^*^ | 8^*^ | 7^*^ | 7
FIT 50-85, 3 | Dominated | Dominated | Dominated | Dominated | 10^*^ | 9^*^
FIT 55-80, 2 | Dominated | Dominated | Dominated | Dominated | Dominated | 11^*^
FIT 45-80, 3 | 7^*^ | 9^*^ | 8^*^ | 9^*^ | 6 | 8
FIT 45-70, 2 | 8^*^ | 7 | 7 | 7 | Dominated | 16^*^
FIT 50-75, 2 | Dominated | Dominated | Dominated | Dominated | 10^*^ | 8
FIT 45-85, 3 | 10^*^ | 13^*^ | Dominated | Dominated | 9^*^ | 13^*^
FIT 50-80, 2 | Dominated | Dominated | Dominated | Dominated | 8 | 9^*^
FIT 45-75, 2 | 7 | 8 | 9 | 11 | 9^*^ | 8
FIT 50-85, 2 | Dominated | Dominated | Dominated | Dominated | 12^*^ | 10^*^
FIT 45-80, 2 | 10 | 13 | 12 | 15^*^ | 8 | 9
FIT 45-85, 2 | 19^*^ | 26^*^ | 25^*^ | 20^*^ | 12 | 16^*^
FIT 50-75, 1 | Dominated | Dominated | Dominated | Dominated | 29^*^ | 17^*^
FIT 45-70, 1 | 21^*^ | 15^*^ | 14 | 13 | Dominated | 18^*^
FIT 50-80, 1 | Dominated | Dominated | Dominated | Dominated | 18^*^ | 15^*^
FIT 45-75, 1 | 16 | 14 | 16 | 19 | 15^*^ | 13^*^
FIT 50-85, 1 | Dominated | Dominated | Dominated | Dominated | 18^*^ | 16^*^
sDNA-FIT 45-70, 2 | Dominated | Dominated | 52^*^ | 55^*^ | Dominated | Dominated
FIT 45-80, 1 | 19 | 22 | 27 | 32 | 14 | 13
FIT 45-85, 1 | 39 | 53 | 43 | 55^*^ | 19 | 25
sDNA-FIT 45-75, 2 | 91^*^ | 78^*^ | 135^*^ | 112^*^ | Dominated | Dominated
sDNA-FIT 45-80, 2 | 176^*^ | 203^*^ | 75^*^ | 68^*^ | 26^*^ | 23^*^
sDNA-FIT 45-85, 2 | 175^*^ | 123^*^ | 69^*^ | 71^*^ | 375^*^ | 237^*^
sDNA-FIT 45-70, 1 | 116^*^ | 291^*^ | 62^*^ | 57^*^ | Dominated | Dominated
sDNA-FIT 45-75, 1 | 103^*^ | 72^*^ | 53 | 53 | 251^*^ | 110^*^
sDNA-FIT 45-80, 1 | 81 | 67 | 62 | 79 | 104^*^ | 78^*^
sDNA-FIT 45-85, 1 | 95 | 140 | 111 | 190 | 94 | 76

COL – colonoscopy; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest LYG/QALYG).

* Near efficient (i.e., within 3 (quality-adjusted) days of life gained per person of the efficient frontier).

Note: Strategies that were dominated with both measures across all 3 models are not shown. Conclusions about efficiency and efficiency ratios were similar across the two measures of the benefit of screening. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 12.3 Efficient Sigmoidoscopy Strategies, by Model and Benefit Variable (LYG, QALYG)

Strategy | Efficiency ratio, by model and benefit variable
Strategy | SimCRC | | CRC-SPIN | | MISCAN
Strategy | Δ COL / Δ LYG | Δ COL / Δ QALYG | Δ COL / Δ LYG | Δ COL / Δ QALYG | Δ COL / Δ LYG | Δ COL / Δ QALYG
SIG 55-70, 10 | -- | -- | -- | -- | -- | --
SIG 50-70, 10 | Dominated | Dominated | Dominated | Dominated | 8 | 9
SIG 45-70, 10 | 4 | 4 | 5 | 6 | 73^*^ | 24^*^
SIG 55-70, 5 | Dominated | Dominated | Dominated | Dominated | 11^*^ | 13^*^
SIG 50-80, 10 | Dominated | Dominated | Dominated | Dominated | 22^*^ | 28^*^
SIG 45-75, 10 | 13^*^ | 15^*^ | 18 | 20 | 18^*^ | 18^*^
SIG 50-70, 5 | Dominated | Dominated | Dominated | Dominated | 14 | 15
SIG 45-85, 10 | Dominated | Dominated | 68^*^ | 91^*^ | 21^*^ | 22^*^
SIG 50-75, 5 | Dominated | Dominated | Dominated | Dominated | 19^*^ | 23^*^
SIG 45-70, 5 | 11 | 12 | 20 | 21 | 15 | 15
SIG 50-80, 5 | Dominated | Dominated | Dominated | Dominated | 23^*^ | 28^*^
SIG 50-85, 5 | Dominated | Dominated | Dominated | Dominated | 26^*^ | 32^*^
SIG 45-75, 5 | 20 | 23 | 27 | 31 | 19 | 23
SIG 45-80, 5 | 38 | 46 | 49 | 60 | 29 | 38
SIG 45-85, 5 | 89 | 141 | 98 | 141 | 78 | 134

COL – colonoscopy; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; SIG – sigmoidoscopy; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest LYG/QALYG).

* Near efficient (i.e., within 3 (quality-adjusted) days of life gained per person of the efficient frontier).

Note: Strategies that were dominated with both measures across all 3 models are not shown. Conclusions about efficiency and efficiency ratios were similar across the two measures of the benefit of screening. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 12.4 Efficient 10-Yearly Sigmoidoscopy Plus Interval FIT Strategies, by Model and Benefit Variable (LYG, QALYG)

Strategy | Efficiency ratio, by model and benefit variable
Strategy | SimCRC | | CRC-SPIN | | MISCAN
Strategy | Δ COL / Δ LYG | Δ COL / Δ QALYG | Δ COL / Δ LYG | Δ COL / Δ QALYG | Δ COL / Δ LYG | Δ COL / Δ QALYG
SIG+FIT 55-70, 10_2 | -- | -- | -- | -- | -- | --
SIG+FIT 55-70, 10_1 | Dominated | Dominated | Dominated | Dominated | 14^*^ | 15^*^
SIG+FIT 55-75, 10_2 | Dominated | Dominated | Dominated | Dominated | 13^*^ | 16^*^
SIG+FIT 50-70, 10_2 | 6^*^ | 6^*^ | 8^*^ | 8^*^ | 9 | 10
SIG+FIT 55-80, 10_2 | Dominated | Dominated | Dominated | Dominated | 13^*^ | Dominated
SIG+FIT 50-75, 10_2 | Dominated | Dominated | Dominated | Dominated | 9 | 12
SIG+FIT 45-70, 10_2 | 5 | 5 | 7 | 7 | 24^*^ | 16^*^
SIG+FIT 50-70, 10_1 | Dominated | Dominated | Dominated | Dominated | 24^*^ | 22^*^
SIG+FIT 50-80, 10_2 | Dominated | Dominated | Dominated | Dominated | 20^*^ | 25^*^
SIG+FIT 50-85, 10_2 | Dominated | Dominated | Dominated | Dominated | 21^*^ | 26^*^
SIG+FIT 45-75, 10_2 | 15 | 17 | 22 | 24 | 15^*^ | 16
SIG+FIT 50-75, 10_1 | Dominated | Dominated | Dominated | Dominated | 18^*^ | 19^*^
SIG+FIT 45-80, 10_2 | 22 | 27 | 25 | 31 | 15 | 17
SIG+FIT 45-70, 10_1 | 22^*^ | 23^*^ | 88^*^ | 49^*^ | 19^*^ | 18^*^
SIG+FIT 50-80, 10_1 | Dominated | Dominated | Dominated | Dominated | 20^*^ | 22^*^
SIG+FIT 45-85, 10_2 | 54^*^ | 75^*^ | 78^*^ | 106^*^ | 38^*^ | 54^*^
SIG+FIT 50-85, 10_1 | Dominated | Dominated | Dominated | Dominated | 21^*^ | 24^*^
SIG+FIT 45-75, 10_1 | 34 | 31 | 34 | 35 | 22^*^ | 22
SIG+FIT 45-80, 10_1 | 35 | 42 | 53 | 69 | 21 | 24
SIG+FIT 45-85, 10_1 | 81 | 116 | 64 | 89 | 46 | 65

COL – colonoscopy; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; SIG – sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest LYG/QALYG).

* Near efficient (i.e., within 3 (quality-adjusted) days of life gained per person of the efficient frontier).

Note: Strategies that were dominated with both measures across all 3 models are not shown. Conclusions about efficiency and efficiency ratios were similar across the two measures of the benefit of screening. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 12.5 Efficient 10-Yearly Computed Tomographic Colonography Strategies, by Model and Benefit Variable (LYG, QALYG)

Strategy | Efficiency ratio, by model and benefit variable
Strategy | SimCRC | | CRC-SPIN | | MISCAN
Strategy | Δ COL / Δ LYG | Δ COL / Δ QALYG | Δ COL / Δ LYG | Δ COL / Δ QALYG | Δ COL / Δ LYG | Δ COL / Δ QALYG
CTC 55-70, 10 | -- | -- | -- | -- | -- | --
CTC 55-75, 10 | Dominated | Dominated | Dominated | Dominated | Dominated | 8^*^
CTC 50-70, 10 | Dominated | Dominated | Dominated | Dominated | 5 | 6
CTC 45-70, 10 | 4 | 4 | 5 | 5 | Dominated | Dominated
CTC 55-70, 5 | Dominated | Dominated | Dominated | Dominated | 8^*^ | 8^*^
CTC 50-80, 10 | Dominated | Dominated | Dominated | Dominated | 10^*^ | 12^*^
CTC 55-75, 5 | Dominated | Dominated | Dominated | Dominated | 9^*^ | 9^*^
CTC 45-75, 10 | 13^*^ | 15^*^ | 15^*^ | 16^*^ | Dominated | Dominated
CTC 50-70, 5 | Dominated | Dominated | Dominated | Dominated | 8 | 8
CTC 55-80, 5 | Dominated | Dominated | Dominated | Dominated | 10^*^ | Dominated
CTC 45-85, 10 | Dominated | Dominated | 19^*^ | 21^*^ | Dominated | Dominated
CTC 50-75, 5 | Dominated | Dominated | Dominated | Dominated | 9 | 10
CTC 45-70, 5 | 11 | 12 | 13 | 14 | 21^*^ | 14^*^
CTC 50-80, 5 | Dominated | Dominated | Dominated | Dominated | 13^*^ | 16^*^
CTC 50-85, 5 | Dominated | Dominated | Dominated | Dominated | 17^*^ | 21^*^
CTC 45-75, 5 | 19 | 22 | 21 | 24 | 11 | 11
CTC 45-80, 5 | 38 | 46 | 37 | 45 | 13 | 16
CTC 45-85, 5 | 104 | 165 | 73 | 103 | 32 | 43

COL – colonoscopy; LYG – life-years gained compared with no screening; QALYG – quality-adjusted life-years gained compared with no screening; CTC – computed tomographic colonography; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest LYG/QALYG).

* Near efficient (i.e., within 3 (quality-adjusted) days of life gained per person of the efficient frontier).

Note: Strategies that were dominated with both measures across all 3 models are not shown. Conclusions about efficiency and efficiency ratios were similar across the two measures of the benefit of screening. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.1a Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for Colonoscopy Screening Strategies: SimCRC

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for colonoscopy screening strategies (SimCRC).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.1b Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for Colonoscopy Screening Strategies: CRC-SPIN

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for colonoscopy screening strategies (CRC-SPIN).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.1c Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for Colonoscopy Screening Strategies: MISCAN

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for colonoscopy screening strategies (MISCAN).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.2a Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for FIT and sDNA-FIT Screening Strategies: SimCRC

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for FIT and sDNA-FIT screening strategies (SimCRC).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.2b Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for FIT and sDNA-FIT Screening Strategies: CRC-SPIN

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for FIT and sDNA-FIT screening strategies (CRC-SPIN).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.2c Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for FIT and sDNA-FIT Screening Strategies: MISCAN

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for FIT and sDNA-FIT screening strategies (MISCAN).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.3a Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for Sigmoidoscopy Screening Strategies: SimCRC

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for sigmoidoscopy screening strategies (SimCRC).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.3b Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for Sigmoidoscopy Screening Strategies: CRC-SPIN

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for sigmoidoscopy screening strategies (CRC-SPIN).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.3c Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for Sigmoidoscopy Screening Strategies: MISCAN

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for sigmoidoscopy screening strategies (MISCAN).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.4a Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies: SimCRC

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for 10-yearly sigmoidoscopy plus interval FIT screening strategies (SimCRC).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.4b Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies: CRC-SPIN

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for 10-yearly sigmoidoscopy plus interval FIT screening strategies (CRC-SPIN).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.4c Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies: MISCAN

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for 10-yearly sigmoidoscopy plus interval FIT screening strategies (MISCAN).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.5a Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for Computed Tomographic Colonography Screening Strategies: SimCRC

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for computed tomographic colonography screening strategies (SimCRC).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.5b Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for Computed Tomographic Colonography Screening Strategies: CRC-SPIN

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for computed tomographic colonography screening strategies (CRC-SPIN).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 12.5c Estimated Colonoscopies vs. Life-Years Gained and vs. Quality-Adjusted Life-Years Gained for a Cohort of 40-Year-Olds for Computed Tomographic Colonography Screening Strategies: MISCAN

Estimated colonoscopies vs life-years gained and vs quality-adjusted life-years gained for computed tomographic colonography screening strategies (MISCAN).

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.