# Appendix 11 Efficiency Ratios by Race and Sex

Appendix Table 11.1a Efficient Colonoscopy Screening Strategies for the Total Population and by Race and Sex: SimCRC

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | Total population | White males | Black males | White females | Black females
COL 55-70, 15 | -- | -- | -- | -- | --
COL 50-70, 15 | 6^*^ | 7 | 8 | 5^*^ | 6^*^
COL 45-70, 15 | 6 | 7 | 8 | 5 | 5
COL 45-75, 15 | 39^*^ | 35^*^ | 33^*^ | 45^*^ | 40^*^
COL 45-70, 10 | 34 | 33 | 32 | 38 | 35
COL 45-75, 10 | 64 | 56 | 52 | 76 | 66
COL 45-85, 10 | 394^*^ | 336^*^ | 257^*^ | 453^*^ | 360^*^
COL 45-70, 5 | 180^*^ | 166^*^ | 156^*^ | 206 | 185^*^
COL 45-75, 5 | 178 | 161 | 151 | 208 | 183
COL 45-80, 5 | 428 | 363 | 294 | 541 | 425
COL 45-85, 5 | 1445 | 1239 | 880 | 1735 | 1323

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all groups are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 11.1b Efficient Colonoscopy Screening Strategies for the Total Population and by Race and Sex: CRC-SPIN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | Total population | White males | Black males | White females | Black females
COL 55-70, 15 | -- | -- | -- | -- | --
COL 55-70, 10 | 17^*^ | 19^*^ | 24^*^ | 15^*^ | 15^*^
COL 50-70, 15 | 8^*^ | 8^*^ | 9^*^ | 7^*^ | 8^*^
COL 45-70, 15 | 7 | 8 | 9 | 7 | 8
COL 45-75, 15 | 59^*^ | 70^*^ | 72^*^ | 55^*^ | 50^*^
COL 45-70, 10 | 44 | 49 | 49 | 42 | 41
COL 45-75, 10 | 112 | 143 | 142 | 100 | 93
COL 45-85, 10 | 828^*^ | 870^*^ | 395^*^ | 574^*^ | 416^*^
COL 45-70, 5 | 179 | 187 | 203 | 160 | 154
COL 45-75, 5 | 344 | 450 | 414 | 322 | 299
COL 45-80, 5 | 736 | 1030 | 843 | 680 | 605
COL 45-85, 5 | 2190 | 8876 | 4827 | 3557 | 1813

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all groups are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 11.1c Efficient Colonoscopy Screening Strategies for the Total Population and by Race and Sex: MISCAN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | Total population | White males | Black males | White females | Black females
COL 55-70, 15 | -- | -- | -- | -- | --
COL 55-70, 10 | 22^*^ | 19^*^ | 24^*^ | 21^*^ | 24^*^
COL 50-70, 15 | 18 | 17 | 18 | 17 | 18
COL 55-85, 15 | Dominated | Dominated | 117^*^ | Dominated | Dominated
COL 45-70, 15 | 85^*^ | 52^*^ | 45^*^ | 26^*^ | 280^*^
COL 50-80, 15 | 56^*^ | 55^*^ | 49^*^ | 64^*^ | 55^*^
COL 50-70, 10 | 28 | 26 | 26 | 31 | 30
COL 45-75, 15 | 38^*^ | 36^*^ | 34^*^ | 44^*^ | 40^*^
COL 45-70, 10 | 45 | 37 | 39 | 55 | 50
COL 50-80, 10 | 86^*^ | 84^*^ | 75^*^ | 100^*^ | 86^*^
COL 45-75, 10 | 52 | 48 | 46 | 57 | 51
COL 45-85, 10 | 227^*^ | 228^*^ | 187^*^ | 270^*^ | 219^*^
COL 50-70, 5 | 120^*^ | 125^*^ | 145^*^ | 122^*^ | 118^*^
COL 50-75, 5 | 367^*^ | 633^*^ | 1825^*^ | 322^*^ | 334^*^
COL 45-70, 5 | 84 | 74 | 74 | 95 | 92
COL 45-75, 5 | 116 | 110 | 103 | 129 | 115
COL 45-80, 5 | 169 | 163 | 145 | 210 | 175
COL 45-85, 5 | 926 | 934 | 724 | 1100 | 863

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all groups are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 11.2a Efficient FIT Screening Strategies for the Total Population and by Race and Sex: SimCRC

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | Total population | White males | Black males | White females | Black females
FIT 55-70, 3 | -- | -- | -- | -- | --
FIT 50-70, 3 | 2 | 3 | 3 | 2 | 2
FIT 45-70, 3 | 3 | 4 | 4 | 3 | 3
FIT 45-75, 3 | 5 | 6 | 6 | 5 | 5
FIT 45-80, 3 | 7^*^ | 8^*^ | 7^*^ | 7 | 7^*^
FIT 45-70, 2 | 8^*^ | 8^*^ | 7^*^ | 18^*^ | 7^*^
FIT 45-85, 3 | 10^*^ | 10^*^ | 9^*^ | 13^*^ | 9^*^
FIT 45-75, 2 | 7 | 7 | 7 | 8 | 7
FIT 45-80, 2 | 10 | 10 | 10 | 11 | 10
FIT 45-85, 2 | 19^*^ | 19^*^ | 17^*^ | 20^*^ | 17^*^
FIT 45-70, 1 | 21^*^ | 23^*^ | 17^*^ | 25^*^ | 17^*^
FIT 45-75, 1 | 16 | 17 | 14 | 17 | 14
FIT 45-80, 1 | 19 | 18 | 17 | 20 | 18
FIT 45-85, 1 | 39 | 40 | 33 | 41 | 35

FIT – fecal immunochemical test fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all groups are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 11.2b Efficient FIT Screening Strategies for the Total Population and by Race and Sex: CRC-SPIN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | Total population | White males | Black males | White females | Black females
FIT 55-70, 3 | -- | -- | -- | -- | --
FIT 55-75, 3 | Dominated | Dominated | 8^*^ | Dominated | 6^*^
FIT 50-70, 3 | 4 | 4 | 4 | 4 | 4
FIT 55-70, 2 | Dominated | Dominated | Dominated | 28^*^ | 18^*^
FIT 50-75, 3 | Dominated | Dominated | Dominated | 6^*^ | 6^*^
FIT 45-70, 3 | 5 | 5 | 5 | 4 | 4
FIT 50-70, 2 | Dominated | Dominated | Dominated | 12^*^ | 12^*^
FIT 45-75, 3 | 7^*^ | 9^*^ | 9^*^ | 7^*^ | 6^*^
FIT 45-80, 3 | 8^*^ | 10^*^ | 10^*^ | 7^*^ | 7^*^
FIT 45-70, 2 | 7 | 7 | 7 | 6 | 6
FIT 45-75, 2 | 9 | 11 | 11 | 8 | 8
FIT 45-80, 2 | 12 | 19^*^ | 16^*^ | 13 | 14^*^
FIT 45-85, 2 | 25^*^ | 22^*^ | 19^*^ | 21^*^ | 15^*^
FIT 45-70, 1 | 14 | 14 | 13 | 14 | 12
FIT 45-75, 1 | 16 | 20 | 22 | 15 | 15
FIT 45-80, 1 | 27 | 32 | 28 | 23 | 21
FIT 45-85, 1 | 43 | 63 | 52 | 42 | 33

FIT – fecal immunochemical test fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all groups are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 11.2c Efficient FIT Screening Strategies for the Total Population and by Race and Sex: MISCAN

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | Total population | White males | Black males | White females | Black females
FIT 55-70, 3 | -- | -- | -- | -- | --
FIT 55-75, 3 | 5 | 5 | 5 | 5 | 4
FIT 50-70, 3 | 6^*^ | 10^*^ | 7^*^ | 6^*^ | 6^*^
FIT 55-70, 2 | 13^*^ | Dominated | 11^*^ | 15^*^ | 12^*^
FIT 55-80, 3 | 6^*^ | 6^*^ | 6^*^ | 6^*^ | 5^*^
FIT 50-75, 3 | 5 | 5 | 5 | 5 | 5
FIT 45-70, 3 | 6^*^ | 6^*^ | 6^*^ | 7^*^ | 7^*^
FIT 55-85, 3 | 7^*^ | Dominated | 7^*^ | 7^*^ | 6^*^
FIT 50-80, 3 | 6 | 6^*^ | 6 | 6 | 5
FIT 55-75, 2 | 14^*^ | Dominated | 22^*^ | 14^*^ | 11^*^
FIT 45-75, 3 | 7^*^ | 6 | 6^*^ | 9^*^ | 10^*^
FIT 50-85, 3 | 10^*^ | 7^*^ | 10^*^ | 10^*^ | 9^*^
FIT 50-70, 2 | 94^*^ | 9^*^ | 13^*^ | 10^*^ | 9^*^
FIT 55-80, 2 | Dominated | Dominated | 310^*^ | 28^*^ | 22^*^
FIT 45-80, 3 | 6 | 6 | 6 | 7 | 7
FIT 50-75, 2 | 10^*^ | 12^*^ | 10^*^ | 11^*^ | 9^*^
FIT 45-85, 3 | 9^*^ | 10^*^ | 9^*^ | 9^*^ | 8^*^
FIT 45-70, 2 | Dominated | 30^*^ | 18^*^ | Dominated | Dominated
FIT 50-80, 2 | 8 | 9^*^ | 8^*^ | 8^*^ | 7
FIT 50-85, 2 | 12^*^ | 9^*^ | 8^*^ | 9^*^ | 11^*^
FIT 45-75, 2 | 9^*^ | 8^*^ | 8^*^ | 8^*^ | 10^*^
FIT 45-80, 2 | 8 | 8 | 8 | 8 | 8
FIT 45-85, 2 | 12 | 13 | 11 | 12 | 11
FIT 50-75, 1 | 29^*^ | 33^*^ | 24^*^ | 36^*^ | 25^*^
FIT 45-70, 1 | Dominated | Dominated | 21^*^ | Dominated | Dominated
FIT 50-80, 1 | 18^*^ | 20^*^ | 17^*^ | 19^*^ | 16^*^
FIT 50-85, 1 | 18^*^ | 20^*^ | 17^*^ | 19^*^ | 16^*^
FIT 45-75, 1 | 15^*^ | 14^*^ | 13^*^ | 16^*^ | 14^*^
FIT 45-80, 1 | 14 | 14 | 13 | 15 | 13
FIT 45-85, 1 | 19 | 20 | 17 | 20 | 17

FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all groups are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 11.1a Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds by Race and Sex for Colonoscopy Screening Strategies: SimCRC

Estimated colonoscopies and life-years gained by race and sex for colonoscopy screening strategies (SimCRC)

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 11.1b Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds by Race and Sex for Colonoscopy Screening Strategies: CRC-SPIN

Estimated colonoscopies and life-years gained by race and sex for colonoscopy screening strategies (CRC-SPIN)

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 11.1c Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds by Race and Sex for Colonoscopy Screening Strategies: MISCAN

Estimated colonoscopies and life-years gained by race and sex for colonoscopy screening strategies (MISCAN)

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 11.2a Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds by Race and Sex for FIT Screening Strategies: SimCRC

Estimated colonoscopies and life-years gained by race and sex for FIT screening strategies (SimCRC)

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 11.2b Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds by Race and Sex for FIT Screening Strategies: CRC-SPIN

Estimated colonoscopies and life-years gained by race and sex for FIT screening strategies (CRC-SPIN)

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Figure 11.2c Estimated Colonoscopies and Life-Years Gained for a Cohort of 40-Year-Olds by Race and Sex for FIT Screening Strategies: MISCAN

Estimated colonoscopies and life-years gained by race and sex for FIT screening strategies (MISCAN)

Note: Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.