# Appendix 10 Efficiency Ratios by Class of Screening Modality

Appendix Table 10.1 Efficient Colonoscopy Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by Model

The tables that follow show the efficiency ratios that correspond with the efficient frontiers in Figures 12–16.

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
COL 55-70, 15 | -- | -- | --
COL 55-70, 10 | Dominated | 17^*^ | 22^*^
COL 50-70, 15 | 6^*^ | 8^*^ | 18
COL 45-70, 15 | 6 | 7 | 85^*^
COL 50-80, 15 | Dominated | Dominated | 56^*^
COL 50-70, 10 | Dominated | Dominated | 28
COL 45-75, 15 | 39^*^ | 59^*^ | 38^*^
COL 45-70, 10 | 34 | 44 | 45
COL 50-80, 10 | Dominated | Dominated | 86^*^
COL 45-75, 10 | 64 | 112 | 52
COL 45-85, 10 | 394^*^ | 828^*^ | 227^*^
COL 50-70, 5 | Dominated | Dominated | 120^*^
COL 50-75, 5 | Dominated | Dominated | 367^*^
COL 45-70, 5 | 180^*^ | 179 | 84
COL 45-75, 5 | 178 | 344 | 116
COL 45-80, 5 | 428 | 736 | 169
COL 45-85, 5 | 1445 | 2190 | 926

COL – colonoscopy; LYG – life-years gained compared with no screening; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 10.2 Efficient FIT and sDNA-FIT Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
FIT 55-70, 3 | -- | -- | --
FIT 55-75, 3 | Dominated | Dominated | 5
FIT 50-70, 3 | 2 | 4 | 6^*^
FIT 55-70, 2 | Dominated | Dominated | 13^*^
FIT 55-80, 3 | Dominated | Dominated | 6^*^
FIT 45-70, 3 | 3 | 5 | 6^*^
FIT 50-75, 3 | Dominated | Dominated | 5
FIT 55-85, 3 | Dominated | Dominated | 7^*^
FIT 55-75, 2 | Dominated | Dominated | 14^*^
FIT 50-80, 3 | Dominated | Dominated | 6
FIT 50-70, 2 | Dominated | Dominated | 94^*^
FIT 45-75, 3 | 5 | 7^*^ | 7^*^
FIT 50-85, 3 | Dominated | Dominated | 10^*^
FIT 45-80, 3 | 7^*^ | 8^*^ | 6
FIT 45-70, 2 | 8^*^ | 7 | Dominated
FIT 50-75, 2 | Dominated | Dominated | 10^*^
FIT 45-85, 3 | 10^*^ | Dominated | 9^*^
FIT 50-80, 2 | Dominated | Dominated | 8
FIT 45-75, 2 | 7 | 9 | 9^*^
FIT 50-85, 2 | Dominated | Dominated | 12^*^
FIT 45-80, 2 | 10 | 12 | 8
FIT 45-85, 2 | 19^*^ | 25^*^ | 12
FIT 50-75, 1 | Dominated | Dominated | 29^*^
FIT 45-70, 1 | 21^*^ | 14 | Dominated
FIT 50-80, 1 | Dominated | Dominated | 18^*^
FIT 45-75, 1 | 16 | 16 | 15^*^
FIT 50-85, 1 | Dominated | Dominated | 18^*^
sDNA-FIT 45-70, 2 | Dominated | 52^*^ | Dominated
FIT 45-80, 1 | 19 | 27 | 14
FIT 45-85, 1 | 39 | 43 | 19
sDNA-FIT 45-75, 2 | 91^*^ | 135^*^ | Dominated
sDNA-FIT 45-80, 2 | 176^*^ | 75^*^ | 26^*^
sDNA-FIT 45-85, 2 | 175^*^ | 69^*^ | 375^*^
sDNA-FIT 45-70, 1 | 116^*^ | 62^*^ | Dominated
sDNA-FIT 45-75, 1 | 103^*^ | 53 | 251^*^
sDNA-FIT 45-80, 1 | 81 | 62 | 104^*^
sDNA-FIT 45-85, 1 | 95 | 111 | 94

COL – colonoscopy; LYG – life-years gained compared with no screening; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; sDNA-FIT – multitarget stool DNA test (stool DNA test with a fecal immunochemical test); -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 10.3 Efficient Sigmoidoscopy Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
SIG 55-70, 10 | -- | -- | --
SIG 50-70, 10 | Dominated | Dominated | 8
SIG 45-70, 10 | 4 | 5 | 73^*^
SIG 55-70, 5 | Dominated | Dominated | 11^*^
SIG 50-80, 10 | Dominated | Dominated | 22^*^
SIG 45-75, 10 | 13^*^ | 18 | 18^*^
SIG 50-70, 5 | Dominated | Dominated | 14
SIG 45-85, 10 | Dominated | 68^*^ | 21^*^
SIG 50-75, 5 | Dominated | Dominated | 19^*^
SIG 45-70, 5 | 11 | 20 | 15
SIG 50-80, 5 | Dominated | Dominated | 23^*^
SIG 50-85, 5 | Dominated | Dominated | 26^*^
SIG 45-75, 5 | 20 | 27 | 19
SIG 45-80, 5 | 38 | 49 | 29
SIG 45-85, 5 | 89 | 98 | 78

COL – colonoscopy; LYG – life-years gained compared with no screening; SIG – sigmoidoscopy; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 10.4 Efficient 10-Yearly Sigmoidoscopy Plus Interval FIT Screening Strategies With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
SIG+FIT 55-70, 10_2 | -- | -- | --
SIG+FIT 55-70, 10_1 | Dominated | Dominated | 14^*^
SIG+FIT 55-75, 10_2 | Dominated | Dominated | 13^*^
SIG+FIT 50-70, 10_2 | 6^*^ | 8^*^ | 9
SIG+FIT 55-80, 10_2 | Dominated | Dominated | 13^*^
SIG+FIT 50-75, 10_2 | Dominated | Dominated | 9
SIG+FIT 45-70, 10_2 | 5 | 7 | 24^*^
SIG+FIT 50-70, 10_1 | Dominated | Dominated | 24^*^
SIG+FIT 50-80, 10_2 | Dominated | Dominated | 20^*^
SIG+FIT 50-85, 10_2 | Dominated | Dominated | 21^*^
SIG+FIT 45-75, 10_2 | 15 | 22 | 15^*^
SIG+FIT 50-75, 10_1 | Dominated | Dominated | 18^*^
SIG+FIT 45-80, 10_2 | 22 | 25 | 15
SIG+FIT 45-70, 10_1 | 22^*^ | 88^*^ | 19^*^
SIG+FIT 50-80, 10_1 | Dominated | Dominated | 20^*^
SIG+FIT 45-85, 10_2 | 54^*^ | 78^*^ | 38^*^
SIG+FIT 50-85, 10_1 | Dominated | Dominated | 21^*^
SIG+FIT 45-75, 10_1 | 34 | 34 | 22^*^
SIG+FIT 45-80, 10_1 | 35 | 53 | 21
SIG+FIT 45-85, 10_1 | 81 | 64 | 46

COL – colonoscopy; LYG – life-years gained compared with no screening; SIG – sigmoidoscopy; FIT – fecal immunochemical test with a cutoff for positivity of 20 μg of hemoglobin per g of feces; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.

Appendix Table 10.5 Efficient Computed Tomographic Colonography Screening Strategies, With Estimated Life-Years Gained as the Measure of the Benefit of Screening, by Model

Strategy | Efficiency ratio (Δ COL / Δ LYG)
Strategy | SimCRC | CRC-SPIN | MISCAN
CTC 55-70, 10 | -- | -- | --
CTC 50-70, 10 | Dominated | Dominated | 5
CTC 45-70, 10 | 4 | 5 | Dominated
CTC 55-70, 5 | Dominated | Dominated | 8^*^
CTC 50-80, 10 | Dominated | Dominated | 10^*^
CTC 55-75, 5 | Dominated | Dominated | 9^*^
CTC 45-75, 10 | 13^*^ | 15^*^ | Dominated
CTC 50-70, 5 | Dominated | Dominated | 8
CTC 55-80, 5 | Dominated | Dominated | 10^*^
CTC 45-85, 10 | Dominated | 19^*^ | Dominated
CTC 50-75, 5 | Dominated | Dominated | 9
CTC 45-70, 5 | 11 | 13 | 21^*^
CTC 50-80, 5 | Dominated | Dominated | 13^*^
CTC 50-85, 5 | Dominated | Dominated | 17^*^
CTC 45-75, 5 | 19 | 21 | 11
CTC 45-80, 5 | 38 | 37 | 13
CTC 45-85, 5 | 104 | 73 | 32

COL – colonoscopy; LYG – life-years gained compared with no screening; CTC – computed tomographic colonography; -- indicates the default strategy (i.e., the strategy requiring the fewest colonoscopies and providing the fewest life-years gained).

* Near efficient (i.e., within 3 days of life gained per person of the efficient frontier).

Note: Strategies that were dominated in all 3 models are not shown. Analyses assume an increased population risk of colorectal cancer based on an incidence rate ratio comparing colorectal cancer incidence among 20- to 44-year-olds in 2012-2016 vs 1975-1979 of 1.19.