# Appendix 1 Estimation of Increasing Population-Level Risk of Colorectal Cancer

We considered several incidence rate ratio (IRR) estimates, which we used to characterize observed increases in colorectal cancer risk in adults 50 and younger. A key issue was that a simple IRR estimate, based on comparison of age-adjusted colorectal cancer incidence from SEER^115,145^ among current 20- to 44-year-olds (i.e., diagnosed in 2012 to 2016) relative to 20 to 44-year-olds diagnosed in 1975-1979 (a time period corresponding with the years of SEER data used for initial model calibration) resulted in IRR estimates that were lower than IRR estimates reported by Siegel et al.^18^

IRR estimates based directly on SEER data, described in section A1.1, ranged from 1.23 (95% confidence interval [CI] 1.15 to 1.31) to 1.25 (95% CI 1.19 to 1.31), depending on whether or not rates were delay-adjusted.^146,147^ [Note that the initial analysis, based on non delay-adjusted SEER incidence rates, yielded an IRR of 1.19. We later modified the inclusion criteria for the analysis, yielding the estimates reported above.^***^ Because this initial estimate was within the 95% confidence intervals reported above for the final estimates, we continued to use IRR of 1.19 in the simulations.] In contrast, Siegel and colleagues estimated age-period-cohort (APC) models using SEER data from 1974 to 2013. The analysis included all tumors recorded in SEER as occurring in the colon or rectum (excluding the appendix) regardless of histology and included all persons aged 20 and older. From these models, they estimate IRRs for colon and rectal cancer for individuals born around 1990 relative to those born around 1950, obtaining estimates of 2.40 for colon cancer (95% CI 1.11 to 5.19) and 4.32 for rectal cancer (95% CI 2.19 to 8.51). We note the high degree of uncertainty in these estimates.

Because of differences in estimated IRRs obtained from analysis of SEER rates and published estimates from APC models, the CISNET Colorectal Cancer Working Group requested that Rebecca Siegel, MPH, of the American Cancer Society fit APC models to SEER data, restricted to 20- to 44-year-olds, to estimate IRRs comparing persons born in 1977 (i.e., 40-year-olds in 2017) vs 1937 (i.e., 40-year-olds in 1977, the midpoint of the years of data the models were initially calibrated to). Consistent with assumptions made for simple SEER comparisons, these analyses excluded carcinoid tumors and other neuroendocrine carcinomas appearing in the colon or rectum^71^ and included SEER data through 2016. The revised IRR was 1.37 (95% CI 1.22 to 1.54). Details of Ms. Siegel’s analysis and the differences between her analysis for the CISNET Colorectal Cancer Working Group and her published paper are described in section A1.2.

There are several reasons for uncertainty in estimated IRRs that capture population-level increases in colorectal cancer risk, which we outline below.

- First, in APC models, age effects capture the increasing colorectal cancer risk that is reflected in the increases in colorectal cancer incidence with age, which the CISNET models simulate as an increase in adenoma prevalence and in the probability of adenoma transition to cancer with age; period effects capture the effect of changes in medical practice, such as the dissemination of screening and the increased use of endoscopic follow-up, over time and can also capture changes in risk, for example, such as changes in diet and exercise or environmental exposures (e.g., antibiotics); cohort effects capture changes in risk across generations (e.g., smoking rates).^148^ It is difficult to tease apart period and cohort effects because the time scales of age, period, and cohort effects are linearly dependent. In other words, age + year of birth = year of diagnosis, i.e., age + cohort = period. APC models are not identifiable without adding constraints to the age, period, and cohort effects, and different constraints can lead to different conclusions, especially about cohort effects.^148^
- Second, there is some uncertainty about which types of cancers to include as colorectal cancers. CISNET modelers focus on specific disease etiology and so include only cancers of the large intestine with histology indicative of colorectal cancer (see Appendix Table 1.1 for the histology codes included as colorectal cancer). In contrast, original analyses by Siegel and colleagues included cancers with a primary location in the large intestine, regardless of histology. This includes cancers with histology coded as “8240: carcinoid tumors, NOS” and “8246: neuroendocrine carcinoma”. Carcinoid cancers are a type of neuroendocrine cancer that occur throughout the body and have a somewhat different etiology than colorectal cancer. Neuroendocrine tumors are rare, though their incidence has increased in the last 15 years.^149^
- Third, the different modeling approaches each compared slightly different cohorts.
- Finally, IRR estimates are uncertain because even with rising rates, colorectal cancer remains relatively rare before age 50.

## A1.1 Specifications for SEER*Stat Incidence Analyses

Appendix Tables 1.1 and 1.2 detail the SEER*Stat analyses for estimation of age-adjusted colorectal cancer incidence rates among current 20- to 44-year-olds (i.e., cases diagnosed in 2012-2016) vs the incidence rate among 20 to 44-year-olds in 1975-1979, a period corresponding with the years of data used for initial calibration of the SimCRC, CRC-SPIN, and MISCAN models. Analyses were performed with and without use of delay-adjusted rates.

## A1.2 Information on APC Models by Siegel

Rebecca Siegel, MPH, of the American Cancer Society, carried out specific analyses for the CISNET Colorectal Cancer Working Group to inform increased risk assumptions. Ms. Siegel’s published analysis^18^ was based on all colorectal cancers in the 9 oldest SEER areas that were diagnosed in adults 20 years and older from 1974 through 2013 (the latest SEER data available at the time). Analyses carried out for CISNET include SEER data up through 2016. Ms. Siegel carried out a series of analyses in response to CISNET queries.

First, APC models were used to estimate IRRs comparing CRC incidence in persons born in 1975 vs 1935 based on SEER data (IRR=1.59).^18,22^

Next, to rule out that possibility that screening is not adequately accounted for by the model, SEER data were restricted to cancers diagnosed at ages 20 to 44 (IRR=1.52).

Finally, APC-modeled IRRs were generated based on the same case selection criteria used for simple IRR estimates (shown in Appendix Table 1.1). This case definition excludes colorectal cancer cases diagnosed at autopsy or death certificate only (these cases were included in the published analysis), second (or later) primaries, and cancers located in the colon and rectum that do not have histology indicative of colorectal cancer (the published analysis included all cancers in the colon and rectum including, for example, carcinoid tumors and other neuroendocrine carcinomas). The resulting rate ratio for 20- to 44-year-olds diagnosed in 1977 vs in 1937 is 1.37 (95% CI 1.22-1.54) (Appendix Figure 1.1).

Appendix Table 1.1 SEER*Stat 8.3.6 Rate Session Using Delay-Adjusted Rates

Tab | Variables/options
Data | Incidence – SEER 9 Reg Research Data with Delay-Adjustment, Malignant Only, Nov 2018 Sub (1975-2016) <Katrina/Rita Population Adjustment>; [underlined: Age variable]: Age recode with <1 year olds
Statistic | Rates (age-adjusted), include rate ratios with 95% CI; [underlined: Standard population]: 2000 US STD Population (19 age groups - Census P25-1130); Select “Include Rate Ratios on Last Row Variable Groupings”
Selection | [underlined: Other.Type of Reporting Source]: Unselect ‘Autopsy only’ and ‘Death certificate only’; [underlined: Site and Morphology.ICD-O-3 Hist/behav] = {; ‘8000/3: Neoplasm, malignant’,; ‘8001/3: Tumor cells, malignant’,; ‘8010/3: Carcinoma, NOS’,; ‘8020/3: Carcinoma, undifferentiated, NOS’,; ‘8021/3: Carcinoma, anaplastic, NOS’,; ‘8022/3: Pleomorphic carcinoma’,; ‘8140/3: Adenocarcinoma, NOS’,; ‘8141/3: Scirrhous adenocarcinoma’,; ‘8144/3: Adenocarcinoma, intestinal type’,; ‘8145/3: Carcinoma, diffuse type’,; ‘8210/3: Adenocarcinoma in adenomatous polyp’,; ‘8211/3: Tubular adenocarcinoma’,; ‘8213/3: Serrated adenocarcinoma’,; ‘8220/3: Adenocarcinoma in adenomatous polyposis coli’,; ‘8221/3: Adenocarcinoma in multiple adenomatous polyps’,; ‘8230/3: Solid carcinoma, NOS’,; ‘8255/3: Adenocarcinoma with mixed subtypes’,; ‘8260/3: Papillary adenocarcinoma, NOS’,; ‘8261/3: Adenocarcinoma in villous adenoma’,; ‘8262/3: Villous adenocarcinoma’,; ‘8263/3: Adenocarcinoma in tubulovillous adenoma’,; ‘8480/3: Mucinous adenocarcinoma’,; ‘8481/3: Mucin-producing adenocarcinoma’,; ‘8490/3: Signet ring cell carcinoma’,; ‘8560/3: Adenosquamous carcinoma’,; ‘8570/3: Adenocarcinoma with squamous metaplasia’,; ‘8574/3: Adenocarcinoma with neuroendocrine differentiation’}; [underlined: Multiple Primary Fields.Sequence number] = {One primary only, 1st of 2 or more primaries}; [underlined: Site and Morphology.Site recode ICD-O-3/WHO 2008] = {Cecum, Ascending Colon, Hepatic Flexure, Transverse Colon, Splenic Flexure, Descending Colon, Sigmoid Colon, Large Intestine NOS, Rectum and Rectosigmoid Junction}; [underlined: Required Delay Fields.Delay site = {‘Colon and Rectum’}]; [underlined: Age at Diagnosis.Age recode with <1 year olds] = {‘20-24 years’,‘25-29 years’,‘30-34 years’,‘35-39 years’,‘40-44 years’}; [underlined: Race, Sex, Year Dx, Registry, County.Year of diagnosis] = {‘1975’,‘1976’,‘1977’,‘1978’,‘1979’,‘2012’,‘2013’, ‘2014’,‘2015’,‘2016’}
Table | [underlined: Year of Diagnosis]: {1975-1979, 2012-2016}

Appendix Table 1.2 SEER*Stat 8.3.6 Rate Session Using Non-Delay-Adjusted Rates

Tab | Variables/options
Data | Incidence – SEER 9 Reg Research Data, Nov 2018 Sub (1975-2016) <Katrina/Rita Population Adjustment>; [underlined: Age variable]: Age recode with <1 year olds
Statistic | Rates (age-adjusted), include rate ratios with 95% CI; [underlined: Standard population]: 2000 US STD Population (19 age groups - Census P25-1130); Select “Include Rate Ratios on Last Row Variable Groupings”
Selection | [underlined: Other.Type of Reporting Source]: Unselect ‘Autopsy only’ and ‘Death certificate only’; [underlined: Site and Morphology.ICD-O-3 Hist/behav] = {; ‘8000/3: Neoplasm, malignant’,; ‘8001/3: Tumor cells, malignant’,; ‘8010/3: Carcinoma, NOS’,; ‘8020/3: Carcinoma, undifferentiated, NOS’,; ‘8021/3: Carcinoma, anaplastic, NOS’,; ‘8022/3: Pleomorphic carcinoma’,; ‘8140/3: Adenocarcinoma, NOS’,; ‘8141/3: Scirrhous adenocarcinoma’,; ‘8144/3: Adenocarcinoma, intestinal type’,; ‘8145/3: Carcinoma, diffuse type’,; ‘8210/3: Adenocarcinoma in adenomatous polyp’,; ‘8211/3: Tubular adenocarcinoma’,; ‘8213/3: Serrated adenocarcinoma’,; ‘8220/3: Adenocarcinoma in adenomatous polyposis coli’,; ‘8221/3: Adenocarcinoma in multiple adenomatous polyps’,; ‘8230/3: Solid carcinoma, NOS’,; ‘8255/3: Adenocarcinoma with mixed subtypes’,; ‘8260/3: Papillary adenocarcinoma, NOS’,; ‘8261/3: Adenocarcinoma in villous adenoma’,; ‘8262/3: Villous adenocarcinoma’,; ‘8263/3: Adenocarcinoma in tubulovillous adenoma’,; ‘8480/3: Mucinous adenocarcinoma’,; ‘8481/3: Mucin-producing adenocarcinoma’,; ‘8490/3: Signet ring cell carcinoma’,; ‘8560/3: Adenosquamous carcinoma’,; ‘8570/3: Adenocarcinoma with squamous metaplasia’,; ‘8574/3: Adenocarcinoma with neuroendocrine differentiation’}; [underlined: Multiple Primary Fields.Sequence number] = {One primary only, 1st of 2 or more primaries}; [underlined: Site and Morphology.Site recode ICD-O-3/WHO 2008] = {Cecum, Ascending Colon, Hepatic Flexure, Transverse Colon, Splenic Flexure, Descending Colon, Sigmoid Colon, Large Intestine NOS, Rectum and Rectosigmoid Junction}; [underlined: Age at Diagnosis.Age recode with <1 year olds] = {‘20-24 years’,‘25-29 years’,‘30-34 years’,‘35-39 years’,‘40-44 years’}; [underlined: Race, Sex, Year Dx, Registry, County.Year of diagnosis] = {‘1975’,‘1976’,‘1977’,‘1978’,‘1979’,‘2012’,‘2013’, ‘2014’,‘2015’,‘2016’}
Table | [underlined: Year of Diagnosis]: {1975-1979, 2012-2016}

Appendix Figure 1.1 Incidence Rate Ratio and 95% Confidence Interval by Birth Cohort From an Age-Period-Cohort Model Fit to Colorectal Cancer Incidence Rates Among 20- to 44-Year-Olds in SEER

Incidence rate ratio by birth cohort.

*** The initial analysis included only the following reporting sources: “Hospital inpatient”; “Laboratory only”; “Physician’s office/private medical practitioner”; or “Nursing/convalescent home/hospice”. The final analysis also included the following reporting sources: “Radiation treatment centers or medical oncology centers” and “Other hospital outpatient units/surgery centers”. In both the initial and final SEER analyses, cases with reporting source coded as “Autopsy only” or “Death certificate only” were excluded.