# References

1 Bibbins-Domingo K, Grossman DC, Curry SJ, . Screening for colorectal cancer: US Preventive Services Task Force recommendation statement. JAMA. 2016;315(23):2564–75. PMID: 27304597 10.1001/jama.2016.5989 27304597
2 Crockett SD, Nagtegaal ID. Terminology, molecular features, epidemiology, and management of serrated colorectal neoplasia. Gastroenterology. 2019;157(4):949–66.e4. PMID: 31323292. 10.1053/j.gastro.2019.06.041 31323292
3 Siegel RL, Miller KD, Goding Sauer A, . Colorectal cancer statistics, 2020. CA Cancer J Clin. 2020;70(3):145–64. PMID: 32133645. 10.3322/caac.21601 32133645
4 SEER. Cancer Stat Facts: Colorectal Cancer. https://seer.cancer.gov/statfacts/html/colorect.html. Accessed Nov 14, 2019. PMID.
5 CP*Trends: An Online Tool to Compare Cohort and Period Trends across Cancer Sites. Surveillance Research Program Web Site. https://surveillance.cancer.gov/cptrends. Accessed Nov 14, 2019.
6 Siegel RL, Fedewa SA, Anderson WF, . Colorectal cancer incidence patterns in the United States, 1974–2013. J Natl Cancer Inst. 2017;109(8):djw322. PMID: 28376186. 10.1093/jnci/djw322 28376186
7 Surveillance Epidemiology and End Results (SEER) Program SEER*Stat Database. Incidence - SEER 9 Regs Research Data with Delay-Adjustment, Malignant Only, Nov 2018 Sub (1975–2016) <Katrina/Rita Population Adjustment> - Linked To County Attributes - Total U.S., 1969–2017 Counties, National Cancer Institute, DCCPS, Surveillance Research Program, released April 2019, based on the November 2018 submission. . www.seer.cancer.gov. Accessed Jan 29, 2020.
8 Virostko J, Capasso A, Yankeelov TE, . Recent trends in the age at diagnosis of colorectal cancer in the US National Cancer Data Base, 2004–2015. Cancer. 2019;125(21):3828–35. PMID: 31328273. 10.1002/cncr.32347 31328273
9 Cress RD, Morris CR, Wolfe BM. Cancer of the colon and rectum in California: trends in incidence by race/ethnicity, stage, and subsite. Prev Med. 2000;31(4):447–53. PMID: 11006071. 10.1006/pmed.2000.0730 11006071
10 Ward E, Jemal A, Cokkinides V, . Cancer disparities by race/ethnicity and socioeconomic status. CA Cancer J Clin. 2004;54(2):78–93. PMID: 15061598. 10.3322/canjclin.54.2.78 15061598
11 Irby K, Anderson WF, Henson DE, . Emerging and widening colorectal carcinoma disparities between blacks and whites in the United States (1975–2002). Cancer Epidemiol Biomarkers Prev. 2006;15(4):792–7. PMID: 16614125. 10.1158/1055-9965.EPI-05-0879 16614125
12 Murphy CC, Lund JL, Sandler RS. Young-onset colorectal cancer: earlier diagnoses or increasing disease burden? Gastroenterology. 2017;152(8):1809–12.e3. PMID: 28461196. 10.1053/j.gastro.2017.04.030 28461196
13 Phipps AI, Scoggins J, Rossing MA, . Temporal trends in incidence and mortality rates for colorectal cancer by tumor location: 1975–2007. Am J Public Health. 2012;102(9):1791–7. PMID: 22873481. 10.2105/AJPH.2011.300393 22873481
14 Siegel RL, Ward EM, Jemal A. Trends in colorectal cancer incidence rates in the United States by tumor location and stage, 1992–2008. Cancer Epidemiol Biomarkers Prev. 2012;21(3):411–6. PMID: 22219318. 10.1158/1055-9965.EPI-11-1020 22219318
15 Siegel RL, Miller KD, Fedewa SA, . Colorectal cancer statistics, 2017. CA Cancer J Clin. 2017;67(3):177–93. PMID: 28248415. 10.3322/caac.21395 28248415
16 Henry KA, Sherman RL, McDonald K, . Associations of census-tract poverty with subsite-specific colorectal cancer incidence rates and stage of disease at diagnosis in the United States. J Cancer Epidemiol. 2014;2014:823484. PMID: 25165475. 10.1155/2014/823484 25165475
17 Brenner H, Hoffmeister M, Arndt V, . Protection from right- and left-sided colorectal neoplasms after colonoscopy: population-based study. J Natl Cancer Inst. 2010;102(2):89–95. PMID: 20042716. 10.1093/jnci/djp436 20042716
18 Brenner H, Chang-Claude J, Seiler CM, . Protection from colorectal cancer after colonoscopy: a population-based, case-control study. Ann Intern Med. 2011;154(1):22–30. PMID: 21200035. 10.7326/0003-4819-154-1-201101040-00004 21200035
19 Doubeni CA, Weinmann S, Adams K, . Screening colonoscopy and risk for incident late-stage colorectal cancer diagnosis in average-risk adults: a nested case-control study. Ann Intern Med. 2013;158(5 Pt 1):312–20. PMID: 23460054.23460054
20 Baxter NN, Warren JL, Barrett MJ, . Association between colonoscopy and colorectal cancer mortality in a US cohort according to site of cancer and colonoscopist specialty. J Clin Oncol. 2012;30(21):2664–9. PMID: 22689809. 10.1200/JCO.2011.40.4772 22689809
21 Nishihara R, Wu K, Lochhead P, . Long-term colorectal-cancer incidence and mortality after lower endoscopy. N Engl J Med. 2013;369(12):1095–105. PMID: 24047059. 10.1056/NEJMoa1301969 24047059
22 Yamauchi M, Lochhead P, Morikawa T, . Colorectal cancer: a tale of two sides or a continuum? Gut. 2012;61(6):794–7. PMID: 22490520. 10.1136/gutjnl-2012-302014 22490520
23 Azzoni C, Bottarelli L, Campanini N, . Distinct molecular patterns based on proximal and distal sporadic colorectal cancer: arguments for different mechanisms in the tumorigenesis. Int J Colorectal Dis. 2007;22(2):115–26. PMID: 17021745. 10.1007/s00384-006-0093-x 17021745
24 O’Brien MJ, Winawer SJ, Zauber AG, . Flat adenomas in the National Polyp Study: is there increased risk for high-grade dysplasia initially or during surveillance? Clin Gastroenterol Hepatol. 2004;2(10):905–11. 2004. PMID: 15476154. 10.1016/s1542-3565(04)00392-1 15476154
25 Siegel R, DeSantis C, Jemal A. Colorectal cancer statistics, 2014. CA Cancer J Clin. 2014;64(2):104–17. PMID: 24639052 10.3322/caac.21220 24639052
26 Lu P, Fields AC, Vise AS, . Anatomic distribution of colorectal adenocarcinoma in young patients. Dis Colon Rectum. 2019;62(8):920–4. PMID: 31162374. 10.1097/DCR.0000000000001422 31162374
27 Murphy CC, Sandler RS, Sanoff HK, . Decrease in incidence of colorectal cancer among individuals 50 years or older after recommendations for population-based screening. Clin Gastroenterol Hepatol. 2017;15(6):903–9.e6. PMID: 27609707. 10.1016/j.cgh.2016.08.037 27609707
28 Wong RJ. Marked variations in proximal colon cancer survival by race/ethnicity within the United States. J Clin Gastroenterol. 2010;44(9):625–30. PMID: 19996985. 10.1097/MCG.0b013e3181c64a7a 19996985
29 Lee B, Holub J, Peters D, . Prevalence of colon polyps detected by colonoscopy screening of asymptomatic Hispanic patients. Dig Dis Sci. 2012;57(2):481–8. PMID: 21918852. 10.1007/s10620-011-1898-1 21918852
30 Lieberman DA, Williams JL, Holub JL, . Race, ethnicity, and sex affect risk for polyps >9 mm in average-risk individuals. Gastroenterology. 2014;147(2):351–8. PMID: 24786894. 10.1053/j.gastro.2014.04.037 24786894
31 Walsh JM, Terdiman JP. Colorectal cancer screening: scientific review. JAMA. 2003;289(10):1288–96. PMID: 12633191. 10.1001/jama.289.10.1288 12633191
32 Chen CD, Yen MF, Wang WM, . A case-cohort study for the disease natural history of adenoma-carcinoma and de novo carcinoma and surveillance of colon and rectum after polypectomy: implication for efficacy of colonoscopy. Br J Cancer. 2003;88(12):1866–73. PMID: 12799628.12799628
33 Galiatsatos P, Foulkes WD. Familial adenomatous polyposis. Am J Gastroenterol. 2006;101(2):385–98. PMID: 16454848.16454848
34 Lynch HT, Smyrk T. Hereditary nonpolyposis colorectal cancer (Lynch syndrome). An updated review. Cancer. 1996;78(6):1149–67. PMID: 8826936. 10.1002/(SICI)1097-0142(19960915)78:6<1149::AID-CNCR1>3.0.CO;2-5 8826936
35 Morson B. President’s address. The polyp-cancer sequence in the large bowel. Proc R Soc Med. 1974;67(6 Pt 1):451–7. PMID: 4853754.4853754
36 Jarvinen HJ, Mecklin JP, Sistonen P. Screening reduces colorectal cancer rate in families with hereditary nonpolyposis colorectal cancer. Gastroenterology. 1995;108(5):1405–11. PMID: 7729632.7729632
37 Citarda F, Tomaselli G, Capocaccia R, . Efficacy in standard clinical practice of colonoscopic polypectomy in reducing colorectal cancer incidence. Gut. 2001;48(6):812–5. PMID: 11358901.11358901
38 Winawer SJ, Zauber AG, Ho MN, . Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. 1993;329(27):1977–81. PMID: 8247072. 10.1056/NEJM199312303292701 8247072
39 Thiis-Evensen E, Hoff GS, Sauar J, . Population-based surveillance by colonoscopy: effect on the incidence of colorectal cancer. Telemark Polyp Study I. Scand J Gastroenterol. 1999;34(4):414–20. PMID: 10365903. 10.1080/003655299750026443 10365903
40 Selby JV, Friedman GD, Quesenberry CP, Jr., . A case-control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. 1992;326(10):653–7. PMID: 1736103. 10.1056/NEJM199203053261001 1736103
41 Newcomb PA, Norfleet RG, Storer BE, . Screening sigmoidoscopy and colorectal cancer mortality. J Natl Cancer Inst. 1992;84(20):1572–5. PMID: 1404450. 10.1093/jnci/84.20.1572 1404450
42 Muller AD, Sonnenberg A. Prevention of colorectal cancer by flexible endoscopy and polypectomy. A case-control study of 32,702 veterans. Ann Intern Med. 1995;123(12):904–10. PMID: 7486484. 10.7326/0003-4819-123-12-199512150-00002 7486484
43 Zauber AG, Winawer SJ, O’Brien MJ, . Colonoscopic polypectomy and long-term prevention of colorectal-cancer deaths. N Engl J Med. 2012;366(8):687–96. PMID: 22356322. 10.1056/NEJMoa1100370 22356322
44 Heitman SJ, Ronksley PE, Hilsden RJ, . Prevalence of adenomas and colorectal cancer in average risk individuals: a systematic review and meta-analysis. Clin Gastroenterol Hepatol. 2009;7(12):1272–8. PMID: 19523536.19523536
45 Hofstad B, Vatn MH, Andersen SN, . Growth of colorectal polyps: redetection and evaluation of unresected polyps for a period of three years. Gut. 1996;39(3):449–56. PMID: 8949653.8949653
46 Bersentes K, Fennerty MB, Sampliner RE, . Lack of spontaneous regression of tubular adenomas in two years of follow-up. Am J Gastroenterol. 1997;92(7):1117–20. PMID: 9219781.9219781
47 Young GP, Bosch LJ. Fecal tests: from blood to molecular markers. Curr Colorectal Cancer Rep. 2011;7(1):62–70. PMID: 21423316. 10.1007/s11888-010-0084-8 21423316
48 Crockett SD, Snover DC, Ahnen DJ, . Sessile serrated adenomas: an evidence-based guide to management. Clin Gastroenterol Hepatol. 2015;13(1):11–26. PMID: 24216467.24216467
49 Schoenfeld P. Small and diminutive polyps: implications for colorectal cancer screening with computed tomography colonography. Clin Gastroenterol Hepatol. 2006;4(3):293–5. PMID: 16527690. 10.1016/j.cgh.2005.12.025 16527690
50 Schoen RE, Weissfeld JL, Pinsky PF, . Yield of advanced adenoma and cancer based on polyp size detected at screening flexible sigmoidoscopy. Gastroenterology. 2006;131(6):1683–9. PMID: 17188959. 10.1053/j.gastro.2006.08.025 17188959
51 Dube C, Yakubu M, McCurdy BR, . Risk of advanced adenoma, colorectal cancer, and colorectal cancer mortality in people with low-risk adenomas at baseline colonoscopy: a systematic review and meta-analysis. Am J Gastroenterol. 2017;112(12):1790–801. PMID: 29087393. 10.1038/ajg.2017.360 29087393
52 Hassan C, Pickhardt PJ, Kim DH, . Systematic review: distribution of advanced neoplasia according to polyp size at screening colonoscopy. Aliment Pharmacol Ther. 2010;31(2):210–7. PMID: 19814745.19814745
53 Corley DA, Jensen CD, Marks AR, . Variation of adenoma prevalence by age, sex, race, and colon location in a large population: implications for screening and quality programs. Clin Gastroenterol Hepatol. 2013;11(2):172–80. PMID: 22985608. 10.1016/j.cgh.2012.09.010 22985608
54 Coleman HG, Loughrey MB, Murray LJ, . Colorectal cancer risk following adenoma removal: a large prospective population-based cohort study. Cancer Epidemiol Biomarkers Prev. 2015;24(9):1373–80. PMID: 26082403. 10.1158/1055-9965.EPI-15-0085 26082403
55 Mooers HM, Holub JL, Lieberman DA. Screening women aged 50–59 for CRC using fecal occult blood test produces outcomes similar to men undergoing screening colonoscopy. Dig Dis Sci. 2018;63(10):2780–5. PMID: 29948570. 10.1007/s10620-018-5156-7 29948570
56 Imperiale TF, Abhyankar PR, Stump TE, . Prevalence of advanced, precancerous colorectal neoplasms in black and white populations: a systematic review and meta-analysis. Gastroenterology. 2018;155(6):1776–1786.e1. PMID: 30142339. 10.1053/j.gastro.2018.08.020 30142339
57 Laiyemo AO, Doubeni C, Pinsky PF, . Race and colorectal cancer disparities: health-care utilization vs different cancer susceptibilities. J Natl Cancer Inst. 2010;102(8):538–46. PMID: 20357245. 10.1093/jnci/djq068 20357245
58 Mendelsohn RB, Winawer SJ, Jammula A, . Adenoma prevalence in blacks and whites having equal adherence to screening colonoscopy: the National Colonoscopy Study. Clin Gastroenterol Hepatol. 2017;15(9):1469–70. PMID: 28419856.28419856
59 Eaden JA, Mayberry JF. Colorectal cancer complicating ulcerative colitis: a review. Am J Gastroenterol. 2000;95(10):2710–9. PMID: 11051339.11051339
60 Schoen RE. Families at risk for colorectal cancer: risk assessment and genetic testing. J Clin Gastroenterol. 2000;31(2):114–20. PMID: 10993425. 10.1097/00004836-200009000-00005 10993425
61 Weitz J, Koch M, Debus J, . Colorectal cancer. Lancet. 2005;365(9454):153–65. PMID: 1563929815639298
62 Winawer SJ. Screening of colorectal cancer: progress and problems. Recent Results Cancer Res. 2005;166:231–44. PMID: 15648193. 10.1007/3-540-26980-0_15 15648193
63 Lowery JT, Ahnen DJ, Schroy PC, 3rd, . Understanding the contribution of family history to colorectal cancer risk and its clinical implications: a state-of-the-science review. Cancer. 2016;122(17):2633–45. PMID: 27258162. 10.1002/cncr.30080 27258162
64 Taylor DP, Burt RW, Williams MS, . Population-based family history-specific risks for colorectal cancer: a constellation approach. Gastroenterology. 2010;138(3):877–85. PMID: 19932107. 10.1053/j.gastro.2009.11.044 19932107
65 Johns LE, Houlston RS. A systematic review and meta-analysis of familial colorectal cancer risk. Am J Gastroenterol. 2001;96(10):2992–3003. PMID: 11693338.11693338
66 Baglietto L, Jenkins MA, Severi G, . Measures of familial aggregation depend on definition of family history: meta-analysis for colorectal cancer. J Clin Epidemiol. 2006;59(2):114–24. PMID: 16426946. 10.1016/j.jclinepi.2005.07.018 16426946
67 Hopper JL. Disease-specific prospective family study cohorts enriched for familial risk. Epidemiol Perspect Innov. 2011;8(1):2. PMID: 21352566.21352566
68 Henrikson NB, Webber EM, Goddard KA, . Family history and the natural history of colorectal cancer: systematic review. Genet Med. 2015;17(9):702–12. PMID: 25590981. 10.1038/gim.2014.188 25590981
69 American Cancer Society. Colorectal Cancer Facts & Figures 2017–2019. Atlanta: 2019.
70 Win AK, Macinnis RJ, Hopper JL, . Risk prediction models for colorectal cancer: a review. Cancer Epidemiol Biomarkers Prev. 2012;21(3):398–410. PMID: 22169185. 10.1158/1055-9965.EPI-11-0771 22169185
71 Ali Khan U, Fallah M, Tian Y, . Personal history of diabetes as important as family history of colorectal cancer for risk of colorectal cancer: a nationwide cohort study. Am J Gastroenterol. 2020;115(7):1103–9. PMID: 32618661. 10.14309/ajg.0000000000000669 32618661
72 Joseph DA, King JB, Dowling NF, . Vital Signs: colorectal cancer screening test use - United States, 2018. MMWR Morb Mortal Wkly Rep. 2020;69(10):253–9. PMID: 32163384. 10.15585/mmwr.mm6910a1 32163384
73 White A, Thompson TD, White MC, . Cancer screening test use - United States, 2015. MMWR Morb Mortal Wkly Rep. 2017;66(8):201–6. PMID: 28253225. 10.15585/mmwr.mm6608a1 28253225
74 Prevlance of colorectal cancer screening among adults--Behavioral Risk Factor Surveillance System, United States, 2010. MMWR Morb Mortal Wkly Rep. 2012;61(suppl):51–6. PMID: 22695464.22695464
75 Holden DJ, Jonas DE, Porterfield DS, . Systematic review: enhancing the use and quality of colorectal cancer screening. Ann Intern Med. 2010;152(10):668–76. PMID: 20388703.20388703
76 de Moor JS, Cohen RA, Shapiro JA, . Colorectal cancer screening in the United States: trends from 2008 to 2015 and variation by health insurance coverage. Prev Med. 2018;112:199–206. PMID: 29729288. 10.1016/j.ypmed.2018.05.001 29729288
77 Rim SH, Joseph DA, Steele CB, . Colorectal cancer screening - United States, 2002, 2004, 2006, and 2008. MMWR Surveill Summ. 2011;60(Suppl):42–6. PMID: 21430619.21430619
78 Zapka J, Klabunde CN, Taplin S, . Screening colonoscopy in the US: attitudes and practices of primary care physicians. J Gen Intern Med. 2012;27(9):1150–8. PMID: 22539065. 10.1007/s11606-012-2051-3 22539065
79 Williams CD, Grady WM, Zullig LL. Use of NCCN guidelines, other guidelines, and biomarkers for colorectal cancer screening. J Natl Compr Canc Netw. 2016;14(11):1479–85. PMID: 27799515. 10.6004/jnccn.2016.0154 27799515
80 Helsingen LM, Vandvik PO, Jodal HC, . Colorectal cancer screening with faecal immunochemical testing, sigmoidoscopy or colonoscopy: a clinical practice guideline. BMJ. 2019;367:I5515. PMID: 31578196. 10.1136/bmj.l5515 31578196
81 U.S. Preventive Services Task Force. Screening for colorectal cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2008;149(9):627–37. PMID: 18838716. 10.7326/0003-4819-149-9-200811040-00243 18838716
82 Lin JS, Piper MA, Perdue LA, . Screening for Colorectal Cancer: A Systematic Review for the US Preventive Services Task Force: Evidence Synthesis No. 135. Rockville (MD): Agency for Healthcare Research and Quality; 2016. PMID: 2744132827441328.
83 Lin JS, Piper MA, Perdue LA, . Screening for colorectal cancer: updated evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2016;315(23):2576–94. PMID: 27305422. 10.1001/jama.2016.3332 27305422
84 Fitzpatrick-Lewis D, Ali MU, Warren R, . Screening for colorectal cancer: a systematic review and meta-analysis. Clin Colorectal Cancer. 2016;15(4):298–313. PMID: 27133893. 10.1016/j.clcc.2016.03.003 27133893
85 Zhang J, Cheng Z, Ma Y, . Effectiveness of screening modalities in colorectal cancer: a network meta-analysis. Clin Colorectal Cancer. 2017;16(4):252–63. PMID: 28687458. 10.1016/j.clcc.2017.03.018 28687458
86 Elmunzer BJ, Singal AG, Sussman JB, . Comparing the effectiveness of competing tests for reducing colorectal cancer mortality: a network meta-analysis. Gastrointest Endosc. 2015;81(3):700–9.e3. PMID: 25708757. 10.1016/j.gie.2014.10.033 25708757
87 Reumkens A, Rondagh EJ, Bakker CM, . Post-colonoscopy complications: a systematic review, time trends, and meta-analysis of population-based studies. Am J Gastroenterol. 2016;111(8):1092–101. PMID: 27296945. 10.1038/ajg.2016.234 27296945
88 Tinmouth J, Vella ET, Baxter NN, . Colorectal cancer screening in average risk populations: evidence summary. Can J Gastroenterol Hepatol. 2016;2016:2878149. PMID: 27597935. 10.1155/2016/2878149 27597935
89 Song L, Jia J, Peng X, . The performance of the SEPT9 gene methylation assay and a comparison with other CRC screening tests: a meta-analysis. Sci Rep. 2017;7(1):3032. PMID: 28596563. 10.1038/s41598-017-03321-8 28596563
90 Yan L, Zhao W, Yu H, . A comprehensive meta-analysis of microRNAs for predicting colorectal cancer. Medicine (Baltimore). 2016;95(9):e2738. PMID: 26945359. 10.1097/MD.0000000000002738 26945359
91 Vermeer NC, Snijders HS, Holman FA, . Colorectal cancer screening: systematic review of screen-related morbidity and mortality. Cancer Treat Rev. 2017;54:87–98. PMID: 28236723. 10.1016/j.ctrv.2017.02.002 28236723
92 Pan J, Xin L, Ma YF, . Colonoscopy reduces colorectal cancer incidence and mortality in patients with non-malignant findings: a meta-analysis. Am J Gastroenterol. 2016;111(3):355–65. PMID: 26753884. 10.1038/ajg.2015.418 26753884
93 Duarte RB, Bernardo WM, Sakai CM, . Computed tomography colonography versus colonoscopy for the diagnosis of colorectal cancer: a systematic review and meta-analysis. Ther Clin Risk Manag. 2018;14:349–60. PMID: 29503554. 10.2147/TCRM.S152147 29503554
94 Imperiale TF, Gruber RN, Stump TE, . Performance characteristics of fecal immunochemical tests for colorectal cancer and advanced adenomatous polyps: a systematic review and meta-analysis. Ann Intern Med. 2019;170(5):319–329. PMID: 30802902. 10.7326/M18-2390 30802902
95 Zhao S, Wang S, Pan P, . Magnitude, risk factors, and factors associated with adenoma miss rate of tandem colonoscopy: a systematic review and meta-analysis. Gastroenterology. 2019;156(6):1661–1674.e11. PMID: 30738046. 10.1053/j.gastro.2019.01.260 30738046
96 Health Quality Ontario. Colon capsule endoscopy for the detection of colorectal polyps: an evidence-based analysis. Ont Health Technol Assess Ser. 2015;15(14):1–39. PMID: 26366239.26366239
97 Spada C, Hassan C, Marmo R, . Meta-analysis shows colon capsule endoscopy is effective in detecting colorectal polyps. Clin Gastroenterol Hepatol. 2010;8(6):516–22. PMID: 20215066. 10.1016/j.cgh.2010.02.018 20215066
98 Rokkas T, Papaxoinis K, Triantafyllou K, . A meta-analysis evaluating the accuracy of colon capsule endoscopy in detecting colon polyps. Gastrointest Endosc. 2010;71(4):792–8. PMID: 20363421. 10.1016/j.gie.2009.10.050 20363421
99 Hamza S, Dancourt V, Lejeune C, . Diagnostic yield of a one sample immunochemical test at different cut-off values in an organised screening programme for colorectal cancer. Eur J Cancer. 2013;49(12):2727–33. PMID: 23601670. 10.1016/j.ejca.2013.03.023 23601670
100 Guittet L, Bouvier V, Mariotte N, . Performance of immunochemical faecal occult blood test in colorectal cancer screening in average-risk population according to positivity threshold and number of samples. Int J Cancer. 2009;125(5):1127–33. PMID: 19431212. 10.1002/ijc.24407 19431212
101 Lin JS, Webber EM, Beil TL, . Fecal DNA Testing in Screening for Colorectal Cancer in Average-Risk Adults. Rockville, MD: 2012. PMID: 2245788322457883.
102 Adler A, Wegscheider K, Lieberman D, . Factors determining the quality of screening colonoscopy: a prospective study on adenoma detection rates, from 12,134 examinations (Berlin colonoscopy project 3, BECOP-3). Gut. 2013;62(2):236–41. PMID: 22442161. 10.1136/gutjnl-2011-300167 22442161
103 Whitlock EP, Lin J, Liles E, . Screening for Colorectal Cancer: An Updated Systematic Review. Agency for Healthcare Research and Quality (US); 2008. PMID: NBK35179 [bookaccession].
104 Whitlock EP, Lin JS, Liles E, . Screening for colorectal cancer: a targeted, updated systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2008;149(9):638–58. PMID: 18838718. 10.7326/0003-4819-149-9-200811040-00245 18838718
105 United Nations Development Programme. 2016 Human Development Report: Human Development for Everyone. New York, NY: 2016. PMID.
106 Lijmer JG, Mol BW, Heisterkamp S, . Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282(11):1061–6. PMID: 10493205. 10.1001/jama.282.11.1061 10493205
107 Leeflang MM, Bossuyt PM, Irwig L. Diagnostic test accuracy may vary with prevalence: implications for evidence-based diagnosis. J Clin Epidemiol. 2009;62(1):5–12. PMID: 18778913. 10.1016/j.jclinepi.2008.04.007 18778913
108 Ransohoff DF, Feinstein AR. Problems of spectrum and bias in evaluating the efficacy of diagnostic tests. N Engl J Med. 1978;299(17):926–30. PMID: 692598. 10.1056/NEJM197810262991705 692598
109 Rutjes AW, Reitsma JB, Di Nisio M, . Evidence of bias and variation in diagnostic accuracy studies. CMAJ. 2006;174(4):469–76. PMID: 16477057. 10.1503/cmaj.050090 16477057
110 Whiting P, Rutjes AW, Reitsma JB, . Sources of variation and bias in studies of diagnostic accuracy: a systematic review. Ann Intern Med. 2004;140(3):189–202. PMID: 14757617. 10.7326/0003-4819-140-3-200402030-00010 14757617
111 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
112 Wells G, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed December 3, 2018.
113 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529–36. PMID: 22007046. 10.7326/0003-4819-155-8-201110180-00009 22007046
114 You JJ, Liu Y, Kirby J, . Virtual colonoscopy, optical colonoscopy, or fecal occult blood testing for colorectal cancer screening: results of a pilot randomized controlled trial. Trials. 2015;16:296. PMID: 26156248. 10.1186/s13063-015-0826-7 26156248
115 de Groot JA, Bossuyt PM, Reitsma JB, . Verification problems in diagnostic accuracy studies: consequences and solutions. BMJ. 2011;343:d4770. PMID: 21810869. 10.1136/bmj.d4770 21810869
116 Fraser CG, Allison JE, Halloran SP, . A proposal to standardize reporting units for fecal immunochemical tests for hemoglobin. J Natl Cancer Inst. 2012;104(11):810–4. PMID: 22472305. 10.1093/jnci/djs190 22472305
117 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: 2440462724404627.
118 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches. The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
119 Atkin WS, Wooldrage K, Parkin DM, . Long term effects of once-only flexible sigmoidoscopy screening after 17 years of follow-up: the UK Flexible Sigmoidoscopy Screening randomised controlled trial. Lancet. 2017;389(10076):1624–33. PMID: 28236467. 10.1016/S0140-6736(17)30396-3 28236467
120 Berry DP, Clarke P, Hardcastle JD, . Randomized trial of the addition of flexible sigmoidoscopy to faecal occult blood testing for colorectal neoplasia population screening. Br J Surg. 1997;84(9):1274–6. PMID: 9313712.9313712
121 Brevinge H, Lindholm E, Buntzen S, . Screening for colorectal neoplasia with faecal occult blood testing compared with flexible sigmoidoscopy directly in a 55–56 years’ old population. Int J Colorectal Dis. 1997;12(5):291–5. PMID: 9401844. 10.1007/s003840050108 9401844
122 Chiu HM, Chen SL, Yen AM, . Effectiveness of fecal immunochemical testing in reducing colorectal cancer mortality from the One Million Taiwanese Screening Program. Cancer. 2015;121(18):3221–9. PMID: 25995082. 10.1002/cncr.29462 25995082
123 Faivre J, Dancourt V, Denis B, . Comparison between a guaiac and three immunochemical faecal occult blood tests in screening for colorectal cancer. Eur J Cancer. 2012;48(16):2969–76. PMID: 22572481. 10.1016/j.ejca.2012.04.007 22572481
124 Faivre J, Dancourt V, Lejeune C, . Reduction in colorectal cancer mortality by fecal occult blood screening in a French controlled study. Gastroenterology. 2004;126(7):1674–80. PMID: 15188160. 10.1053/j.gastro.2004.02.018 15188160
125 Garcia-Albeniz X, Hsu J, Bretthauer M, . Effectiveness of screening colonoscopy to prevent colorectal cancer among Medicare beneficiaries aged 70 to 79 years: a prospective observational study. Ann Intern Med. 2017;166(1):18–26. PMID: 27669524. 10.7326/M16-0758 27669524
126 Hol L, van Leerdam ME, van Ballegooijen M, . Screening for colorectal cancer: randomised trial comparing guaiac-based and immunochemical faecal occult blood testing and flexible sigmoidoscopy. Gut. 2010;59(1):62–8. PMID: 19671542. 10.1136/gut.2009.177089 19671542
127 Holme O, Loberg M, Kalager M, . Long-term effectiveness of sigmoidoscopy screening on colorectal cancer incidence and mortality in women and men: a randomized trial. JAMA. 2018;168(11):775–782. PMID: 29710125. 10.7326/M17-1441 29710125
128 Kronborg O, Jorgensen OD, Fenger C, . Randomized study of biennial screening with a faecal occult blood test: results after nine screening rounds. Scand J Gastroenterol. 2004;39(9):846–51. PMID: 15513382. 10.1080/00365520410003182 15513382
129 Lindholm E, Brevinge H, Haglind E. Survival benefit in a randomized clinical trial of faecal occult blood screening for colorectal cancer. Br J Surg. 2008;95(8):1029–36. PMID: 18563785. 10.1002/bjs.6136 18563785
130 Miller EA, Pinsky PF, Schoen RE, . Effect of flexible sigmoidoscopy screening on colorectal cancer incidence and mortality: long-term follow-up of the randomised US PLCO cancer screening trial. Lancet Gastroenterol Hepatol. 2019;4(2):101–10. PMID: 30502933. 10.1016/S2468-1253(18)30358-3 30502933
131 Passamonti B, Malaspina M, Fraser CG, . A comparative effectiveness trial of two faecal immunochemical tests for haemoglobin (FIT). Assessment of test performance and adherence in a single round of a population-based screening programme for colorectal cancer. Gut. 2018;67(3):485–96. PMID: 27974550. 10.1136/gutjnl-2016-312716 27974550
132 Pitkaniemi J, Seppa K, Hakama M, . Effectiveness of screening for colorectal cancer with a faecal occult-blood test, in Finland. BMJ Open Gastroenterol. 2015;2(1):e000034. PMID: 26462283. 10.1136/bmjgast-2015-000034 26462283
133 Quintero E, Castells A, Bujanda L, . Colonoscopy versus fecal immunochemical testing in colorectal-cancer screening. N Engl J Med. 2012;366(8):697–706. PMID: 22356323. 10.1056/NEJMoa1108895 22356323
134 Rasmussen M, Kronborg O, Fenger C, . Possible advantages and drawbacks of adding flexible sigmoidoscopy to hemoccult-II in screening for colorectal cancer. A randomized study. Scand J Gastroenterol. 1999;34(1):73–8. PMID: 10048736. 10.1080/00365529950172862 10048736
135 Regge D, Iussich G, Segnan N, . Comparing CT colonography and flexible sigmoidoscopy: a randomised trial within a population-based screening programme. Gut. 2017;66(8):1434–40. PMID: 27196588. 10.1136/gutjnl-2015-311278 27196588
136 Sali L, Mascalchi M, Falchini M, . Reduced and full-preparation CT colonography, fecal immunochemical test, and colonoscopy for population screening of colorectal cancer: a randomized trial. J Natl Cancer Inst. 2016;108(2). PMID: 26719225 10.1093/jnci/djv319 26719225
137 Santare D, Kojalo I, Liepniece-Karele I, . Comparison of the yield from two faecal immunochemical tests at identical cutoff concentrations - a randomized trial in Latvia. Eur J Gastroenterol Hepatol. 2016;28(8):904–10. PMID: 27120388 10.1097/MEG.0000000000000650 27120388
138 Scholefield JH, Moss SM, Mangham CM, . Nottingham trial of faecal occult blood testing for colorectal cancer: a 20-year follow-up. Gut. 2012;61(7):1036–40. PMID: 22052062. 10.1136/gutjnl-2011-300774 22052062
139 Schreuders EH, Grobbee EJ, Nieuwenburg SA, . Multiple rounds of one sample versus two sample faecal immunochemical test-based colorectal cancer screening: a population-based study. Lancet Gastroenterol Hepatol. 2019;4(8):622–631. PMID: 31196734. 10.1016/S2468-1253(19)30176-1 31196734
140 Segnan N, Armaroli P, Bonelli L, . Once-only sigmoidoscopy in colorectal cancer screening: follow-up findings of the Italian Randomized Controlled Trial--SCORE. J Natl Cancer Inst. 2011;103(17):1310–22. PMID: 21852264. 10.1093/jnci/djr284 21852264
141 Segnan N, Senore C, Andreoni B, . Randomized trial of different screening strategies for colorectal cancer: patient response and detection rates. J Natl Cancer Inst. 2005;97(5):347–57. PMID: 15741571. 10.1093/jnci/dji050 15741571
142 Segnan N, Senore C, Andreoni B, . Comparing attendance and detection rate of colonoscopy with sigmoidoscopy and FIT for colorectal cancer screening. Gastroenterology. 2007;132(7):2304–12. PMID: 17570205. 10.1053/j.gastro.2007.03.030 17570205
143 Shaukat A, Mongin SJ, Geisser MS, . Long-term mortality after screening for colorectal cancer. N Engl J Med. 2013;369(12):1106–14. PMID: 24047060. 10.1056/NEJMoa1300720 24047060
144 Stoop EM, de Haan MC, de Wijkerslooth TR, . Participation and yield of colonoscopy versus non-cathartic CT colonography in population-based screening for colorectal cancer: a randomised controlled trial. Lancet Oncol. 2012;13(1):55–64. PMID: 22088831. 10.1016/S1470-2045(11)70283-2 22088831
145 van Roon AH, Goede SL, van Ballegooijen M, . Random comparison of repeated faecal immunochemical testing at different intervals for population-based colorectal cancer screening. Gut. 2013;62(3):409–15. PMID: 22387523. 10.1136/gutjnl-2011-301583 22387523
146 van Rossum LG, van Rijn AF, Laheij RJ, . Random comparison of guaiac and immunochemical fecal occult blood tests for colorectal cancer in a screening population. Gastroenterology. 2008;135(1):82–90. PMID: 18482589. 10.1053/j.gastro.2008.03.040 18482589
147 Verne JE, Aubrey R, Love SB, . Population based randomised study of uptake and yield of screening by flexible sigmoidoscopy compared with screening by faecal occult blood testing. BMJ. 1998;317(7152):182–5. PMID: 9665902. 10.1136/bmj.317.7152.182 9665902
148 Zubero MB, Arana-Arri E, Pijoan JI, . Population-based colorectal cancer screening: comparison of two fecal occult blood test. Front Pharmacol. 2014;4:175. PMID: 24454288. 10.3389/fphar.2013.00175 24454288
149 Grobbee EJ, van der Vlugt M, van Vuuren AJ, . Diagnostic yield of one-time colonoscopy vs one-time flexible sigmoidoscopy vs multiple rounds of mailed fecal immunohistochemical tests in colorectal cancer screening. Clin Gastroenterol Hepatol. 2020;18(3):667–675.e1. PMID: 31419575. 10.1016/j.cgh.2019.08.015 31419575
150 Steele RJ, Carey FA, Stanners G, . Randomized controlled trial: flexible sigmoidoscopy as an adjunct to faecal occult blood testing in population screening. J Med Screen. 2020;27(2):59–67. PMID: 31690179. 10.1177/0969141319879955 31690179
151 Ahlquist DA, Sargent DJ, Loprinzi CL, . Stool DNA and occult blood testing for screen detection of colorectal neoplasia. Ann Intern Med. 2008;149(7):441–50. PMID: 18838724. 10.7326/0003-4819-149-7-200810070-00004 18838724
152 Allison J, Tekawa IS, Ransom LJ, . A comparison of fecal occult-blood tests for colorectal-cancer screening. N Engl J Med. 1996;334(3):155–9. PMID: 8531970. 10.1056/NEJM199601183340304 8531970
153 Allison JE, Sakoda LC, Levin TR, . Screening for colorectal neoplasms with new fecal occult blood tests: update on performance characteristics. J Natl Cancer Inst. 2007;99(19):1462–70. PMID: 17895475. 10.1093/jnci/djm150 17895475
154 Arana-Arri E, Idigoras I, Uranga B, . Population-based colorectal cancer screening programmes using a faecal immunochemical test: should faecal haemoglobin cut-offs differ by age and sex? BMC Cancer. 2017;17(1):577. PMID: 28851318. 10.1186/s12885-017-3555-3 28851318
155 Brenner H, Chen H. Fecal occult blood versus DNA testing: indirect comparison in a colorectal cancer screening population. Clin Epidemiol. 2017;9:377–84. PMID: 28761377. 10.2147/CLEP.S136565 28761377
156 Brenner H, Tao S. Superior diagnostic performance of faecal immunochemical tests for haemoglobin in a head-to-head comparison with guaiac based faecal occult blood test among 2235 participants of screening colonoscopy. Eur J Cancer. 2013;49(14):3049–54. PMID: 23706981. 10.1016/j.ejca.2013.04.023 23706981
157 Castiglione G, Visioli CB, Ciatto S, . Sensitivity of latex agglutination faecal occult blood test in the Florence District population-based colorectal cancer screening programme. Br J Cancer. 2007;96(11):1750–4. PMID: 17453007. 10.1038/sj.bjc.6603759 17453007
158 Chang LC, Shun CT, Hsu WF, . Fecal immunochemical test detects sessile serrated adenomas and polyps with a low level of sensitivity. Clin Gastroenterol Hepatol. 2017;15(6):872–9.e1. PMID: 27498176. 10.1016/j.cgh.2016.07.029 27498176
159 Chen CH, Wen CP, Tsai MK. Fecal immunochemical test for colorectal cancer from a prospective cohort with 513,283 individuals: providing detailed number needed to scope (NNS) before colonoscopy. Medicine (Baltimore). 2016;95(36):e4414. PMID: 27603337. 10.1097/MD.0000000000004414 27603337
160 Chen LS, Yen AM, Chiu SY, . Baseline faecal occult blood concentration as a predictor of incident colorectal neoplasia: longitudinal follow-up of a Taiwanese population-based colorectal cancer screening cohort. Lancet Oncol. 2011;12(6):551–8. PMID: 21592859. 10.1016/S1470-2045(11)70101-2 21592859
161 Chen SL, Hsu CY, Yen AM, . Demand for colonoscopy in colorectal cancer screening using a quantitative fecal immunochemical test and age/sex-specific thresholds for test positivity. Cancer Epidemiol Biomarkers Prev. 2018;27(6):704–9. PMID: 29593012. 10.1158/1055-9965.EPI-17-0387 29593012
162 Chen YY, Chen TH, Su MY, . Accuracy of immunochemical fecal occult blood test for detecting colorectal neoplasms in individuals undergoing health check-ups. Adv Dig Med. 2014;1(3):74–9.
163 Cheng TI, Wong JM, Hong CF, . Colorectal cancer screening in asymptomaic adults: comparison of colonoscopy, sigmoidoscopy and fecal occult blood tests. J Formos Med Assoc. 2002;101(10):685–90. PMID: 12517041.12517041
164 Chiu HM, Ching JY, Wu KC, . A risk-scoring system combined with a fecal immunochemical test is effective in screening high-risk subjects for early colonoscopy to detect advanced colorectal neoplasms. Gastroenterology. 2016;150(3):617–25.e3. PMID: 26627608. 10.1053/j.gastro.2015.11.042 26627608
165 Chiu HM, Lee YC, Tu CH, . Association between early stage colon neoplasms and false-negative results from the fecal immunochemical test. Clin Gastroenterol Hepatol. 2013;11(7):832–8. PMID: 23376002. 10.1016/j.cgh.2013.01.013 23376002
166 Cooper GS, Markowitz SD, Chen Z, . Performance of multitarget stool DNA testing in African American patients. Cancer. 2018;124(19):3876–80. PMID: 30193399. 10.1002/cncr.31660 30193399
167 de Wijkerslooth TR, Stoop EM, Bossuyt PM, . Immunochemical fecal occult blood testing is equally sensitive for proximal and distal advanced neoplasia. Am J Gastroenterol. 2012;107(10):1570–8. PMID: 22850431. 10.1038/ajg.2012.249 22850431
168 Deng L, Chang D, Foshaug RR, . Development and validation of a high-throughput mass spectrometry based urine metabolomic test for the detection of colonic adenomatous polyps. Metabolites. 2017;7(3):22. 10.3390/metabo7030032
169 Fletcher JG, Silva AC, Fidler JL, . Noncathartic CT colonography: image quality assessment and performance and in a screening cohort. Am J Roentgenol. 2013;201(4):787–94. PMID: 24059367. 10.2214/AJR.12.9225 24059367
170 Garcia M, Domenech X, Vidal C, . Interval cancers in a population-based screening program for colorectal cancer in catalonia, Spain. Gastroenterol Res Pract. 2015;2015:672410. PMID: 25802515. 10.1155/2015/672410 25802515
171 Gies A, Cuk K, Schrotz-King P, . Direct comparison of diagnostic performance of 9 quantitative fecal immunochemical tests for colorectal cancer screening. Gastroenterology. 2018;154(1):93–104. 10.1053/j.gastro.2017.09.018 28958859
172 Graser A, Stieber P, Nagel D, . Comparison of CT colonography, colonoscopy, sigmoidoscopy and faecal occult blood tests for the detection of advanced adenoma in an average risk population. Gut. 2009;58(2):241–8. PMID: 18852257. 10.1136/gut.2008.156448 18852257
173 Haug U, Grobbee EJ, Lansdorp-Vogelaar I, . Immunochemical faecal occult blood testing to screen for colorectal cancer: can the screening interval be extended? Gut. 2017;66(7):1262–7. PMID: 27006184. 10.1136/gutjnl-2015-310102 27006184
174 Hernandez V, Cubiella J, Gonzalez-Mao MC, . Fecal immunochemical test accuracy in average-risk colorectal cancer screening. World J Gastroenterol. 2014;20(4):1038–47. PMID: 24574776. 10.3748/wjg.v20.i4.1038 24574776
175 Imperiale TF, Ransohoff DF, Itzkowitz SH, . Multitarget stool DNA testing for colorectal-cancer screening. N Engl J Med. 2014;370(14):1287–97. PMID: 24645800. 10.1056/NEJMoa1311194 24645800
176 Itoh M, Takahashi K, Nishida H, . Estimation of the optimal cut off point in a new immunological faecal occult blood test in a corporate colorectal cancer screening programme. J Med Screen. 1996;3(2):66–71. PMID: 8849762. 10.1177/096914139600300204 8849762
177 Johnson CD, Chen MH, Toledano AY, . Accuracy of CT colonography for detection of large adenomas and cancers. N Engl J Med. 2008;359(12):1207–17. PMID: 18799557. 10.1056/NEJMoa0800996 18799557
178 Johnson CD, Fletcher JG, MacCarty RL, . Effect of slice thickness and primary 2D versus 3D virtual dissection on colorectal lesion detection at CT colonography in 452 asymptomatic adults. AJR Am J Roentgenol. 2007;189(3):672–80. PMID: 17715116. 10.1148/radiol.12102177 17715116
179 Juul JS, Andersen B, Laurberg S, . Differences in diagnostic activity in general practice and findings for individuals invited to the Danish screening programme for colorectal cancer: a population-based cohort study. Scand J Prim Health Care. 2018;36(3):281–90. PMID: 29929415. 10.1080/02813432.2018.1487378 29929415
180 Kim NH, Park JH, Park DI, . The fecal immunochemical test has high accuracy for detecting advanced colorectal neoplasia before age 50. Dig Liver Dis. 2017;49(5):557–61. PMID: 28065631. 10.1016/j.dld.2016.12.020 28065631
181 Kim YS, Kim N, Kim SH, . The efficacy of intravenous contrast-enhanced 16-raw multidetector CT colonography for detecting patients with colorectal polyps in an asymptomatic population in Korea. J Clin Gastroenterol. 2008;42(7):791–8. PMID: 18580500. 10.1097/MCG.0b013e31811edcb7 18580500
182 Launoy GD, Bertrand HJ, Berchi C, . Evaluation of an immunochemical fecal occult blood test with automated reading in screening for colorectal cancer in a general average-risk population. Int J Cancer. 2005;115(3):493–6. PMID: 15700317. 10.1002/ijc.20921 15700317
183 Lee YH, Hur M, Kim H, . Optimal cut-off concentration for a faecal immunochemical test for haemoglobin by Hemo Techt NS-Plus C15 system for the colorectal cancer screening. Clin Chem Lab Med. 2015;53(3):e69–71. PMID: 25153599. 10.1515/cclm-2014-0442 25153599
184 Lefere P, Silva C, Gryspeerdt S, . Teleradiology based CT colonography to screen a population group of a remote island; at average risk for colorectal cancer. Eur J Radiol. 2013;82(6):e262–e7. PMID: 23473734. 10.1016/j.ejrad.2013.02.010 23473734
185 Levi Z, Birkenfeld S, Vilkin A, . A higher detection rate for colorectal cancer and advanced adenomatous polyp for screening with immunochemical fecal occult blood test than guaiac fecal occult blood test, despite lower compliance rate. A prospective, controlled, feasibility study. Int J Cancer. 2011;128(10):2415–24. PMID: 20658527. 10.1002/ijc.25574 20658527
186 Levy BT, Bay C, Xu Y, . Test characteristics of faecal immunochemical tests (FIT) compared with optical colonoscopy. J Med Screen. 2014;21(3):133–43. PMID: 24958730. 10.1177/0969141314541109 24958730
187 Liles EG, Perrin N, Rosales AG, . Performance of a quantitative fecal immunochemical test for detecting advanced colorectal neoplasia: a prospective cohort study. BMC Cancer. 2018;18(1):509. PMID: 29720130. 10.1186/s12885-018-4402-x 29720130
188 Macari M, Bini EJ, Jacobs SL, . Colorectal polyps and cancers in asymptomatic average-risk patients: evaluation with CT colonography. Radiology. 2004;230(3):629–36. PMID: 14739311. 10.1148/radiol.2303021624 14739311
189 Mlakar DN, Bric TK, Skrjanec AL, . Interval cancers after negative immunochemical test compared to screen and non-responders’ detected cancers in Slovenian colorectal cancer screening programme. Radiol Oncol. 2018;52(4):413–21. PMID: 30511936. 10.2478/raon-2018-0025 30511936
190 Morikawa T, Kato J, Yamaji Y, . A comparison of the immunochemical fecal occult blood test and total colonoscopy in the asymptomatic population. Gastroenterology. 2005;129(2):422–8. PMID: 16083699. 10.1016/j.gastro.2005.05.056 16083699
191 Nakama H, Kamijo N, Abdul Fattah AS, . Validity of immunological faecal occult blood screening for colorectal cancer: a follow up study. J Med Screen. 1996;3(2):63–5. PMID: 8849761. 10.1177/096914139600300203 8849761
192 Nakama H, Yamamoto M, Kamijo N, . Colonoscopic evaluation of immunochemical fecal occult blood test for detection of colorectal neoplasia. Hepatogastroenterology. 1999;46(25):228–31. PMID: 10228797.10228797
193 Ng SC, Ching JY, Chan V, . Diagnostic accuracy of faecal immunochemical test for screening individuals with a family history of colorectal cancer. Aliment Pharmacol Ther. 2013;38(7):835–41. PMID: 23957462. 10.1111/apt.12446 23957462
194 Park DI, Ryu S, Kim YH, . Comparison of guaiac-based and quantitative immunochemical fecal occult blood testing in a population at average risk undergoing colorectal cancer screening. Am J Gastroenterol. 2010;105(9):2017–25. PMID: 20502450. 10.1038/ajg.2010.179 20502450
195 Pickhardt PJ, Choi JR, Hwang I, . Computed tomographic virtual colonoscopy to screen for colorectal neoplasia in asymptomatic adults. N Engl J Med. 2003;349(23):2191–200. PMID: 14657426. 10.1056/NEJMoa031618 14657426
196 Potter NT, Hurban P, White MN, . Validation of a real-time PCR-based qualitative assay for the detection of methylated SEPT9 DNA in human plasma. Clin Chem. 2014:60(9)1183–91. PMID: 24938752. 10.1373/clinchem.2013.221044 24938752
197 Redwood DG, Asay ED, Blake ID, . Stool DNA testing for screening detection of colorectal neoplasia in Alaska Native people. Mayo Clin Proc. 2016;91(1):61–70. PMID: 26520415. 10.1016/j.mayocp.2015.10.008 26520415
198 Rex DK, Adler SN, Aisenberg J, . Accuracy of capsule colonoscopy in detecting colorectal polyps in a screening population. Gastroenterology. 2015;148(5):948–57.e2. PMID: 25620668. 10.1053/j.gastro.2015.01.025 25620668
199 Selby K, Jensen CD, Lee JK, . Influence of varying quantitative fecal immunochemical test positivity thresholds on colorectal cancer detection: a community-based cohort study. Ann Intern Med. 2018;169(7):439–47. PMID: 30242328. 10.7326/M18-0244 30242328
200 Shapiro JA, Bobo JK, Church TR, . A comparison of fecal immunochemical and high-sensitivity guaiac tests for colorectal cancer screening. Am J Gastroenterol. 2017;112(11):1728–35. PMID: 29016558. 10.1038/ajg.2017.285 29016558
201 Sohn DK, Jeong SY, Choi HS, . Single immunochemical fecal occult blood test for detection of colorectal neoplasia. Cancer Res Treat. 2005;37(1):20–3. PMID: 19956505. 10.4143/crt.2005.37.1.20 19956505
202 Stegeman I, van Doorn SC, Mundt MW, . Participation, yield, and interval carcinomas in three rounds of biennial FIT-based colorectal cancer screening. Cancer Epidemiol. 2015;39(3):388–93. PMID: 25910865. 10.1016/j.canep.2015.03.012 25910865
203 van der Vlugt M, Grobbee EJ, Bossuyt PM, . Interval colorectal cancer incidence among subjects undergoing multiple rounds of fecal immunochemical testing. Gastroenterology. 2017;153(2):439–47.e2. PMID: 28483499. 10.1053/j.gastro.2017.05.004 28483499
204 Wong MC, Ching JY, Chan VC, . Diagnostic accuracy of a qualitative fecal immunochemical test varies with location of neoplasia but not number of specimens. Clin Gastroenterol Hepatol. 2015;13(8):1472–9. PMID: 25724708. 10.1016/j.cgh.2015.02.021 25724708
205 Zalis ME, Blake MA, Cai W, . Diagnostic accuracy of laxative-free computed tomographic colonography for detection of adenomatous polyps in asymptomatic adults: a prospective evaluation. Ann Intern Med. 2012;156(10):692–702. PMID: 22586008. 10.7326/0003-4819-156-10-201205150-00005 22586008
206 Ribbing Wilen H, Blom J, Hoijer J, . Fecal immunochemical test in cancer screening-colonoscopy outcome in FIT positives and negatives. Scand J Gastroenterol. 2019;54(3):303–10. PMID: 30907196. 10.1080/00365521.2019.1585569 30907196
207 Voska M, Zavoral M, Grega T, . Accuracy of colon capsule endoscopy for colorectal neoplasia detection in individuals referred for a screening colonoscopy. Gastroenterol Res Pract. 2019;2019:5975438. PMID: 31565052. 10.1155/2019/5975438 31565052
208 Toes-Zoutendijk E, Kooyker AI, Dekker E, . Incidence of interval colorectal cancer after negative results from first-round fecal immunochemical screening tests, by cutoff value and participant sex and age. Clin Gastroenterol Hepatol. 2020;18(7):1493–1500. PMID: 31442598. 10.1016/j.cgh.2019.08.021 31442598
209 Bosch LJ, Melotte V, Mongera S, . Multitarget stool DNA test performance in an average-risk colorectal cancer screening population. Am J Gastroenterol. 2019;114(12):1909–18. PMID: 31764091. 10.14309/ajg.0000000000000445 31764091
210 Adeyemo A, Bannazadeh M, Riggs T, . Does sedation type affect colonoscopy perforation rates? Dis Colon Rectum. 2014;57(1):110–4. PMID: 24316954. 10.1097/DCR.0000000000000002 24316954
211 An S, Lee KH, Kim YH, . Screening CT colonography in an asymptomatic average-risk Asian population: a 2-year experience in a single institution. AJR Am J Roentgenol. 2008;191(3):W100–6. PMID: 18716076. 10.2214/AJR.07.3367 18716076
212 Arora G, Mannalithara A, Singh G, . Risk of perforation from a colonoscopy in adults: a large population-based study. Gastrointest Endosc. 2009;69(3:Pt 2):654–64. PMID: 19251006. 10.1016/j.gie.2008.09.008 19251006
213 Atkin WS, Hart A, Edwards R, . Uptake, yield of neoplasia, and adverse effects of flexible sigmoidoscopy screening. Gut. 1998;42(4):560–5. PMID: 9616321. 10.1136/gut.42.4.560 9616321
214 Bair D, Pham J, Seaton MB, . The quality of screening colonoscopies in an office-based endoscopy clinic. Can J Gastroenterol. 2009;23(1):41–7. PMID: 19172208. 10.1155/2009/831029 19172208
215 Berhane C, Denning D. Incidental finding of colorectal cancer in screening colonoscopy and its cost effectiveness. Am Surg. 2009;75(8):699–703. PMID: 19725293. 10.1155/2009/831029 19725293
216 Bielawska B, Day AG, Lieberman DA, . Risk factors for early colonoscopic perforation include non-gastroenterologist endoscopists: a multivariable analysis. Clin Gastroenterol Hepatol. 2014;12(1):85–92. PMID: 23891916. 10.1016/j.cgh.2013.06.030 23891916
217 Bielawska B, Hookey LC, Sutradhar R, . Anesthesia assistance in outpatient colonoscopy and risk of aspiration pneumonia, bowel perforation, and splenic injury. Gastroenterology. 2018;154(1):77–85.e3. PMID: 28865733. 10.1053/j.gastro.2017.08.043 28865733
218 Binefa G, Garcia M, Mila N, . Colorectal cancer screening programme in Spain: results of key performance indicators after five rounds (2000–2012). Sci Rep. 2016;6:19532. PMID: 26787510. 10.1038/srep19532 26787510
219 Blotiere PO, Weill A, Ricordeau P, . Perforations and haemorrhages after colonoscopy in 2010: a study based on comprehensive French health insurance data (SNIIRAM). Clin Res Hepatol Gastroenterol. 2014;38(1):112–7. PMID: 24268997. 10.1016/j.clinre.2013.10.005 24268997
220 Bokemeyer B, Bock H, Huppe D, . Screening colonoscopy for colorectal cancer prevention: results from a German online registry on 269000 cases. Eur J Gastroenterol Hepatol. 2009;21(6):650–5. PMID: 19445041. 10.1097/MEG.0b013e32830b8acf 19445041
221 Bretthauer M, Kaminski MF, Loberg M, . Population-based colonoscopy screening for colorectal cancer: a randomized clinical trial. JAMA Intern Med. 2016;176(7):894–902. PMID: 27214731. 10.1001/jamainternmed.2016.0960 27214731
222 Cash BD, Riddle MS, Bhattacharya I, . CT colonography of a Medicare-aged population: outcomes observed in an analysis of more than 1400 patients. AJR Am J Roentgenol. 2012;199(1):W27–34. PMID: 22733929. 10.2214/AJR.11.7729 22733929
223 Castro G, Azrak MF, Seeff LC, . Outpatient colonoscopy complications in the CDC’s Colorectal Cancer Screening Demonstration Program: a prospective analysis. Cancer. 2013;119(Suppl 15)2849–54. PMID: 23868479. 10.1002/cncr.28159 23868479
224 Chin M, Mendelson R, Edwards J, . Computed tomographic colonography: prevalence, nature, and clinical significance of extracolonic findings in a community screening program. Am J Gastroenterol. 2005;100(12):2771–6. PMID: 16393234. 10.1111/j.1572-0241.2005.00337.x 16393234
225 Chukmaitov A, Bradley CJ, Dahman B, . Association of polypectomy techniques, endoscopist volume, and facility type with colonoscopy complications. Gastrointest Endosc. 2013;77(3):436–46. PMID: 23290773.23290773
226 Chukmaitov A, Siangphoe U, Dahman B, . Patient comorbidity and serious adverse events after outpatient colonoscopy: population-based study from three states, 2006 to 2009. Dis Colon Rectum. 2016;59(7):677–87. PMID: 27270521. 10.1097/DCR.0000000000000603 27270521
227 Cooper GS, Kou TD, Rex DK. Complications following colonoscopy with anesthesia assistance: a population-based analysis. JAMA Intern Med. 2013;173(7):551–6. PMID: 23478904. 10.1001/jamainternmed.2013.2908 23478904
228 Cotterill M, Gasparelli R, Kirby E. Colorectal cancer detection in a rural community. Development of a colonoscopy screening program. Can Fam Physician. 2005;51(9):1224–8. PMID: 16190175.16190175
229 Crispin A, Birkner B, Munte A, . Process quality and incidence of acute complications in a series of more than 230,000 outpatient colonoscopies. Endoscopy. 2009;41(12):1018–25. PMID: 19856246. 10.1055/s-0029-1215214 19856246
230 Dancourt V, Lejeune C, Lepage C, . Immunochemical faecal occult blood tests are superior to guaiac-based tests for the detection of colorectal neoplasms. Eur J Cancer. 2008;44(15):2254–8. PMID: 18760592.18760592
231 Derbyshire E, Hungin P, Nickerson C, . Colonoscopic perforations in the English National Health Service Bowel Cancer Screening Programme. Endoscopy. 2018;50(9):861–70. PMID: 29590669. 10.1055/a-0584-7138 29590669
232 Dominitz JA, Baldwin LM, Green P, . Regional variation in anesthesia assistance during outpatient colonoscopy is not associated with differences in polyp detection or complication rates. Gastroenterology. 2013;144(2):298–306. PMID: 23103615.23103615
233 Durbin JM, Stroup SP, Altamar HO, . Genitourinary abnormalities in an asymptomatic screening population: findings on virtual colonoscopy. Clin Nephrol. 2012;77(3):204–10. PMID: 22377251.22377251
234 Edwards JT, Mendelson RM, Fritschi L, . Colorectal neoplasia screening with CT colonography in average-risk asymptomatic subjects: community-based study. Radiology. 2004:230(2):459–64. PMID: 14688402.14688402
235 Ferlitsch M, Reinhart K, Pramhas S, . Sex-specific prevalence of adenomas, advanced adenomas, and colorectal cancer in individuals undergoing screening colonoscopy. JAMA. 2011;306(12):1352–8. PMID: 21954479.21954479
236 Flicker MS, Tsoukas AT, Hazra A, . Economic impact of extracolonic findings at computed tomographic colonography. J Comput Assist Tomogr. 2008;32(4):497–503. PMID: 18664832.18664832
237 Forsberg A, Hammar U, Ekbom A, . A register-based study: adverse events in colonoscopies performed in Sweden 2001–2013. Scand J Gastroenterol. 2017;52(9):1042–7. PMID: 28562115. 10.1080/00365521.2017.1334812 28562115
238 Ginnerup PB, Rosenkilde M, Christiansen TE, . Extracolonic findings at computed tomography colonography are a challenge. Gut. 2003;52(12):1744–7. PMID: 14633954.14633954
239 Gluecker TM, Johnson CD, Wilson LA, . Extracolonic findings at CT colonography: evaluation of prevalence and cost in a screening population. Gastroenterology. 2003;124(4):911–6. PMID: 12671887.12671887
240 Grossberg LB, Vodonos A, Papamichael K, . Predictors of post-colonoscopy emergency department use. Gastrointest Endosc. 2018;87(2):517–25.e6. PMID: 28859952. 10.1016/j.gie.2017.08.019 28859952
241 Hamdani U, Naeem R, Haider F, . Risk factors for colonoscopic perforation: a population-based study of 80118 cases. World J Gastroenterol. 2013;19(23):3596–601. PMID: 23801860.23801860
242 Hara AK, Johnson CD, MacCarty RL, . Incidental extracolonic findings at CT colonography. Radiology. 2000;215(2):353–7. PMID: 10796907.10796907
243 Ho JM, Gruneir A, Fischer HD, . Serious events in older Ontario residents receiving bowel preparations for outpatient colonoscopy with various comorbidity profiles: a descriptive, population-based study. Can J Gastroenterol. 2012;26(7):436–40. PMID: 22803018.22803018
244 Hoff G, de Lange T, Bretthauer M, . Patient-reported adverse events after colonoscopy in Norway. Endoscopy. 2017;49(8):745–53. PMID: 28445903. 10.1055/s-0043-105265 28445903
245 Hoff G, Thiis-Evensen E, Grotmol T, . Do undesirable effects of screening affect all-cause mortality in flexible sigmoidoscopy programmes? Experience from the Telemark Polyp Study 1983–1996. Eur J Cancer Prev. 2001;10(2):131–7. PMID: 11330453.11330453
246 Hsieh TK, Hung L, Kang FC, . Anesthesia does not increase the rate of bowel perforation during colonoscopy: a retrospective study. Acta Anaesthesiol Taiwan. 2009;47(4):162–6. PMID: 20015815.20015815
247 Iafrate F, Iussich G, Correale L, . Adverse events of computed tomography colonography: an Italian National Survey. Dig Liver Dis. 2013;45(8):645–50. PMID: 23643567.23643567
248 Ibanez J, Vanaclocha-Espi M, Perez-Sanz E, . Severe complications in colorectal cancer screening colonoscopies in the Valencian community. Gastroenterol Hepatol. 2018;41(9):553–61. PMID: 30055861. 10.1016/j.gastrohep.2018.06.007 30055861
249 Jain A, Falzarano J, Jain A, . Outcome of 5,000 flexible sigmoidoscopies done by nurse endoscopists for colorectal screening in asymptomatic patients. Hawaii Med J. 2002;61(6):118–20. PMID: 12148407.12148407
250 Johnson DA, Lieberman D, Inadomi JM, . Increased post-procedural non-gastrointestinal adverse events after outpatient colonoscopy in high-risk patients. Clin Gastroenterol Hepatol. 2017;15(6):883–91.e9. PMID: 28017846. 10.1016/j.cgh.2016.12.015 28017846
251 Kamath AS, Iqbal CW, Sarr MG, . Colonoscopic splenic injuries: incidence and management. J Gastrointest Surg. 2009;13(12):2136–40. PMID: 19830501.19830501
252 Kang HY, Kang HW, Kim SG, . Incidence and management of colonoscopic perforations in Korea. Digestion. 2008;78(4):218–23. PMID: 19142003.19142003
253 Kim DH, Pickhardt PJ, Hanson ME, . CT colonography: performance and program outcome measures in an older screening population. Radiology. 2010;254(2):493–500. PMID: 20093521.20093521
254 Kim DH, Pickhardt PJ, Taylor AJ, . CT colonography versus colonoscopy for the detection of advanced neoplasia. N Engl J Med. 2007;357(14):1403–12. PMID: 17914041.17914041
255 Kim JS, Kim BW, Kim JI, . Endoscopic clip closure versus surgery for the treatment of iatrogenic colon perforations developed during diagnostic colonoscopy: a review of 115,285 patients. Surg Endosc. 2013;27(2):501–4. PMID: 22773239.22773239
256 Kim YS, Kim N, Kim SY, . Extracolonic findings in an asymptomatic screening population undergoing intravenous contrast-enhanced computed tomography colonography. J Gastroenterol Hepatol. 2008;23(7 Pt 2):e49–57. PMID: 17645481.17645481
257 Ko CW, Riffle S, Michaels L, . Serious complications within 30 days of screening and surveillance colonoscopy are uncommon. Clin Gastroenterol Hepatol. 2010;8(2):166–73. PMID: 19850154.19850154
258 Ko CW, Riffle S, Shapiro JA, . Incidence of minor complications and time lost from normal activities after screening or surveillance colonoscopy. Gastrointest Endosc. 2007;65(4):648–56. PMID: 17173914.17173914
259 Korman LY, Overholt BF, Box T, . Perforation during colonoscopy in endoscopic ambulatory surgical centers. Gastrointest Endosc. 2003;58(4):554–7. PMID: 14520289.14520289
260 Kubisch CH, Crispin A, Mansmann U, . Screening for colorectal cancer is associated with lower disease stage: a population-based study. Clin Gastroenterol Hepatol. 2016;14(11):1612–8.e3. PMID: 27085763. 10.1016/j.cgh.2016.04.008 27085763
261 Laanani M, Coste J, Blotiere PO, . Patient, procedure, and endoscopist risk factors for perforation, bleeding, and splenic injury after colonoscopies. Clin Gastroenterol Hepatol. 2019;17(4):719–727.e13. PMID: 30099110. 10.1016/j.cgh.2018.08.005 30099110
262 Larson ME, Pickhardt PJ. CT colonography screening in extracolonic cancer survivors: impact on rates of colorectal and extracolonic findings by cancer type. Abdom Radiol. 2019;44(1):31–40. PMID: 30066170. 10.1007/s00261-018-1708-8 30066170
263 Layton JB, Klemmer PJ, Christiansen CF, . Sodium phosphate does not increase risk for acute kidney injury after routine colonoscopy, compared with polyethylene glycol. Clin Gastroenterol Hepatol. 2014;12(9):1514–21. PMID: 24486407. 10.1016/j.cgh.2014.01.034 24486407
264 Levin TR, Conell C, Shapiro JA, . Complications of screening flexible sigmoidoscopy. Gastroenterology. 2002;123(6):1786–92. PMID: 12454834.12454834
265 Levin TR, Zhao W, Conell C, . Complications of colonoscopy in an integrated health care delivery system. Ann Intern Med. 2006;145(12):880–6. PMID: 17179057.17179057
266 Loffeld RJ, Engel A, Dekkers PE. Incidence and causes of colonoscopic perforations: a single-center case series. Endoscopy. 2011;43(3):240–2. PMID: 21165826.21165826
267 Lorenzo-Zuniga V, Moreno de Vega, Domenech E, . Endoscopist experience as a risk factor for colonoscopic complications. Colorectal Dis. 2010;12(10 Online):e273–7. PMID: 19930145.19930145
268 Macari M, Nevsky G, Bonavita J, . CT colonography in senior versus nonsenior patients: extracolonic findings, recommendations for additional imaging, and polyp prevalence. Radiology. 2011;259(3):767–74. PMID: 21467252.21467252
269 Mansmann U, Crispin A, Henschel V, . Epidemiology and quality control of 245 000 outpatient colonoscopies. Dtsch Arztebl Int. 2008;105(24):434–40. PMID: 19626186.19626186
270 Mikkelsen EM, Thomsen MK, Tybjerg J, . Colonoscopy-related complications in a nationwide immunochemical fecal occult blood test-based colorectal cancer screening program. Clin Epidemiol. 2018;10:1649–55. PMID: 30519113. 10.2147/CLEP.S181204 30519113
271 Moreno CC, Fibus TF, Krupinski EA, . Addressing racial disparity in colorectal cancer screening with CT colonography: experience in an African-American cohort. Clin Colorectal Cancer. 2018;17(2):e363–e7. PMID: 29572136. 10.1016/j.clcc.2018.02.007 29572136
272 Multicentre Australian Colorectal-neoplasia Screening (MACS) Group. A comparison of colorectal neoplasia screening tests: a multicentre community-based study of the impact of consumer choice. Med J Aust. 2006;184(11):546–50. PMID: 16768659.16768659
273 Nelson DB, McQuaid KR, Bond JH, . Procedural success and complications of large-scale screening colonoscopy. Gastrointest Endosc. 2002;55(3):307–14. PMID: 11868001.11868001
274 O’Connor SD, Pickhardt PJ, Kim DH, . Incidental finding of renal masses at unenhanced CT: prevalence and analysis of features for guiding management. AJR Am J Roentgenol. 2011;197(1):139–45. PMID: 21701022.21701022
275 Parente F, Boemo C, Ardizzoiae A, . Outcomes and cost evaluation of the first two rounds of a colorectal cancer screening program based on immunochemical fecal occult blood test in northern Italy. Endoscopy. 2013;45(1):27–34. PMID: 23254404.23254404
276 Pickhardt PJ. Incidence of colonic perforation at CT colonography: review of existing data and implications for screening of asymptomatic adults. Radiology. 2006;239(2):313–6. PMID: 16641348.16641348
277 Pickhardt PJ, Boyce CJ, Kim DH, . Should small sliding hiatal hernias be reported at CT colonography? AJR Am J Roentgenol. 2011;196(4):W400–4. PMID: 21427303. 10.2214/AJR.10.5392 21427303
278 Pickhardt PJ, Hanson ME, Vanness DJ, . Unsuspected extracolonic findings at screening CT colonography: clinical and economic impact. Radiology. 2008;249(1):151–9. PMID: 18796673. 10.1148/radiol.2491072148 18796673
279 Pickhardt PJ, Kim DH, Meiners RJ, . Colorectal and extracolonic cancers detected at screening CT colonography in 10,286 asymptomatic adults. Radiology. 2010;255(1):83–8. PMID: 20308446.20308446
280 Pickhardt PJ, Kim DH, Taylor AJ, . Extracolonic tumors of the gastrointestinal tract detected incidentally at screening CT colonography. Dis Colon Rectum. 2007;50(1):56–63. PMID: 17115333.17115333
281 Polter DE. Risk of colon perforation during colonoscopy at Baylor University Medical Center. Baylor Univ Med Cent Proc. 2015;28(1):3–6. PMID: 25552784.25552784
282 Pooler BD, Kim DH, Pickhardt PJ. Potentially important extracolonic findings at screening CT colonography: incidence and outcomes data from a clinical screening program. AJR Am J Roentgenol. 2016;206(2):313–8. PMID: 26491809. 10.2214/AJR.15.15193 26491809
283 Pox CP, Altenhofen L, Brenner H, . Efficacy of a nationwide screening colonoscopy program for colorectal cancer. Gastroenterology. 2012;142(7):1460–7. PMID: 22446606.22446606
284 Quallick MR, Brown WR. Rectal perforation during colonoscopic retroflexion: a large, prospective experience in an academic center. Gastrointest Endosc. 2009;69(4):960–3. PMID: 19327487.19327487
285 Rabeneck L, Paszat LF, Hilsden RJ, . Bleeding and perforation after outpatient colonoscopy and their risk factors in usual clinical practice. Gastroenterology. 2008;135(6):1899–906. PMID: 18938166.18938166
286 Rathgaber SW, Wick TM. Colonoscopy completion and complication rates in a community gastroenterology practice. Gastrointest Endosc. 2006;64(4):556–62. PMID: 16996349.16996349
287 Rim JH, Youk T, Kang JG, . Fecal occult blood test results of the national colorectal cancer screening program in South Korea (2006–2013). Sci Rep. 2017;7(1):2804. PMID: 28584248. 10.1038/s41598-017-03134-9 28584248
288 Rutter CM, Johnson E, Miglioretti DL, . Adverse events after screening and follow-up colonoscopy. Cancer Causes Control. 2012;23(2):289–96. PMID: 22105578.22105578
289 Sagawa T, Kakizaki S, Iizuka H, . Analysis of colonoscopic perforations at a local clinic and a tertiary hospital. World J Gastroenterol. 2012;18(35):4898–904. PMID: 23002362.23002362
290 Saraste D, Martling A, Nilsson PJ, . Complications after colonoscopy and surgery in a population-based colorectal cancer screening programme. J Med Screen. 2016;23(3):135–40. PMID: 26940962. 10.1177/0969141315625701 26940962
291 Sieg A, Hachmoeller-Eisenbach U, Eisenbach T. Prospective evaluation of complications in outpatient GI endoscopy: a survey among German gastroenterologists. Gastrointest Endosc. 2001;53(6):620–7. PMID: 11323588.11323588
292 Singh H, Penfold RB, DeCoster C, . Colonoscopy and its complications across a Canadian regional health authority. Gastrointest Endosc. 2009;69(3 Pt 2):665–71. PMID: 19251007.19251007
293 Sosna J, Blachar A, Amitai M, . Colonic perforation at CT colonography: assessment of risk in a multicenter large cohort. Radiology. 2006;239(2):457–63. PMID: 16543590.16543590
294 Stock C, Ihle P, Sieg A, . Adverse events requiring hospitalization within 30 days after outpatient screening and nonscreening colonoscopies. Gastrointest Endosc. 2013;77(3):419–29. PMID: 23410698.23410698
295 Strul H, Kariv R, Leshno M, . The prevalence rate and anatomic location of colorectal adenoma and cancer detected by colonoscopy in average-risk individuals aged 40–80 years. Am J Gastroenterol. 2006;101(2):255–62. PMID: 16454827.16454827
296 Suissa A, Bentur OS, Lachter J, . Outcome and complications of colonoscopy: a prospective multicenter study in northern Israel. Diagn Ther Endosc. 2012;2012:612542. PMID: 22778539.22778539
297 Tam MS, Abbas MA. Perforation following colorectal endoscopy: what happens beyond the endoscopy suite? Perm J. 2013;17(2):17–21. PMID: 23704838.23704838
298 Taya M, McHargue C, Ricci ZJ, . Comparison of extracolonic findings and clinical outcomes in a screening and diagnostic CT colonography population. Abdom Radiol (NY). 2019;44(2):429–437. PMID: 30209542. 10.1007/s00261-018-1753-3 30209542
299 Veerappan GR, Ally MR, Choi JH, . Extracolonic findings on CT colonography increases yield of colorectal cancer screening. AJR Am J Roentgenol. 2010;195(3):677–86. PMID: 20729446.20729446
300 Viiala CH, Olynyk JK. Outcomes after 10 years of a community-based flexible sigmoidoscopy screening program for colorectal carcinoma. Med J Australia. 2007;187(5):274–7. PMID: 17767431.17767431
301 Wallace MB, Kemp JA, Meyer F, . Screening for colorectal cancer with flexible sigmoidoscopy by nonphysician endoscopists. Am J Med. 1999;107(3):214–8. PMID: 10492313.10492313
302 Wang L, Mannalithara A, Singh G, . Low rates of gastrointestinal and non-gastrointestinal complications for screening or surveillance colonoscopies in a population-based study. Gastroenterology. 2018;154(3):540–55.e8. PMID: 29031502. 10.1053/j.gastro.2017.10.006 29031502
303 Wang P, Xu T, Ngamruengphong S, . Rates of infection after colonoscopy and osophagogastroduodenoscopy in ambulatory surgery centres in the USA. Gut. 2018;67(9):1626–36. PMID: 29777042. 10.1136/gutjnl-2017-315308 29777042
304 Warren JL, Klabunde CN, Mariotto AB, . Adverse events after outpatient colonoscopy in the Medicare population. Ann Intern Med. 2009;150(12):849–57. PMID: 19528563.19528563
305 Xirasagar S, Hurley TG, Sros L, . Quality and safety of screening colonoscopies performed by primary care physicians with standby specialist support. Med Care. 2010;48(8):703–9. PMID: 20613663.20613663
306 Zafar HM, Harhay MO, Yang J, . Adverse events following computed tomographic colonography compared to optical colonoscopy in the elderly. Prev Med Rep. 2014;1:3–8. PMID: 25530940.25530940
307 Zwink N, Holleczek B, Stegmaier C, . Complication rates in colonoscopy screening for cancer. Dtsch Arztebl Int. 2017;114(18):321–7. PMID: 28587708. 10.3238/arztebl.2017.0321 28587708
308 Basson MD, Persinger D, Newman WP. Association of colonoscopy with risk of appendicitis. JAMA Surgery. 2018;153(1):90–1. PMID: 28979984. 10.1001/jamasurg.2017.3790 28979984
309 Kobiela J, Spychalski P, Wieszczy P, . Mortality and rate of hospitalization in a colonoscopy screening program from a randomized health services study. Clin Gastroenterol Hepatol. 2020;18(7):1501–1508.e3. PMID: 31525515. 10.1016/j.cgh.2019.09.010 31525515
310 Grossberg LB, Papamichael K, Leffler DA, . Patients over age 75 are at increased risk of emergency department visit and hospitalization following colonoscopy. Dig Dis Sci. 2020;65(7):1964–1970. PMID: 31784850. 10.1007/s10620-019-05962-3 31784850
311 Penz D, Ferlitsch A, Waldmann E, . Impact of adenoma detection rate on detection of advanced adenomas and endoscopic adverse events in a study of over 200,000 screening colonoscopies. Gastrointest Endosc. 2020;91(1):135–141. PMID: 31499041. 10.1016/j.gie.2019.08.038 31499041
312 Chukmaitov A, Dahman B, Bradley CJ. Outpatient facility volume, facility type, and the risk of serious colonoscopy-related adverse events in patients with comorbid conditions: a population-based study. Int J Colorectal Dis. 2019;34(7):1203–10. PMID: 31093737. 10.1007/s00384-019-03304-3 31093737
313 Thulin T, Hammar U, Ekbom A, . Perforations and bleeding in a population-based cohort of all registered colonoscopies in Sweden from 2001 to 2013. United European Gastroenterol J. 2019;7(1):130–7. PMID: 30788125. 10.1177/2050640618809782 30788125
314 Segnan N, Senore C, Andreoni B, . Baseline findings of the Italian multicenter randomized controlled trial of “once-only sigmoidoscopy”--SCORE. J Natl Cancer Inst. 2002;94(23):1763–72. PMID: 12464648. 10.1093/jnci/94.23.1763 12464648
315 Atkin WS. Single flexible sigmoidoscopy screening to prevent colorectal cancer: baseline findings of a UK multicentre randomised trial. Lancet. 2002;359(9314):1291–300. PMID: 11965274. 10.1016/S0140-6736(02)08268-5 11965274
316 Mandel JS, Bond JH, Church TR, . Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med. 1993;328(19):1365–71. PMID: 8474513. 10.1056/NEJM199305133281901 8474513
317 Weissfeld JL, Schoen RE, Pinsky PF, . Flexible sigmoidoscopy in the PLCO cancer screening trial: results from the baseline screening examination of a randomized trial. J Natl Cancer Inst. 2005;97(13):989–97. PMID: 15998952. 10.1093/jnci/dji175 15998952
318 van Roon AH, Wilschut JA, Hol L, . Diagnostic yield improves with collection of 2 samples in fecal immunochemical test screening without affecting attendance. Clin Gastroenterol Hepatol. 2011;9(4):333–9. PMID: 21185397. 10.1016/j.cgh.2010.12.012 21185397
319 Thomas W, White CM, Mah J, . Longitudinal compliance with annual screening for fecal occult blood. Minnesota Colon Cancer Control Study. Am J Epidemiol. 1995;142(2):176–82. PMID: 7598117. 10.1093/oxfordjournals.aje.a117616 7598117
320 Parra-Blanco A, Nicolas-Perez D, Gimeno-Garcia A, . The timing of bowel preparation before colonoscopy determines the quality of cleansing, and is a significant factor contributing to the detection of flat lesions: a randomized study. World J Gastroenterol. 2006;12(38):6161–6. PMID: 17036388. 10.3748/wjg.v12.i38.6161 17036388
321 Mandel JS, Church TR, Bond JH, . The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. 2000;343(22):1603–7. PMID: 11096167. 10.1056/NEJM200011303432203 11096167
322 Malila N, Oivanen T, Malminiemi O, . Test, episode, and programme sensitivities of screening for colorectal cancer as a public health policy in Finland: experimental design. BMJ. 2008;337:a2261. PMID: 19022840. 10.1136/bmj.a2261 19022840
323 Kewenter J, Brevinge H, Engaras B, . Results of screening, rescreening, and follow-up in a prospective randomized study for detection of colorectal cancer by fecal occult blood testing. Results for 68,308 subjects. Scand J Gastroenterol. 1994;29(5):468–73. PMID: 8036464. 10.3109/00365529409096840 8036464
324 Hardcastle JD, Chamberlain JO, Robinson MH, . Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348(9040):1472–7. PMID: 8942775. 10.1016/S0140-6736(96)03386-7 8942775
325 Faivre J, Dancourt V, Manfredi S, . Positivity rates and performances of immunochemical faecal occult blood tests at different cut-off levels within a colorectal cancer screening programme. Dig Liver Dis. 2012;44(8):700–4. PMID: 22542582. 10.1016/j.dld.2012.03.015 22542582
326 Denters MJ, Deutekom M, Fockens P, . Implementation of population screening for colorectal cancer by repeated fecal occult blood test in the Netherlands. BMC Gastroenterol. 2009;9:28. PMID: 19393087. 10.1186/1471-230X-9-28 19393087
327 Miles A, Wardle J, McCaffery K, . The effects of colorectal cancer screening on health attitudes and practices. Cancer Epidemiol Biomarkers Prev. 2003;12(7):651–5. PMID: 12869406.12869406
328 Atkin WS, Edwards R, Kralj-Hans I, . Once-only flexible sigmoidoscopy screening in prevention of colorectal cancer: a multicentre randomised controlled trial. Lancet. 2010;375(9726):1624–33. PMID: 20430429. 10.1016/S0140-6736(10)60551-X 20430429
329 Koskenvuo L, Malila N, Pitkaniemi J, . Sex differences in faecal occult blood test screening for colorectal cancer. Br J Surg. 2019;106(4):436–447. PMID: 30460999. 10.1002/bjs.11011 30460999
330 Kapidzic A, van Roon AH, van Leerdam ME, . Attendance and diagnostic yield of repeated two-sample faecal immunochemical test screening for colorectal cancer. Gut. 2017;66(1):118–23. PMID: 26370109. 10.1136/gutjnl-2014-308957 26370109
331 Doroudi M, Schoen RE, Pinsky PF. Early detection versus primary prevention in the PLCO flexible sigmoidoscopy screening trial: Which has the greatest impact on mortality? Cancer. 2017;123(24):4815–22. PMID: 28976536. 10.1002/cncr.31034 28976536
332 Schoen RE, Pinsky PF, Weissfeld JL, . Colorectal-cancer incidence and mortality with screening flexible sigmoidoscopy. N Engl J Med. 2012;366(25):2345–57. PMID: 22612596. 10.1016/S2468-1253(18)30358-3 22612596
333 Malila N, Palva T, Malminiemi O, . Coverage and performance of colorectal cancer screening with the faecal occult blood test in Finland. J Med Screen. 2011;18(1):18–23. PMID: 21536812 10.1258/jms.2010.010036 21536812
334 Senore C, Correale L, Regge D, . Flexible sigmoidoscopy and CT colonography screening: patients’ experience with and factors for undergoing screening-insight from the Proteus Colon Trial. Radiology. 2018;286(3):873–83. PMID: 29040021. 10.1148/radiol.2017170228 29040021
335 Castells A, Quintero E. Programmatic screening for colorectal cancer: the COLONPREV study. Dig Dis Sci. 2015;60(3):672–80. PMID: 25492501. 10.1007/s10620-014-3446-2 25492501
336 Schoen RE, Razzak A, Yu KJ, . Incidence and mortality of colorectal cancer in individuals with a family history of colorectal cancer. Gastroenterology. 2015;149(6):1438–45.e1. PMID: 26255045. 10.1053/j.gastro.2015.07.055 26255045
337 Holme O, Loberg M, Kalager M, . Effect of flexible sigmoidoscopy screening on colorectal cancer incidence and mortality: a randomized clinical trial. Ann Intern Med. 2014;312(6):606–15. PMID: 29710125.29710125
338 Holme O, Bretthauer M, Eide TJ, . Long-term risk of colorectal cancer in individuals with serrated polyps. Gut. 2015;64(6):929–36. PMID: 25399542. 10.1136/gutjnl-2014-307793 25399542
339 Jodal HC, Loberg M, Holme O, . Mortality from postscreening (interval) colorectal cancers is comparable to that from cancer in unscreened patients-a randomized sigmoidoscopy trial. Gastroenterology. 2018;155(6):1787–94.e3. PMID: 30165051. 10.1053/j.gastro.2018.08.035 30165051
340 Laiyemo AO, Doubeni C, Pinsky PF, . Occurrence of distal colorectal neoplasia among whites and blacks following negative flexible sigmoidoscopy: an analysis of PLCO trial. J Gen Intern Med. 2015;30(10):1447–53. PMID: 25835747. 10.1007/s11606-015-3297-3 25835747
341 Senore C, Ederle A, Fantin A, . Acceptability and side-effects of colonoscopy and sigmoidoscopy in a screening setting. J Med Screen. 2011;18(3):128–34. PMID: 22045821. 10.1258/jms.2011.010135 22045821
342 Gondal G, Grotmol T, Hofstad B, . The Norwegian Colorectal Cancer Prevention (NORCCAP) screening study: baseline findings and implementations for clinical work-up in age groups 50–64 years. Scand J Gastroenterol. 2003;38(6):635–42. PMID: 12825872. 10.1080/00365520310003002 12825872
343 Hoff G, Grotmol T, Skovlund E, . Risk of colorectal cancer seven years after flexible sigmoidoscopy screening: randomised controlled trial. BMJ. 2009;338:b1846. PMID: 19483252. 10.1136/bmj.b1846 19483252
344 Kewenter J, Brevinge H. Endoscopic and surgical complications of work-up in screening for colorectal cancer. Dis Colon Rectum. 1996;39(6):676–80. PMID: 8646956. 10.1007/bf02056949 8646956
345 Dube C, Tinmouth J. Number of samples in faecal immunochemical test screening: more might be less. Lancet Gastroenterol Hepatol. 2019;4(8):577–8. PMID: 31196733. 10.1016/S2468-1253(19)30191-8 31196733
346 Grobbee EJ, van der Vlugt M, van Vuuren AJ, . A randomised comparison of two faecal immunochemical tests in population-based colorectal cancer screening. Gut. 2017;66(11):1975–82. PMID: 27507905. 10.1136/gutjnl-2016-311819 27507905
347 Larsen MB, Njor S, Ingeholm P, . Effectiveness of colorectal cancer screening in detecting earlier-stage disease-a nationwide cohort study in Denmark. Gastroenterology. 2018;155(1):99–106. PMID: 29626451. 10.1053/j.gastro.2018.03.062 29626451
348 Cole SR, Tucker GR, Osborne JM, . Shift to earlier stage at diagnosis as a consequence of the National Bowel Cancer Screening Program. Med J Australia. 2013;198(6):327–30. PMID: 23545032.23545032
349 Vicentini M, Zorzi M, Bovo E, . Impact of screening programme using the faecal immunochemical test on stage of colorectal cancer: results from the IMPATTO study. Int J Cancer. 2019;145(1):110–121. PMID: 30585621. 10.1002/ijc.32089 30585621
350 Johnson CD, Herman BA, Chen MH, . The National CT Colonography Trial: assessment of accuracy in participants 65 years of age and older. Radiology. 2012;263(2):401–8. PMID: 22361006. 10.1148/radiol.12102177 22361006
351 U.S. Food and Drug Administration. Summary of Safety and Effectiveness Data for Cologuard. 2014. https://www.accessdata.fda.gov/cdrh_docs/pdf13/p130017b.pdf. Accessed May 28, 2021.
352 Church TR, Wandell M, Lofton-Day C, . Prospective evaluation of methylated SEPT9 in plasma for detection of asymptomatic colorectal cancer. Gut. 2014;63(2):317–25. PMID: 23408352. 10.1373/clinchem.2013.221044 23408352
353 Wang H, Tso V, Wong C, . Development and validation of a highly sensitive urine-based test to identify patients with colonic adenomatous polyps. Clin Transl Gastroenterol. 2014;5:e54. PMID: 24646506. 10.1038/ctg.2014.2 24646506
354 Cash B. UpToDate: Postpolypectomy coagulation syndrome. https://www.uptodate.com/contents/postpolypectomy-coagulation-syndrome#H320467159. Accessed March 30, 2020. PMID.
355 Zalis ME, Barish MA, Choi JR, . CT colonography reporting and data system: a consensus proposal. Radiology. 2005;236(1):3–9. PMID: 15987959.15987959
356 Fernandez-Urien I, Carretero C, Gonzalez B, . Incidence, clinical outcomes, and therapeutic approaches of capsule endoscopy-related adverse events in a large study population. Rev Esp Enferm Dig. 2015;107(12):745–52. PMID: 26671587.26671587
357 Castells A, Quintero E, Alvarez C, . Rate of detection of advanced neoplasms in proximal colon by simulated sigmoidoscopy vs fecal immunochemical tests. Clin Gastroenterol Hepatol. 2014;12(10):1708–16.e4. PMID: 24681078. 10.1016/j.cgh.2014.03.022 24681078
358 Lord SJ, Irwig L, Simes RJ. When is measuring sensitivity and specificity sufficient to evaluate a diagnostic test, and when do we need randomized trials? Ann Intern Med. 2006;144(11):850–5. PMID: 16754927. 10.7326/0003-4819-144-11-200606060-00011 16754927
359 Liles E, Coronado G, Perrin N, . Uptake of a colorectal cancer screening blood test is higher than of a fecal test offered in clinic: a randomized trial. Cancer treatment and research communications [serial on the Internet]. 2017 [cited Search 1 - CENTRAL; 10: Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01432189/full.
360 Centers for Disease Control and Prevention (CDC). Vital signs: colorectal cancer screening test use - United States, 2012. MMWR Morb Mortal Wkly Rep. 2013;62(44):881–8. PMID: 24196665.24196665
361 Meissner HI, Breen N, Klabunde CN, . Patterns of colorectal cancer screening uptake among men and women in the United States. Cancer Epidemiol Biomarkers Prev. 2006;15(2):389–94. PMID: 16492934. 10.1158/1055-9965.EPI-05-0678 16492934
362 Schoen RE, Pinsky PF, Weissfeld JL, . Colorectal cancers not detected by screening flexible sigmoidoscopy in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Gastrointest Endosc. 2012;75(3):612–20. PMID: 22341106. 10.1016/j.gie.2011.10.024 22341106
363 Baxter NN, Goldwasser MA, Paszat LF, . Association of colonoscopy and death from colorectal cancer. Ann Intern Med. 2009;150(1):1–8. PMID: 19075198.19075198
364 Singh H, Nugent Z, Demers AA, . The reduction in colorectal cancer mortality after colonoscopy varies by site of the cancer. Gastroenterology. 2010;139(4):1128–37. PMID: 20600026.20600026
365 Jenkins Wessling E, Lanspa SJ. Colonoscopy and chromoscopy in hereditary colorectal cancer syndromes. Fam Cancer. 2016;15(3):453–5. PMID: 26892866. 10.1007/s10689-016-9881-9 26892866
366 Doubeni CA, Corley DA, Quinn VP, . Effectiveness of screening colonoscopy in reducing the risk of death from right and left colon cancer: a large community-based study. Gut. 2018;67(2):291–8. PMID: 27733426. 10.1136/gutjnl-2016-312712 27733426
367 Lee JK, Jensen CD, Levin TR, . Long-term risk of colorectal cancer and related deaths after a colonoscopy with normal findings. JAMA Intern Med. 2019;179(2):153–160. PMID: 30556824. 10.1001/jamainternmed.2018.5565 30556824
368 Kaminski MF, Bretthauer M, Zauber AG, . The NordICC Study: rationale and design of a randomized trial on colonoscopy screening for colorectal cancer. Endoscopy. 2012;44(7):695–702. PMID: 22723185. 10.1055/s-0032-1306895 22723185
369 Rex DK, Schoenfeld PS, Cohen J, . Quality indicators for colonoscopy. Gastrointest Endosc. 2015;81(1):31–53. PMID: 25480100. 10.1016/j.gie.2014.07.058 25480100
370 Rex DK, Bond JH, Winawer S, . Quality in the technical performance of colonoscopy and the continuous quality improvement process for colonoscopy: recommendations of the U.S. Multi-Society Task Force on Colorectal Cancer. Am J Gastroenterol. 2002;97(6):1296–308. PMID: 12094842. 10.1111/j.1572-0241.2002.05812.x 12094842
371 Ikematsu H, Saito Y, Tanaka S, . The impact of narrow band imaging for colon polyp detection: a multicenter randomized controlled trial by tandem colonoscopy. J Gastroenterol. 2012;47(10):1099–107. PMID: 22441532. 10.1007/s00535-012-0575-2 22441532
372 Kahi CJ, Anderson JC, Waxman I, . High-definition chromocolonoscopy vs. high-definition white light colonoscopy for average-risk colorectal cancer screening. Am J Gastroenterol. 2010;105(6):1301–7. PMID: 20179689. 10.1038/ajg.2010.51 20179689
373 Siersema PD, Rastogi A, Leufkens AM, . Retrograde-viewing device improves adenoma detection rate in colonoscopies for surveillance and diagnostic workup. World J Gastroenterol. 2012;18(26):3400–8. PMID: 22807609. 10.3748/wjg.v18.i26.3400 22807609
374 Zhou G, Liu X, Berzin T, . 951e – A Real-Time Automatic Deep Learning Polyp Detection System Increases Polyp and Adenoma Detection During Colonoscopy: A Prospective Double-Blind Randomized Study. Gastroenterology [serial on the Internet]. 2019 [cited Bridge 1 - CENTRAL; 156(6): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01962880/full.
375 Ahmad O, Brandao P, Sami S, . Artificial intelligence for real-time polyp localisation in colonoscopy withdrawal videos. Gastrointest Endosc [serial on the Internet]. 2019 [cited Bridge 1 - CENTRAL; 89(6): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01963430/full.
376 Brenner H, Altenhofen L, Stock C, . Prevention, early detection, and overdiagnosis of colorectal cancer within 10 years of screening colonoscopy in Germany. Clin Gastroenterol Hepatol. 2015;13(4):717–23. PMID: 25218160. 10.1016/j.cgh.2014.08.036 25218160
377 Burling D, Wylie P, Gupta A, . CT colonography: accuracy of initial interpretation by radiographers in routine clinical practice. Clin Radiol. 2010;65(2):126–32. PMID: 20103434. 10.1016/j.crad.2009.09.011 20103434
378 McFarland EG, Fletcher JG, Pickhardt P, . ACR Colon Cancer Committee white paper: status of CT colonography 2009. J Am Coll Radiol. 2009;6(11):756–72 e4. PMID: 19878883. 10.1016/j.jacr.2009.09.007 19878883
379 The American College of Radiology. ACR-SAR-SCBT-MR practice parameter for the performance of computer tomography (CT) colonography in adults. https://www.acr.org/-/media/ACR/Files/Practice-Parameters/ct-colonog.pdf. Accessed Dec 8, 2019.
380 Poullos PD, Beaulieu CF. Current techniques in the performance, interpretation, and reporting of CT colonography. Gastrointest Endosc Clin N Am. 2010;20(2):169–92. PMID: 20451809. 10.1016/j.giec.2010.02.007 20451809
381 Pickhardt PJ, Hassan C, Laghi A, . Clinical management of small (6- to 9-mm) polyps detected at screening CT colonography: a cost-effectiveness analysis. AJR Am J Roentgenol. 2008;191(5):1509–16. PMID: 18941093. 10.2214/AJR.08.1010 18941093
382 Pickhardt PJ, Hassan C, Laghi A, . Small and diminutive polyps detected at screening CT colonography: a decision analysis for referral to colonoscopy. AJR Am J Roentgenol. 2008;190(1):136–44. PMID: 18094303. 10.2214/AJR.07.2646 18094303
383 Boellaard TN, Venema HW, Streekstra GJ, . Effective radiation dose in CT colonography: is there a downward trend? Acad Radiol. 2012;19(9):1127–33. PMID: 22750132. 10.1016/j.acra.2012.04.013 22750132
384 van Gelder RE, Venema HW, Serlie IW, . CT colonography at different radiation dose levels: feasibility of dose reduction. Radiology. 2002;224(1):25–33. PMID: 16338133. 10.1148/radiol.2241011126 12091658
385 Jensch S, van Gelder RE, Venema HW, . Effective radiation doses in CT colonography: results of an inventory among research institutions. Eur Radiol. 2006;16(5):981–7. PMID: 16418863. 10.1007/s00330-005-0047-7 16418863
386 Yee J, McFarland E. Extracolonic findings and radiation at CT colonography: what the referring provider needs to know. Abdom Radiol. 2018;43(3):554–65. PMID: 29450613. 10.1007/s00261-018-1461-z 29450613
387 National Research Council; Division on Earth and Life Studies; Board on Radiation Effects Research; Committee to Assess Health Risks from Exposure to Low Levels of Ionizing Radiation. Health Risks From Exposure to Low Levels of Ionizing Radiation: BEIR VII Phase 2. Washington, DC: National Academies Press; 2006.
388 Brenner DJ, Hall EJ. Computed tomography--an increasing source of radiation exposure. N Engl J Med. 2007;357(22):2277–84. PMID: 18046031. 10.1056/NEJMra072149 18046031
389 Cardis E, Vrijheid M, Blettner M, . Risk of cancer after low doses of ionising radiation: retrospective cohort study in 15 countries. BMJ. 2005;331(7508):77. PMID: 15987704. 10.1136/bmj.38499.599861.E0 15987704
390 Einstein AJ, Henzlova MJ, Rajagopalan S. Estimating risk of cancer associated with radiation exposure from 64-slice computed tomography coronary angiography. JAMA. 2007;298(3):317–23. PMID: 17635892. 10.1001/jama.298.3.317 17635892
391 Buls N, de Mey J, Covens P, . Health screening with CT: prospective assessment of radiation dose and associated detriment. JBR-BTR. 2005;88(1):12–6. PMID: 15792162.15792162
392 Berrington de Gonzalez A, Kim KP, Knudsen AB, . Radiation-related cancer risks from CT colonography screening: a risk-benefit analysis. AJR Am J Roentgenol. 2011;196(4):816–23. PMID: 21427330. 10.2214/AJR.10.4907 21427330
393 Pickhardt PJ, Bodeen G, Brett A, . Comparison of femoral neck BMD evaluation obtained using Lunar DXA and QCT with asynchronous calibration from CT colonography. J Clin Densitom. 2015;18(1):5–12. PMID: 24880495. 10.1016/j.jocd.2014.03.002 24880495
394 Summers RM, Baecher N, Yao J, . Feasibility of simultaneous computed tomographic colonography and fully automated bone mineral densitometry in a single examination. J Comput Assist Tomogr. 2011;35(2):212–6. PMID: 21412092. 10.1097/RCT.0b013e3182032537 21412092
395 Belsey J, Epstein O, Heresbach D. Systematic review: oral bowel preparation for colonoscopy. Aliment Pharmacol Ther. 2007;25(4):373–84. PMID: 17269992. 10.1111/j.1365-2036.2006.03212.x 17269992
396 Tan JJ, Tjandra JJ. Which is the optimal bowel preparation for colonoscopy - a meta-analysis. Colorectal Dis. 2006;8(4):247–58. PMID: 16630226. 10.1111/j.1463-1318.2006.00970.x 16630226
397 California Colorectal Cancer Coalition, American Cancer Society, Operation Access. Improving Access to Colorectal Cancer Screening, Diagnosis, and Treatment in Underserved Communities. 2011.
398 Florida Department of Health. Get the FIT Facts. 2015.
399 Kaiser Permanente Division of Research. 2012 Annual Report: Cancer. 2015.
400 Debarros M, Steele SR. Colorectal cancer screening in an equal access healthcare system. J Cancer. 2013;4(3):270–80. PMID: 23459768. 10.7150/jca.5833 23459768
401 Department of Veterans Affairs. Colonoscopy Versus Fecal Immunochemical Test in Reducing Mortality From Colorectal Cancer (CONFIRM). https://clinicaltrials.gov/ct2/show/NCT01239082. Accessed Dec 6, 2019. PMID.
402 Mosen DM, Liles EG, Feldstein AC, . Participant uptake of the fecal immunochemical test decreases with the two-sample regimen compared with one-sample FIT. Eur J Cancer Prev. 2014;23(6):516–23. PMID: 25203483. 10.1097/CEJ.0000000000000084 25203483
403 Vart G, Banzi R, Minozzi S. Comparing participation rates between immunochemical and guaiac faecal occult blood tests: a systematic review and meta-analysis. Prev Med. 2012;55(2):87–92. PMID: 22634386. 10.1016/j.ypmed.2012.05.006 22634386
404 Zheng S, Chen K, Liu X, . Cluster randomization trial of sequence mass screening for colorectal cancer. Dis Colon Rectum. 2003;46(1):51–8. PMID: 12544522. 10.1007/s10350-004-6496-2 12544522
405 Sarakarn P, Promthet S, Vatanasapt P, . Preliminary results: colorectal cancer screening using fecal immunochemical test (FIT) in a Thai population aged 45–74 years: a population-based randomized controlled trial. Asian Pac J Cancer Prev. 2017;18(10):2883–9. PMID: 29072830.29072830
406 Idigoras Rubio I, Arana-Arri E, Portillo Villares I, . Participation in a population-based screening for colorectal cancer using the faecal immunochemical test decreases mortality in 5 years. Eur J Gastroenterol Hepatol. 2019;31(2):197–204. PMID: 30543575. 10.1097/MEG.0000000000001338 30543575
407 Levin TR, Corley DA, Jensen CD, . Effects of organized colorectal cancer screening on cancer incidence and mortality in a large community-based population. Gastroenterology. 2018;155(5):1383–91.e5. PMID: 30031768. 10.1053/j.gastro.2018.07.017 30031768
408 Leeflang MM, Rutjes AW, Reitsma JB, . Variation of a test’s sensitivity and specificity with disease prevalence. CMAJ. 2013;185(11):E537–44. doi: 10.1503/cmaj.121286.23798453
409 Khalid-de Bakker C, Jonkers D, Smits K, . Participation in colorectal cancer screening trials after first-time invitation: a systematic review. Endoscopy. 2011;43(12):1059–86. PMID: 22135196. 10.1055/s-0031-1291430 22135196
410 Mysliwiec PA, Jensen CD, Zhao W, . 120 fecal immunochemical test performance over multiple rounds of annual testing in an outreach screening program. Gastroenterology. 2014;146(5):S-33–4. 10.1016/S0016-5085(14)60115-3
411 Nielson CM, Vollmer WM, Petrik AF, . Factors affecting adherence in a pragmatic trial of annual fecal immunochemical testing for colorectal cancer. J Gen Intern Med. 2019;34(6):978–985. PMID: 30684199. 10.1007/s11606-018-4820-0 30684199
412 Gellad ZF, Stechuchak KM, Fisher DA, . Longitudinal adherence to fecal occult blood testing impacts colorectal cancer screening quality. Am J Gastroenterol. 2011;106(6):1125–34. PMID: 21304501. 10.1038/ajg.2011.11 21304501
413 Liang PS, Wheat CL, Abhat A, . Adherence to competing strategies for colorectal cancer screening over 3 years. Am J Gastroenterol. 2016;111(1):105–14. PMID: 26526080. 10.1038/ajg.2015.367 26526080
414 Jensen CD, Corley DA, Quinn VP, . Fecal immunochemical test program performance over 4 rounds of annual screening: a retrospective cohort study. Ann Intern Med. 2016;164(7):456–63. PMID: 26811150. 10.7326/M15-0983 26811150
415 Denis B, Gendre I, Perrin P. Participation in four rounds of a French colorectal cancer screening programme with guaiac faecal occult blood test: a population-based open cohort study. J Med Screen. 2015;22(2):76–82. PMID: 25576338. 10.1177/0969141314567795 25576338
416 Fenton JJ, Elmore JG, Buist DS, . Longitudinal adherence with fecal occult blood test screening in community practice. Ann Fam Med. 2010;8(5):397–401. PMID: 20843880. 10.1370/afm.1133 20843880
417 Knudsen MD, Berstad P, Hjartaker A, . Lifestyle predictors for non-participation and outcome in the second round of faecal immunochemical test in colorectal cancer screening. Br J Cancer. 2017;117(4):461–9. PMID: 28704841. 10.1038/bjc.2017.189 28704841
418 Koivogui A, Le Mab G, Benamouzig R. Detection of colorectal neoplasia in a cohort before and after the change of fecal occult blood test in a French Colorectal cancer screening program. Am J Gastroenterol. 2018;113(12):1891–9. PMID: 30337703. 10.1038/s41395-018-0367-2 30337703
419 Lo SH, Halloran S, Snowball J, . Colorectal cancer screening uptake over three biennial invitation rounds in the English bowel cancer screening programme. Gut. 2015;64(2):282–91. PMID: 24812001. 10.1136/gutjnl-2013-306144 24812001
420 Osborne JM, Wilson C, Duncan A, . Patterns of participation over four rounds of annual fecal immunochemical test-based screening for colorectal cancer: what predicts rescreening? BMC Public Health. 2017;18(1):81. PMID: 28764667. 10.1186/s12889-017-4634-8 28764667
421 Singal AG, Corley DA, Kamineni A, . Patterns and predictors of repeat fecal immunochemical and occult blood test screening in four large health care systems in the United States. Am J Gastroenterol. 2018;113(5):746–54. PMID: 29487413. 10.1038/s41395-018-0023-x 29487413
422 Telford J, Gentile L, Gondara L, . Performance of a quantitative fecal immunochemical test in a colorectal cancer screening pilot program: a prospective cohort study. CMAJ Open. 2016;4(4):E668–73. PMID: 28018880. 10.9778/cmajo.20160047 28018880
423 Zorzi M, Hassan C, Capodaglio G, . Long-term performance of colorectal cancerscreening programmes based on the faecal immunochemical test. Gut. 2018;67(12):2124–30. PMID: 29101260. 10.1136/gutjnl-2017-314753 29101260
424 Murphy CC, Sen A, Watson B, . A systematic review of repeat fecal occult blood tests for colorectal cancer screening. Cancer Epidemiol Biomarkers Prev. 2020;29(2):278–87. PMID: 31740521. 10.1158/1055-9965.EPI-19-0775 31740521
425 Finney Rutten LJ, Jacobson DJ, Jenkins GD, . Colorectal cancer screening completion: an examination of differences by screening modality. Prev Med Rep. 2020;20:101202. PMID: 32995145. 10.1016/j.pmedr.2020.101202 32995145
426 Eckmann JD, Ebner DW, Bering J, . Multitarget stool DNA screening in clinical practice: high positive predictive value for colorectal neoplasia regardless of exposure to previous colonoscopy. Am J Gastroenterol. 2020;115(4):608–15. PMID: 32068535. 10.14309/ajg.0000000000000546 32068535
427 Chubak J, Garcia MP, Burnett-Hartman AN, . Time to colonoscopy after positive fecal blood test in four U.S. health care systems. Cancer Epidemiol Biomarkers Prev. 2016;25(2):344–50. PMID: 26843520. 10.1158/1055-9965.EPI-15-0470 26843520
428 Corley DA, Jensen CD, Quinn VP, . Association between time to colonoscopy after a positive fecal test result and risk of colorectal cancer and cancer stage at diagnosis. JAMA. 2017;317(16):1631–41. PMID: 28444278. 10.1001/jama.2017.3634 28444278
429 Halm EA, Beaber EF, McLerran D, . Association between primary care visits and colorectal cancer screening outcomes in the era of population health outreach. J Gen Intern Med. 2016;31(10):1190–7. PMID: 27279097. 10.1007/s11606-016-3760-9 27279097
430 May FP, Yano EM, Provenzale D, . Barriers to follow-up colonoscopies for patients with positive results from fecal immunochemical tests during colorectal cancer screening. Clin Gastroenterol Hepatol. 2019;17(3):469–76. PMID: 29857147. 10.1016/j.cgh.2018.05.022 29857147
431 Partin MR, Gravely AA, Burgess JF, Jr., . Contribution of patient, physician, and environmental factors to demographic and health variation in colonoscopy follow-up for abnormal colorectal cancer screening test results. Cancer. 2017;123(18):3502–12. PMID: 28493543. 10.1002/cncr.30765 28493543
432 Burgess DJ, van Ryn M, Grill J, . Presence and correlates of racial disparities in adherence to colorectal cancer screening guidelines. J Gen Intern Med. 2011;26(3):251–8. PMID: 21088920. 10.1007/s11606-010-1575-7 21088920
433 Burnett-Hartman AN, Mehta SJ, Zheng Y, . Racial/ethnic disparities in colorectal cancer screening across healthcare systems. Am J Prev Med. 2016;51(4):e107–15. PMID: 27050413. 10.1016/j.amepre.2016.02.025 27050413
434 Cooper GS, Kou TD, Schluchter MD, . Changes in receipt of cancer screening in Medicare beneficiaries following the Affordable Care Act. J Natl Cancer Inst. 2016;108(5). PMID: 26640244. 10.1093/jnci/djv374 26640244
435 Fedewa SA, Corley DA, Jensen CD, . Colorectal cancer screening initiation after age 50 years in an organized program. Am J Prev Med. 2017;53(3):335–44. PMID: 28427954. 10.1016/j.amepre.2017.02.018 28427954
436 Zhao G, Okoro CA, Li J, . Health insurance status and clinical cancer screenings among U.S. adults. Am J Prev Med. 2018;54(1):e11–9. PMID: 29102459. 10.1016/j.amepre.2017.08.024 29102459
437 D’Andrea E, Ahnen DJ, Sussman DA, . Quantifying the impact of adherence to screening strategies on colorectal cancer incidence and mortality. Cancer Med. 2020;9(2):824–836. PMID: 31777197.31777197
438 Mannucci A, Zuppardo RA, Rosati R, . Colorectal cancer screening from 45 years of age: thesis, antithesis and synthesis. World J Gastroenterol. 2019;25(21):2565. PMID: 31210710.31210710
439 Rutter C, Knudsen A, Lin J, Bouskill K. Black and white differences in colorectal cancer screening and screening outcomes: a narrative review. Cancer Epidemiol Biomarkers Prev. 2021;30(1):3–12. PMID: 33144285.33144285
440 Doubeni CA, Fletcher RH. Family history of colorectal cancer: it is time to rethink screening recommendations. Gastroenterology. 2015;149(6):1321–2. PMID: 26416326. 10.1053/j.gastro.2015.09.030 26416326
441 Augustus GJ, Ellis NA. Colorectal cancer disparity in African Americans: risk factors and carcinogenic mechanisms. Am J Pathol. 2018;188(2):291–303. PMID: 29128568. 10.1016/j.ajpath.2017.07.023 29128568
442 Shaukat A, Church TR. Long-term effectiveness of sigmoidoscopy screening in women and men. Ann Intern Med. 2018;169(9):663. PMID: 30398635. 10.7326/L18-0511 30398635
443 Selby K, Levine EH, Doan C, . Effect of sex, age, and positivity threshold on fecal immunochemical test accuracy: a systematic review and meta-analysis. Gastroenterology. 2019;157(6):1494–505. PMID: 31472152. 10.1053/j.gastro.2019.08.023 31472152
444 Leddin D, Lieberman DA, Tse F, . Clinical practice guideline on screening for colorectal cancer in individuals with a family history of nonhereditary colorectal cancer or adenoma: the Canadian Association of Gastroenterology Banff Consensus. Gastroenterology. 2018;16:16. PMID: 30121253. 10.1053/j.gastro.2018.08.017 30121253
445 Butterworth AS, Higgins JP, Pharoah P. Relative and absolute risk of colorectal cancer for individuals with a family history: a meta-analysis. Eur J Cancer. 2006;42(2):216–27. PMID: 16338133. 10.1016/j.ejca.2005.09.023 16338133
446 Weigl K, Jansen L, Chang-Claude J, . Family history and the risk of colorectal cancer: the importance of patients’ history of colonoscopy. Int J Cancer. 2016;139(10):2213–20. PMID: 27459311. 10.1002/ijc.30284 27459311
447 Usher-Smith JA, Walter FM, Emery JD, . Risk prediction models for colorectal cancer: a systematic review. Cancer Prev Res (Phila). 2016;9(1):13–26. PMID: 26464100. 10.1158/1940-6207.CAPR-15-0274 26464100
448 Peng Z, Zhu W, Dai J, . MicroRNA-200 as potential diagnostic markers for colorectal cancer: meta-analysis and experimental validation. Cell Mol Biol (Noisy-le-grand). 2018;64(6):77–85. PMID: 29808805.29808805
449 Usher-Smith JA, Harshfield A, Saunders CL, . External validation of risk prediction models for incident colorectal cancer using UK Biobank. Br J Cancer. 2018;118(5):750–9. PMID: 29381683. 10.1038/bjc.2017.463 29381683
450 Smith T, Muller DC, Moons KG, . Comparison of prognostic models to predict the occurrence of colorectal cancer in asymptomatic individuals: a systematic literature review and external validation in the EPIC and UK Biobank prospective cohort studies. Gut. 2019;68(4):672–83. PMID: 29615487. 10.1136/gutjnl-2017-315730 29615487
451 Park YM, Kim HS, Park JJ, . A simple scoring model for advanced colorectal neoplasm in asymptomatic subjects aged 40–49 years. BMC Gastroenterology. 2017;17(1):7. PMID: 28068908. 10.1186/s12876-016-0562-9 28068908
452 Yang HJ, Choi S, Park SK, . Derivation and validation of a risk scoring model to predict advanced colorectal neoplasm in adults of all ages. J Gastroenterol Hepatol. 2017;32(7):1328–35. PMID: 28012211. 10.1111/jgh.13711 28012211
453 Jung YS, Park CH, Kim NH, . Impact of age on the risk of advanced colorectal neoplasia in a young population: an analysis using the predicted probability model. Dig Dis Sci. 2017;62(9):2518–25. PMID: 28733868. 10.1007/s10620-017-4683-y 28733868
454 Kim TJ, Kim ER, Hong SN, . Adenoma detection rate influences the risk of metachronous advanced colorectal neoplasia in low-risk patients. Gastrointest Endosc. 2018;87(3):809–17.e1. PMID: 28987544. 10.1016/j.gie.2017.09.028 28987544
455 Evaluation of the ctDNA LUNAR Test in an Average Patient Screening Episode (ECLIPSE). https://clinicaltrials.gov/ct2/show/NCT04136002. Accessed March 30, 2020.
456 Friedland S, Watson D, Pan JY, . 575 a highly sensitive and quantitative multimodal blood test for the detection of colorectal adenomas and cancer. Gastroenterology. 2020;158(6):S-121.
457 Chen X, Gole J, Gore A, . Non-invasive early detection of cancer four years before conventional diagnosis using a blood test. Nat Commun. 2020;11(1):3475. PMID: 32694610. 10.1038/s41467-020-17316-z 32694610
458 Liu MC, Oxnard GR, Klein EA, . Sensitive and specific multi-cancer detection and localization using methylation signatures in cell-free DNA. Ann Oncol. 2020;31(6):745–59. 10.1016/j.annonc.2020.02.011 33506766
459 Centers for Disease Control and Prevention. United States Cancer Statistics: 1999–2014, WONDER Online Database. https://wonder.cdc.gov/wonder/help/cancer-v2014.html. Accessed.
460 Ashraf I, Paracha SR, Arif M, . Digital rectal examination versus spontaneous passage of stool for fecal occult blood testing. South Med J. 2012;105(7):357–61. PMID: 22766663. 10.1097/SMJ.0b013e31825bfdc5 22766663
461 Nakama H, Zhang B, Abdul Fattah AS, . Does stool collection method affect outcomes in immunochemical fecal occult blood testing? Dis Colon Rectum. 2001;44(6):871–5. PMID: 11391151.11391151
462 Qaseem A, Crandall CJ, Mustafa RA, . Screening for colorectal cancer in asymptomatic average-risk adults: a guidance statement from the American College of Physicians. Ann Intern Med. 2019;171(9):643–54. PMID: 31683290. 10.7326/M19-0642 31683290
463 Moreno C, Kim DH, Bartel TB, . ACR Appropriateness Criteria: colorectal cancer screening. J Am Coll Radiol. 2018;15(5):S56–68. PMID: 29724427. 10.1016/j.jacr.2018.03.014 29724427
464 Wolf AM, Fontham ET, Church TR, . Colorectal cancer screening for average-risk adults: 2018 guideline update from the American Cancer Society. CA Cancer J Clin. 2018;68(4):250–81. PMID: 29846947. 10.3322/caac.21457 29846947
465 Rex DK, Boland CR, Dominitz JA, . Colorectal cancer screening: recommendations for physicians and patients from the U.S. Multi-Society Task Force on Colorectal Cancer. Gastrointest Endosc. 2017;86(1):18–33. PMID: 28600070. 10.1016/j.gie.2017.04.003 28600070
466 Bacchus CM, Dunfield L, Gorber SC, . Recommendations on screening for colorectal cancer in primary care. CMAJ. 2016;188(5):340–8. PMID: 26903355. 10.1503/cmaj.151125 26903355
467 Scottish Intercollegiate Guidelines Network (SIGN). Diagnosis and Management of Colorectal Cancer: A National Clinical Guideline. Edinburgh: SIGN; 2016.
468 Short MW, Layton MC, Teer BN, . Colorectal cancer screening and surveillance. Am Fam Physician. 2015;91(2):93–100. PMID: 25591210.25591210
469 Provenzale D, Gupta S, Ahnen DJ, . NCCN Guidelines Insights: colorectal cancer screening, version 1.2018. J Natl Compr Canc Netw. 2018;16(8):939–949. PMID: 30099370. 10.6004/jnccn.2018.0067 30099370
470 Lansdorp-Vogelaar I, von Karsa L. European guidelines for quality assurance in colorectal cancer screening and diagnosis. –Introduction. Endoscopy. 2012;44(S 03):SE15–30. PMID: 23012118. 10.1055/s-0032-1308898 23012118
471 Brink D, Barlow J, Bush K, . Institute for Clinical Systems Improvement. Colorectal Cancer Screening. May 2012. https://www.icsi.org/_asset/j73fu0/Colorectal.pdf
472 Mayo-Smith WW, Hara AK, Mahesh M, . How I do it: managing radiation dose in CT. Radiology. 2014;273(3):657–72. PMID: 25420167. 10.1148/radiol.14132328 25420167