# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tina Fan, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; the CISNET Colorectal Working Group; Samir Gupta, MD, and Carolyn Rutter, PhD, for their content expertise and review of the draft report; Rebecca Siegal, MPH, for providing incidence data; Douglas A. Corley, MD, PhD, MPH, Desmond Leddin MB, MSc, FRCPC, FRCPI, David Lieberman, MD, Dawn Provenzale, MD, MS, Paul Pinksy, PhD, and Carrie Klabunde, PhD, who provided expert review of the draft report; the National Cancer Institute for providing federal partner review of our draft report; and Todd Hannon and Katherine Essick, BS, at the Kaiser Permanente Center for Health Research for technical and editorial assistance.