# Chapter 3 Results

## Description of Included Studies

This systematic review updates our prior review, which supported the 2016 USPSTF recommendation on screening for colorectal cancer. We found 33 studies^21,^ ^119–150^ on the effectiveness or comparative effectiveness of screening on colorectal cancer incidence or mortality (13 of which are new since the prior review^119,^ ^122,^ ^125,^ ^127,^ ^130–132,^ ^135–137,^ ^139,^ ^149,^ ^150^), 59 studies^151–209^ on the diagnostic accuracy of various screening tests (28 new^154,^ ^155,^ ^158,^ ^159,^ ^161,^ ^162,^ ^164,^ ^166,^ ^168,^ ^170,^ ^171,^ ^173,^ ^179,^ ^180,^ ^187,^ ^189,^ ^196–200,^ ^202–204,^ ^206–209^), and 131 studies^119,^ ^121,^ ^124,^ ^125,^ ^127,^ ^129,^ ^130,^ ^133–136,^ ^138,^ ^140–144,^ ^147,^ ^150,^ ^169,^ ^172,^ ^177,^ ^178,^ ^181,^ ^184,^ ^188,^ ^195,^ ^198,^ ^205,^ ^210–313^ on harms of screening (37 new^119,^ ^125,^ ^127,^ ^130,^ ^135,^ ^136,^ ^150,^ ^198,^ ^217,^ ^218,^ ^221,^ ^226,^ ^231,^ ^237,^ ^240,^ ^244,^ ^248,^ ^250,^ ^260–262,^ ^270,^ ^271,^ ^281,^ ^282,^ ^287,^ ^290,^ ^298,^ ^302,^ ^303,^ ^307–313^) (Table 4). A full list of included studies and their ancillary publications is available in Appendix B. This review includes evidence for direct visualization screening tests (i.e., flexible sigmoidoscopy, colonoscopy, CTC, capsule endoscopy), stool-based screening tests (i.e., gFOBT, HSgFOBT, FIT, sDNA), serum-based screening tests, and urine-based screening tests. Urine tests and capsule endoscopy as screening modalities were not included in the prior review.

Table 4 Evidence Landscape of Included Studies by Key Question and Screening Test

Key question | | Total no. of Studies | Direct Visualization | | | | Stool | | | | Serum | Urine
Key question | | Total no. of Studies | FS (+/− stool testing) | Colo | CTC | CE | gFOBT | HSgFOBT | FIT | sDNA | mSEPT9 | Metab
1 | Screening effectiveness | 13 | 4^*^ | 2^*^ | 0 | 0 | 6^*^ | 0 | 1^*^ | 0 | 0 | 0
1 | Comparative effectiveness | 21 | 11^*^ | 5^*^ | 3^*^ | 0 | 8 | 0 | 13^*^ | 0 | 0 | 0
2 | Colonoscopy reference standard ^‡^ | 40 | 0 | 4 | 9 | 2^*^ | NA | 2^*^ | 26^*^ | 4^*^ | 1 | 1^*^
2 | Differential verification ^†^ | 19 | 0 | 0 | 0 | 0 | NA | 3 | 19^*^ | 0 | 0 | 0
3 | Serious adverse events | 110 | 19^*^ | 68^*^ (S); 20^*^ (F) | 17^*^ | 1^*^ | NA^**^ | NA^**^ | NA^**^ | NA^**^ | NA^**^ | NA^**^
3 | Radiation | 7 | NA | NA | 7 | NA | NA | NA | NA | NA | NA | NA
3 | ECF | 27 | NA | NA | 27^*^ | NA | NA | NA | NA | NA | NA | NA

* Includes new data since the 2016 USPSTF recommendation

† Differential verification consisted of direct visualization for those with an abnormal screening test and cancer registry followup for all participants.

** No hypothesized harms for non-invasive screening tests beyond that of the followup testing.

‡ For colonoscopy and CTC studies, the reference standard could include colonoscopy plus CTC (segmental unblinding)

Abbreviations: CE = capsule endoscopy; Colo = colonoscopy; CTC = computed tomography colonography; ECF = extracolonic findings; F = followup colonoscopy due to an abnormal screening test; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; HS = high-sensitivity; Metab = metabolomic-based test; NA = not applicable or not addressed in this review; S = screening; sDNA = stool-based deoxyribonucleic acid

## KQ1 What Is the Effectiveness or Comparative Effectiveness of Screening Programs in Reducing Colorectal Cancer, Mortality, or Both? Does the Effectiveness of Screening Programs Vary by Subgroups (e.g., Age, Sex, Race/Ethnicity)?

### Summary of Results

We included 33 unique fair- to good-quality studies (published in 66 articles^21,^ ^119–150,^ ^314–346^) to assess the effectiveness or comparative effectiveness of screening tests on CRC incidence and mortality (Table 4). We found two prospective cohort studies^21,^ ^125^ that examined the effectiveness of screening colonoscopy, four RCTs^119,^ ^127,^ ^130,^ ^140^ that examined the effectiveness of FS with or without a FIT, no studies that examined the effectiveness of CTC, six trials^124,^ ^128,^ ^129,^ ^132,^ ^138,^ ^143^ that examined the effectiveness of a gFOBT, one prospective cohort study^122^ that examined the effectiveness of a FIT, and no studies that examined the effectiveness of HSgFOBT, sDNA, serum-based, or urine-based tests versus no screening. In addition to one screening FS RCT^127^ evaluating FS plus FIT versus FS alone, we found 20 studies^120,^ ^121,^ ^123,^ ^126,^ ^131,^ ^133–137,^ ^139,^ ^141,^ ^142,^ ^144–150^ that compared screening modalities, however, the majority were designed to assess the relative uptake and CRC yield between different screening modalities, rather than to assess the reduction in CRC incidence and mortality.

#### Effectiveness of Screening

We found well-conducted trials for one- or two-time FS and annual or biennial gFOBT screening programs demonstrating a reduction in CRC incidence and mortality (Table 5). Since our previous review, three previously included FS trials have published longer followup^119,^ ^127,^ ^130^; these data are consistent with our prior understanding of benefit. Based on four RCTs^119,^ ^127,^ ^130,^ ^140^ (n=458,002) that used intention-to-treat analyses, a one- or two-time FS was consistently associated with a decrease in CRC incidence (IRR 0.78 (95% CI, 0.74 to 0.83) and CRC-specific mortality (IRR 0.74 (95% CI, 0.68 to 0.80) compared with no screening at 11 to 17 years of followup. Reductions in CRC incidence and mortality were greater for men than women. Based on five RCTs (n=419,966) that used intention-to-treat analyses, biennial screening with Hemoccult or Hemoccult II was associated with a reduction of CRC-specific mortality compared with no screening after two to nine rounds of screening at 11 to 30 years of followup (RR 0.91 [95% CI, 0.84 to 0.98] at 19.5 years; RR 0.78 [95% CI, 0.65 to 0.93] at 30 years). One additional trial of screening with gFOBT in Finland (n=360,492) had only interim findings, with a followup of 4.5 years. While neither FS nor Hemoccult II is commonly used in the United States to screen for CRC, these trials provide foundational evidence for newer, yet similar, screening tests.

Table 5 Key Question 1: Overall Summary of Impact of Screening vs. No Screening on Colorectal Cancer Incidence and Mortality

Screening test; (Sample n) | Round | Followup, years | Group | CRC incidence | CRC mortality
Colonoscopy; k=2, cohort; (n=436,927)^21,^ ^125^ | 1 | 8–24^†^ | Total | w/polypectomy HR, adj: 0.53 (95% CI, 0.40 to 0.71)^*^; negative colo HR, adj: 0.47 (95% CI, 0.39 to 0.57)^*^; Age 70–74 y: RD −0.42% (95% CI, −0.24 to −0.63)^†^; Age 75–79 y: RD −0.14% (95% CI, −0.41 to −0.16)^†^ | HR, adj: 0.32 (95% CI, 0.24 to 0.45)^*^
Colonoscopy; k=2, cohort; (n=436,927)^21,^ ^125^ | 1 | 8–24^†^ | Distal | w/polypectomy HR, adj: 0.37 (95% CI, 0.23 to 0.61)^*^; negative colo HR, adj: 0.29 (95% CI, 0.21 to 0.39)^*^ | HR, adj: 0.18 (95% CI, 0.10 to 0.31)^*^
Colonoscopy; k=2, cohort; (n=436,927)^21,^ ^125^ | 1 | 8–24^†^ | Proximal | w/polypectomy HR, adj: 0.79 (95% CI, 0.52 to 1.19)^*^; negative colo HR, adj: 0.29 (95% CI, 0.21 to 0.39)^*^ | HR, adj: 0.47 (95% CI, 0.29 to 0.76)^†^
FS; k=4, RCT; (n=458,002)^119,^ ^127,^ ^130,^ ^140^ | 1–2; Q3–5y | 11–17 | Total | IRR 0.78 (95% CI, 0.74 to 0.83) | IRR 0.74 (0.68 to 0.80)
FS; k=4, RCT; (n=458,002)^119,^ ^127,^ ^130,^ ^140^ | 1–2; Q3–5y | 11–17 | Distal | IRR 0.67 (95% CI, 0.60 to 0.75) | IRR 0.61 (95% CI, 0.49 to 0.74)
FS; k=4, RCT; (n=458,002)^119,^ ^127,^ ^130,^ ^140^ | 1–2; Q3–5y | 11–17 | Proximal | IRR 0.93 (95% CI, 0.88 to 0.99) | IRR 0.90 (95% CI, 0.80 to 1.00)
Hemoccult II; k=5, RCT; (n=419,966)^124,^ ^128,^ ^129,^ ^138,^ ^143^ | 2–9; Q2y | 11–30 | Total | RR range from 0.90 (95% CI, 0.77 to 1.04) from 1.02 (95% CI, 0.93 to 1.12) | RR range from 0.78 (95% CI, 0.65, 0.93) to 0.91 (95% CI, 0.84, 0.98)^‡^
Hemoccult II; k=5, RCT; (n=419,966)^124,^ ^128,^ ^129,^ ^138,^ ^143^ | 2–9; Q2y | 11–30 | Distal | NR | NR
Hemoccult II; k=5, RCT; (n=419,966)^124,^ ^128,^ ^129,^ ^138,^ ^143^ | 2–9; Q2y | 11–30 | Proximal | NR | NR
FIT; k=1, cohort; (n=5.4 million)^122^ | Q2y | Up to 6 y (mean 3y) | Total | NR | RR, adj: 0.90 (95% CI, 0.84, 0.95)

* 22 year followup for incidence; 24 year followup for mortality. Adjusted for: age, BMI, family history, smoking status, physical activity, diet, vitamin use, aspirin use, NSAID use, cholesterol-lowering drug use, hormone replacement therapy

‡ Annual RR from one trial only 0.68 (0.56, 0.82), 11 rounds, q1y, 30 y follow-up

† standardized 8 year risk

Abbreviations: adj = adjusted; CI = confidence interval; colo = colonoscopy; FIT = fecal immunochemical test; f/u = followup; HR = hazard ratio; IRR = incidence rate ratio; k = number of studies; n = number; NR = not reported; Q = interval; RCT = randomized controlled trial; RD = risk difference; RR = relative risk; w/ = with; y = years.

We found two large, prospective observational studies evaluating the association of receipt of screening colonoscopy and one evaluating receipt of FIT on CRC incidence and/or mortality.^21,^ ^125^ For colonoscopy, after 24 years of followup, one study (n=88,902) among health professionals found the CRC-specific mortality rate was lower in people who self-reported at least one screening colonoscopy compared with those who had never had a screening colonoscopy (adjusted HR, 0.32 [95% CI, 0.24 to 0.45]).^21^ This study found that screening colonoscopies were associated with lower CRC mortality from both distal and proximal cancers. It also found that results were no longer statistically significant after 5 years in people with a first-degree relative with CRC, as opposed to a sustained association beyond 5 years in people without a family history. Another study among Medicare beneficiaries (n=348,025) with much shorter followup found that people ages 70 to 74 years who underwent a screening colonoscopy had a lower 8-year standardized risk for CRC (−0.42 percent [95% CI, −0.24 to 0.63]) than those who did not undergo the test.^125^ The magnitude of benefit was lower and no longer statistically significant for people ages 75 to 79 years, and this study did not report any mortality outcomes. Although many observational studies have evaluated national FIT screening programs, we found only one prospective observational study meeting our inclusion and quality criteria. This study (n=5,417,699) found that one to three rounds of screening with a biennial FIT (OC-Sensor or HM JACK) were associated with lower CRC mortality than no screening (adjusted RR, 0.90 [95% CI, 0.84 to 0.95]).^122^

While three gFOBT studies include adults under age 50 years, none of them provided age-stratified analyses for this age group. We could not directly compare the magnitude of benefit in CRC mortality and cancer incidence among screening tests because of major differences in the design of included studies for each test type (e.g., trial versus observational study, intention to screen versus as screened, outcome metric reported). We found no studies evaluating the effectiveness of CTC, capsule endoscopy, HSgFOBT, sDNA, serum, or urine tests on CRC incidence and/or mortality.

#### Comparative Effectiveness of Screening

In one FS screening RCT, persons in the FS plus FIT arm had lower CRC-specific mortality than those in the FS-only arm, age-adjusted HR 0.62 (95% CI, 0.42 to 0.90) versus 0.84 (95% CI, 0.61 to 1.17), although this difference was not statistically significant. Additional included trials were primarily designed to evaluate the comparative uptake/adherence, test positivity, and initial cancer detection of one screening test versus another. Only a handful of studies were adequately powered to detect a reduction in cancer incidence or mortality. In general the number of cancers detected in these studies was low, and only one study reported mortality outcomes. Most studies only reported cancer yield after one round of screening, and only three studies reported interval cancers. As a result, we cannot draw any robust conclusions about the comparative effectiveness of various screening tests on reducing cancer incidence or mortality from empiric studies. Based on one study, one-time FS or colonoscopy does not appear to detect more cancers than 4 rounds of FIT. Based on 4 studies, FIT can detect more cancers than Hemoccult II, and a two-sample FIT does not appear to be superior to a one-sample FIT. In addition, 4 studies comparing different FITs did not find statistically significant differences in cancers after one or two rounds of screening, despite differences in test positivity. However, the overall number of cancers was low and none of these studies reported interval cancers. Several adequately powered studies are currently underway that will evaluate the comparative effectiveness of direct visualization versus stool-based screening programs (Appendix I). We found no active comparative effectiveness trials evaluating sDNA, serum tests, or urine tests.

### Detailed Results for the Effectiveness of Direct Visualization Tests

#### Flexible Sigmoidoscopy

We found four fair-quality trials (n=458,002) assessing the effectiveness of FS screening on CRC incidence and/or mortality; all four of these trials were included in our previous review. However, since our prior synthesis of these trials, three trials^119,^ ^127,^ ^130^ have published results with longer followup. Because all of these trials were included in our previous review, we provide only a brief discussion of these trials below. Additional details can be found in our prior review.^82,^ ^83^

##### Study and Population Characteristics

Only one of the four trials was conducted in the United States (the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial [PLCO]); the other three were conducted in western Europe (Table 6). All trials recruited average-risk adults between age 50 and 74 years, with a mean age ranging from 56 to 60 years. Colorectal cancer prevalence among participants screened at baseline ranged from 0.3 to 0.5 percent. The cumulative incidence of CRC identified in screened and unscreened participants over a median of 10 to 17 years of followup ranged from 1.6 to 2.6 percent. All trials recruited an even mix of men and women. Two trials reported that approximately 10 percent of the participants had a family history of CRC. One trial, the United Kingdom Flexible Sigmoidoscopy Screening Trial (UKFSST), explicitly excluded participants with two or more close relatives with CRC. Only the PLCO trial reported the race/ethnicity of participants, approximately 14 percent of whom were nonwhite.

Table 6 Key Question 1: Study and Population Characteristics of Screening Flexible Sigmoidoscopy RCTs

| NORCCAP | PLCO | SCORE | UKFSST
Author, year^*^ | Holme, 2018^127^ | Miller, 2019^130^ | Segnan, 2011^140^ | Atkin, 2017^119^
Country | Norway | US | Italy | UK
Targeted Age, years | 50–64 | 55–74 | 55–64 | 55–64
Program n | IG: 20,572; CG: 78,220 | IG: 77,445; CG: 77,455 | IG: 17,136; CG: 17,136 | IG: 57,099; CG: 112,939
Number of rounds | 1 | 2 | 1 | 1
Median length of followup, years | 14.8 | 16.8; 12.1 (all-cause mortality) | 10.5 (incidence); 11.4 (mortality) | 17.1
Attendance to screening, % | 63 | 1st Screen: 84; 2nd Screen: 54 | 58 | 67
CRC yield at baseline, % (n/n) | 0.3 (41/12,960) | 0.3 (185/64,658) | 0.5 (54/9,911) | 0.3 (131/40,674)
CRC cumulative incidence, % (n/n) | 2.2 (2,144/98,792) | 2.1 (3222/154,887) | 1.6 (557/34,272) | 2.6 (4483/170,034)
Criteria for colonoscopy | Polyp ≥10 mm; adenoma; CRC; abnormal FOBT | Polyp or mass was detected | Advanced adenoma; CRC; ≥3 adenomas; ≥5 hyperplastic polyps above rectum; inadequate bowel prep with ≥1 polyp | Advanced adenoma; CRC; ≥3 adenomas; ≥20 hyperplastic polyps above rectum
Referred to Colonoscopy, % | 20.4 | 32.9 (of participants screened 1 or 2 times); 20.7 (of FS exams) | 8.6 | 5.2

* Most recent publication

Abbreviations: CG = control group; CRC = colorectal cancer; FOBT = fecal occult blood test; IG = intervention group; n = number of participants; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; UK = United Kingdom; UKFSST = UK Flexible Sigmoidoscopy Screening Trial; US = United States

The screening protocol for the four trials varied. The Norwegian Colorectal Cancer Prevention (NORCCAP) trial evaluated a one-time FS with or without a FIT (approximately half of the screening participants also received a FIT) versus no screening. The other three trials compared a FS alone with no screening. The PLCO trial evaluated screening with a followup FS at 3 to 5 years, while the Screening for COlon REctum (SCORE) trial and the UKFSST evaluated a one-time FS. Followup colonoscopy varied widely by trial: from 5.2 percent in UKFSST to 32.9 percent in PLCO. Variation in colonoscopy rates reflect the different referral criteria used in each of the trials.

The adherence to initial FS ranged from 58 to 83 percent, with the highest adherence observed in the PLCO trial. Only the PLCO trial reported whether the control group received screening—about 47 percent of the control group was found to have some type of lower endoscopy during the screening phase of the trial. In the other three trials control participants were not contacted and were unaware of their trial involvement.

##### Outcomes

Based on intention-to-screen analyses of the four trials, one- or two-time FS decreased CRC incidence and CRC-specific mortality, but not all-cause mortality over a median of 11 to 17 years (Table 7). The pooled IRR for CRC incidence for FS versus no screening was 0.78 (95% CI, 0.74 to 0.83; I^2^=29%) with 28 to 47 fewer CRC cases per 100,000 person-years among those with FS screening (Figure 3). The pooled IRR for CRC mortality for FS versus no screening was 0.74 (95% CI, 0.68 to 0.80; I^2^=0%) (Figure 4) with 10 to 17 fewer CRC deaths per 100,000 person-years among those with FS screening. The pooled IRR for all-cause mortality for FS versus no screening was 0.99 (95% CI, 0.98 to 1.00; I^2^=0.15%) (Figure 5).

Table 7 Key Question 1: Results of Screening Flexible Sigmoidoscopy RCTs

Trial | Median followup, years | Randomized group | N | CRC incidence | | | CRC mortality | | | All-cause mortality
Trial | Median followup, years | Randomized group | N | No. of CRC cases | Rate, per 100,000 p-y | RR (95% CI) | No. of CRC deaths | Rate, per 100,000 p-y | RR (95% CI) | No. of deaths | Rate, per 100,000 p-y | RR (95% CI)
NORCCAP^127^ | 14.8 | IG | 20,572 | 393 | 135.9 | 0.78^*^; (0.70, 0.87) | 122 | 41.9 | 0.79^*^; (0.65, 0.96) | 3,809 | 1309.1 | 0.98^*^; (0.95, 1.02)
NORCCAP^127^ | 14.8 | CG | 78,220 | 1,751 | 174.5 | 0.78^*^; (0.70, 0.87) | 530 | 52.9 | 0.79^*^; (0.65, 0.96) | 13,433 | 1333.3 | 0.98^*^; (0.95, 1.02)
PLCO^130^ | 16.8; (12.1 for all-cause mortality) | IG | 77,445 | 1,461 | 125.5 | 0.82; (0.76, 0.88) | 417 | 33.7 | 0.75; (0.66, 0.85) | 10,879 | NR | NR
PLCO^130^ | 16.8; (12.1 for all-cause mortality) | CG | 77,455 | 1,761 | 153.3 | 0.82; (0.76, 0.88) | 549 | 44.8 | 0.75; (0.66, 0.85) | 11,102 | NR | NR
SCORE^140^ | 10.5; (11.4 for CRC mortality) | IG | 17,136 | 251 | 144.11 | 0.82; (0.69, 0.96) | 65 | 34.66 | 0.78; (0.56, 1.08) | 1,202 | 640.96 | NR
SCORE^140^ | 10.5; (11.4 for CRC mortality) | CG | 17,136 | 306 | 176.43 | 0.82; (0.69, 0.96) | 83 | 44.45 | 0.78; (0.56, 1.08) | 1,233 | 660.26 | NR
UKFSST^119^ | 17.1 | IG | 57,099 | 1,230 | 137 | 0.74^*^; (0.70, 0.80) | 353 | 39 | 0.70^*^; (0.62, 0.79) | 13,279 | 1472 | 0.99^*^; (0.97, 1.01)
UKFSST^119^ | 17.1 | CG | 112,939 | 3,253 | 184 | 0.74^*^; (0.70, 0.80) | 996 | 56 | 0.70^*^; (0.62, 0.79) | 26,409 | 1483 | 0.99^*^; (0.97, 1.01)

* Hazard ratio

Abbreviations: CG = control group; CI = confidence interval; CRC = colorectal cancer; FOBT = fecal occult blood test; IG = intervention group; n = number of participants; NORCCAP = Norwegian Colorectal Cancer Prevention; p-y = person-years; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; RR = relative risk; SCORE = Screening for COlon Rectum; UK = United Kingdom; UKFSST = UK Flexible Sigmoidoscopy Screening Trial; US = United States

Figure 3 Key Question 1: Forest Plot of Flexible Sigmoidoscopy Screening vs. No Screening on Colorectal Cancer Incidence

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; IRR = incidence rate ratio; k = thousand; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; p-y = person-years; UKFSST = United Kingdom Flexible Sigmoidoscopy Screening Trial

Figure 3 shows a forest plot of flexible sigmoidoscopy screening versus no screening on colorectal cancer incidence. The pooled incidence rate ratio is 0.78 with a 95% confidence interval of 0.74 to 0.83. The effect favors the intervention group.

Figure 4 Key Question 1: Forest Plot of Flexible Sigmoidoscopy Screening vs. No Screening on Colorectal Cancer Mortality

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; IRR = incidence rate ratio; k = thousand; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; p-y = person-years; UKFSST = United Kingdom Flexible Sigmoidoscopy Screening Trial

Figure 4 shows a forest plot of flexible sigmoidoscopy screening versus no screening on colorectal cancer mortality. The pooled incidence rate ratio is 0.74 with a 95% confidence interval of 0.68 to 0.8. The effect favors the intervention group.

Figure 5 Key Question 1: Forest Plot of Flexible Sigmoidoscopy Screening vs. No Screening on All-Cause Mortality

Abbreviations: CI = confidence interval; IRR = incidence rate ratio; No. = number; NORCCAP = Norwegian Colorectal Cancer Prevention trial; PLCO = Prostate, Lung, Colorectal and Ovarian cancer screening trial; REML = restricted maximum likelihood; UKFSST = United Kingdom Flexible Sigmoidoscopy Screening Trial; SCORE = Screening for COlon Rectum

Notes: Assumed the n analyzed did not change between 11 and 15 years of followup for NORCCAP.

Figure 5 shows a forest plot of flexible sigmoidoscopy screening versus no screening on all-cause mortality. The pooled incidence rate ratio is 0.98 with a 95% confidence interval of 0.97 to 1.00. The effect favors the intervention group.

In the NORCCAP trial, the FS plus FIT arm had lower CRC-specific mortality than the FS-only arm—age-adjusted HR 0.62 (95% CI, 0.42 to 0.90) versus 0.84 (95% CI, 0.61 to 1.17)—although this difference was not statistically significant.

##### By Stage or Location

Reductions in CRC incidence and CRC-specific mortality were greater for distal than proximal cancers (Table 8). The pooled IRR for CRC incidence for distal cancers was 0.67 (95% CI, 0.60 to 0.75; I^2^=67%) versus 0.93 for proximal cancers (95% CI, 0.88 to 0.99; I^2^=88%) (Figure 6). Likewise, the pooled IRR for CRC-specific mortality for distal cancers was 0.61 (95% CI, 0.49 to 0.74; I^2^=66%) versus 0.90 for proximal cancers (95% CI, 0.80 to 1.00; I^2^=0%) (Figure 7).

Table 8 Key Question 1: Results of Screening Flexible Sigmoidoscopy RCTs, for Sex, Location, and Age Subgroups

Trial | Median followup, years | Subgroup | CRC incidence | | | CRC mortality | | | All-cause mortality
Trial | Median followup, years | Subgroup | IG rate, per 100,000 p-y | CG rate, per 100,000 p-y | RR (95% CI) | IG rate, per 100,000 p-y | CG rate, per 100,000 p-y | RR (95% CI) | IG rate, per 100,000 p-y | CG rate, per 100,000 p-y | RR (95% CI)
NORCCAP^127^ | 14.8 | Male | 131.4 | 196.9 | 0.66^*^; (0.57, 0.78) | 40 | 63.3 | 0.63^*^; (0.47, 0.83) | 1572 | 1638.1 | 0.96^*^; (0.91, 1.0)
NORCCAP^127^ | 14.8 | Female | 140.1 | 153.6 | 0.92^*^; (0.79, 1.07) | 43.7 | 43.3 | 1.01^*^; (0.77, 1.33) | 1056.4 | 1047.5 | 1.02^*^; (0.96, 1.07)
NORCCAP^127^ | 14.8 | Distal | 67.1 | 98.5 | 0.68^*^; (0.58, 0.79) | 23.4 | 27.8 | 0.83^*^; (0.64, 1.09) | NA | NA | NA
NORCCAP^127^ | 14.8 | Proximal | 66.1 | 72.0 | 0.92^*^; (0.78, 1.08) | 16.2 | 22.7 | 0.71^*^; (0.52, 0.98) | NA | NA | NA
NORCCAP^127^ | 14.8 | 50–54 years | 81.5 | 110.2 | 0.67^*^; (0.42, 1.07) | 21.1 | 31.3 | 0.67^*^; (0.42, 1.07) | NR | NR | 1.02^*^; (0.95, 1.08)
NORCCAP^127^ | 14.8 | 55–64 years | 162.4 | 206.0 | 0.79^*^; (0.70, 0.89) | 52.0 | 63.5 | 0.82^*^; (0.66, 1.02) | NR | NR | 1.02^*^; (0.95, 1.08)
PLCO^130^ | 16.8; (12.1 for all-cause mortality) | Male | 141.3 | 184.1 | 0.77; (0.70, 0.84) | 38.8 | 57.3 | 0.68; (0.57, 0.80) | NR | NR | NR
PLCO^130^ | 16.8; (12.1 for all-cause mortality) | Female | 110.5 | 123.9 | 0.89; (0.80, 0.99) | 28.8 | 30.3 | 0.87; (0.71, 1.06) | NR | NR | NR
PLCO^130^ | 16.8; (12.1 for all-cause mortality) | Distal | 53.2 | 74.6 | 0.71; (0.64, 0.79) | 10.9 | 21.4 | 0.51; (0.41, 0.63) | NR | NR | NR
PLCO^130^ | 16.8; (12.1 for all-cause mortality) | Proximal | 70.3 | 77.1 | 0.91; (0.83, 1.00) | 18.8 | 19.7 | 0.95; (0.79, 1.14) | NR | NR | NR
PLCO^130^ | 16.8; (12.1 for all-cause mortality) | 55–64 years | 102.1 | 120.6 | 0.85; (0.77, 0.93) | 28.1 | 32.0 | 0.88; (0.73, 1.05) | NR | NR | NR
PLCO^130^ | 16.8; (12.1 for all-cause mortality) | 65–74 years | 171.0 | 215.9 | 0.79; (0.72, 0.88) | 44.4 | 69.6 | 0.64; (0.53, 0.77) | NR | NR | NR
SCORE^140^ | 10.5; (11.4 for CRC mortality) | Male | 190.94 | 216.83 | 0.88; (0.71, 1.09) | NR | NR | NR | NR | NR | NR
SCORE^140^ | 10.5; (11.4 for CRC mortality) | Female | 98.54 | 136.05 | 0.72; (0.55, 0.96) | NR | NR | NR | NR | NR | NR
SCORE^140^ | 10.5; (11.4 for CRC mortality) | Distal | 87.27 | 114.16 | 0.76; (0.62, 0.94) | 18.66 | 25.70 | 0.73; (0.47, 1.12) | NR | NR | NR
SCORE^140^ | 10.5; (11.4 for CRC mortality) | Proximal | 56.84 | 62.27 | 0.91; (0.69, 1.20) | 16.00 | 18.74 | 0.85; (0.52, 1.39) | NR | NR | NR
SCORE^140^ | 10.5; (11.4 for CRC mortality) | Age 60–64 | 157.49 | 199.56 | 0.79; (0.62, 1.00) | NR | NR | NR | NR | NR | NR
SCORE^140^ | 10.5; (11.4 for CRC mortality) | Age 55–59 | 133.70 | 158.95 | 0.84; (0.67, 1.06) | NR | NR | NR | NR | NR | NR
UKFSST^119^ | 17.1 | Male | 166 | 236 | 0.70^*^; (0.65, 0.77) | 48 | 71 | 0.67^*^; (0.57, 0.79) | 1841 | 1835 | 1.00^*^; (0.98, 1.03)
UKFSST^119^ | 17.1 | Female | 111 | 137 | 0.81^*^; (0.73, 0.89) | 31 | 42 | 0.74^*^; (0.61, 0.90) | 1136 | 1163 | 0.98^*^; (0.95, 1.01)
UKFSST^119^ | 17.1 | Distal | 66 | 112 | 0.59^*^; (0.54, 0.64) | Female: 11; Male: 23 | Female: 18; Male: 45 | Female:; 0.61^*^; (0.45, 0.83); Male:; 0.51^*^; (0.41, 0.64) | NA | NA | NA
UKFSST^119^ | 17.1 | Proximal | 68 | 71 | 0.96^*^; (0.87, 1.06) | Female: 19; Male: 23 | Female: 22; Male: 24 | Female:; 0.86^*^; (0.67, 1.10); Male:; 0.95^*^; (0.75, 1.21) | NA | NA | NA
UKFSST^119^ | 17.1 | 55–59 years | 114 | 154 | 0.74^*^; (0.67, 0.82) | 31 | 46 | 0.67^*^; (0.55, 0.81) | 1138 | 1138 | 1.00^*^; (0.97, 1.03)
UKFSST^119^ | 17.1 | 60–64 years | 162 | 216 | 0.75^*^; (0.69, 0.82) | 48 | 66 | 0.72^*^; (0.62, 0.84) | 1821 | 1849 | 0.98^*^; (0.96, 1.01)

* Hazard ratio

Abbreviations: CG = control group; CI = confidence interval; CRC = colorectal cancer; FOBT = fecal occult blood test; IG = intervention group; n = number of participants; NORCCAP = Norwegian Colorectal Cancer Prevention; p-y = person-years; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; RR = relative risk; SCORE = Screening for COlon Rectum; UK = United Kingdom; UKFSST = UK Flexible Sigmoidoscopy Screening Trial; US = United States

Figure 6 Key Question 1: Forest Plot of Flexible Sigmoidoscopy Screening vs. No Screening on Colorectal Cancer Incidence by Location

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; IRR = incidence rate ratio; k = thousand; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; p-y = person-years; UKFSST = United Kingdom Flexible Sigmoidoscopy Screening Trial

Figure 6 shows a forest plot of flexible sigmoidoscopy screening versus no screening on colorectal cancer incidence by location. For distal CRC, the pooled incidence rate ratio is 0.67 with a 95% confidence interval of 0.60 to 0.75. The effect favors the intervention group. For proximal CRC, the pooled incidence rate ratio is 0.93 with a 95% confidence interval of 0.88 to 0.99. The effect favors the intervention group.

Figure 7 Key Question 1: Forest Plot of Flexible Sigmoidoscopy Screening vs. No Screening on Colorectal Cancer Mortality by Location

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; IRR = incidence rate ratio; k = thousand; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; p-y = person-years; UKFSST = United Kingdom Flexible Sigmoidoscopy Screening Trial

Figure 7 shows a forest plot of flexible sigmoidoscopy screening versus no screening on colorectal cancer mortality by location. For distal CRC, the pooled incidence rate ratio is 0.61 with a 95% confidence interval of 0.49 to 0.74. The effect favors the intervention group. For proximal CRC, the pooled incidence rate ratio is 0.90 with a 95% confidence interval of 0.8 to 1.00. The effect favors the intervention group.

##### By Age, Sex, Race/Ethnicity, or Family History

While individual trials reported age-stratified results, age strata were not consistent and none of the trials included participants under age 50 years (Table 8). Overall, there were no statistically significant differences among age groups reported in individual trials.

Reductions in CRC incidence and CRC-specific mortality were greater for men than women (Table 8). The pooled IRR for CRC incidence for men was 0.73 (95% CI, 0.68 to 0.79; I^2^=31%) versus 0.85 for women (95% CI, 0.79 to 0.92; I^2^=12%) (Figure 8). The pooled IRR for CRC mortality for men was 0.67 (95% CI, 0.60 to 0.74; I^2^=0%) versus 0.85 for women (95% CI, 0.72 to 1.00; I^2^=32%) (Figure 9).

Figure 8 Key Question 1: Forest Plot of Flexible Sigmoidoscopy Screening vs. No Screening on Colorectal Cancer Incidence by Sex

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; IRR = incidence rate ratio; k = thousand; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; p-y = person-years; UKFSST = United Kingdom Flexible Sigmoidoscopy Screening Trial

Figure 8 shows a forest plot of flexible sigmoidoscopy screening versus no screening on colorectal cancer incidence by sex. For females, the pooled incidence rate ratio is 0.85 with a 95% confidence interval of 0.79 to 0.92. The effect favors the intervention group. For males, the pooled incidence rate ratio is 0.73 with a 95% confidence interval of 0.68 to 0.79. The effect favors the intervention group.

Figure 9 Key Question 1: Forest Plot of Flexible Sigmoidoscopy Screening vs. No Screening on Colorectal Cancer Mortality by Sex

Abbreviations: CG = control group; CI = confidence interval; IG = intervention group; IRR = incidence rate ratio; k = thousand; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; p-y = person-years; UKFSST = United Kingdom Flexible Sigmoidoscopy Screening Trial

Figure 9 shows a forest plot of flexible sigmoidoscopy screening versus no screening on colorectal cancer mortality by sex. For females, the pooled incidence rate ratio is 0.85 with a 95% confidence interval of 0.72 to 1.00. The effect favors the intervention group. For males, the pooled incidence rate ratio is 0.67 with a 95% confidence interval of 0.60 to 0.74. The effect favors the intervention group.

Trials did not report results by race/ethnicity or family history.

#### Colonoscopy

We found no trials that evaluated the effectiveness of screening colonoscopy on CRC incidence or mortality. We found two fair-quality prospective cohort studies^21,^ ^125^ (n=436,927) that evaluated the impact of receipt of screening colonoscopy on CRC incidence and mortality, one of which is new since the previous review.^125^ Based on a priori inclusion and exclusion criteria, we excluded nested case-control and retrospective studies.

##### Study and Population Characteristics

One fair-quality study^21^ used data from two large prospective cohorts in 1988, the Nurses’ Health Study (57,166 women) and the Health Professionals Follow-up Study (31,736 men). Participants were health professionals who were generally considered average risk; people with a history of cancer, ulcerative colitis, familial polyposis syndromes, previous colorectal polyps, or previous lower endoscopy were excluded. Those with a family history of CRC were included. Ages at the start of the study ranged from 42 to 67 years for women and 42 to 77 years for men. The study analyzed the association between screening colonoscopy and FS and the risk of CRC over 22 years and CRC mortality over 24 years. All analyses were stratified by age and sex, and additional analyses for numerous other risk factors (i.e., obesity, smoking, family history, physical activity, dietary patterns, alcohol use, aspirin and other medication/supplement use) were also evaluated. Investigators conducted additional analyses adjusting for propensity scores to address selection bias.

The other fair-quality study used data from a 20 percent random subsample of Medicare beneficiaries from 1999 to 2012.^125^ Participants were average-risk older adults, ages 70 to 79 years, without a prior history of CRC, adenoma, inflammatory bowel disease, or colectomy, and had not received any prior colonoscopy, FS, or FOBT. The analysis also excluded people who had received an abdominal CT or barium enema; had a diagnosis of anemia, GI bleeding, irritable bowel disease, diverticular disease, or ischemic bowel disease; or had symptoms of diarrhea, constipation, change in bowel habit, or weight loss in the previous 6 months. The study emulated a trial design of screening colonoscopy versus no screening using sequential simulated trials that included 348,025 nonunique individuals (10,034 who had a screening colonoscopy and 337,991 randomly selected people with no screening). The median followup was 40 months. Approximately 25 percent of beneficiaries were followed for more than 5.5 years. Baseline prevalence of CRC was 0.89% (in ages 70–74 years) and 1.14% (in ages 75–79 years) in people who had a screening colonoscopy, and 0.03% (both age groups) in people with no screening. Analyses were adjusted for age, sex, race, utilization of preventive services, geographic location, comorbidities, and calendar month. Beneficiaries who had a screening colonoscopy had a lower proportion of chronic disease and higher proportion of utilization of other preventive services.

##### Outcomes

Both studies demonstrated an association between receipt of screening colonoscopy and lower CRC incidence and mortality compared with no colonoscopy.

In the cohort study of health professionals,^21^ there were 1,815 incident cases of CRC after 22 years of followup. Cancer incidence was lower in people who self-reported a screening endoscopy with polypectomy (multivariate HR, 0.53 [95% CI, 0.40 to 0.71]), negative screening colonoscopy (multivariate HR, 0.47 [95% CI, 0.39 to 0.57]), and negative screening FS (multivariate HR, 0.56 [95% CI, 0.49 to 0.65]) compared with those who had never had a screening endoscopy. During 24 years of followup, there were 474 deaths due to CRC. The CRC-specific mortality rate was lower in people with a self-reported screening colonoscopy (multivariate HR, 0.32 [95% CI, 0.24, 0.45]) and screening FS (multivariate HR, 0.59 [95% CI, 0.45 to 0.76]) compared with those who had never had a screening endoscopy.

In the cohort study of Medicare beneficiaries,^125^ after a median followup of 40 months, 1,282 individuals who had a colonoscopy were diagnosed with CRC, and 45,530 who had no screening were diagnosed with CRC. For people ages 70 to 74 years, the standardized 8-year risk for CRC was 2.19 percent (95% CI, 2.00 to 2.37) if they underwent a screening colonoscopy versus 2.62 percent (95% CI, 2.56 to 2.67) if they were not screened (difference −0.42 percent; 95% CI, −0.24 to −0.63). Likewise, for people ages 75 to 79 years, the standardized 8-year risk for CRC was 2.84 percent (95% CI, 2.54 to 3.13) in people who had a screening colonoscopy versus 2.97 percent (95% CI, 2.92 to 3.03) in people who were not screened (difference −0.14 percent; 95% CI, −0.41 to 0.16). This study did not report any mortality outcomes.

##### By Stage or Location

In the cohort study of health professionals,^21^ the lower cancer incidence in those who had colonoscopies versus no screening was observed at all stages of CRC at presentation. Only a negative screening colonoscopy was associated with reduced incidence of proximal CRC (multivariate HR, 0.74 [95% CI, 0.57 to 0.96]). This study found that screening colonoscopies were associated with reduced CRC mortality from both distal CRC (multivariate HR, 0.18 [95% CI, 0.10 to 0.31]) and proximal CRC (multivariate HR, 0.47 [95% CI, 0.29 to 0.76]), but this was not true for FS.

In a subsample of the cohort study of Medicare beneficiaries who were linked to the SEER registry,^125^ a higher proportion of stage 0 to II cancers and lower proportion of stage IV cancers were observed in people who had a screening colonoscopy compared with people who did not have screening. Outcomes by location were not reported.

##### By Age, Sex, Race/Ethnicity, or Family History

In the cohort study of health professionals,^21^ results related to CRC incidence and mortality were similar for men and women. The inverse association of colonoscopy and CRC was similar among age groups. In people with a first degree relative (FDR) with CRC, the association for CRC mortality was no longer statistically significant after 5 years (multivariate HR 0.91, 95% CI 0.55, 1.52) compared with a sustained association beyond 5 years in people without a family history (multivariate HR 0.43, 95% CI 0.32, 0.58) (p=0.04 for interaction). No subgroup analyses by age were reported.

The cohort study of Medicare beneficiaries reported age-stratified results (as described above) but no other subgroup analyses.

#### CT Colonography

We found no prospective studies evaluating the effectiveness of screening CTC on cancer incidence or mortality.

#### Capsule Endoscopy

We found no prospective studies evaluating the effectiveness of screening capsule endoscopy on cancer incidence or mortality.

### Detailed Results for Effectiveness of Stool Tests

#### gFOBT

We found no new screening trials of gFOBT and one new publication^132^ reporting longer-term followup for a previously included trial. Six previously included, large population screening trials (n=780,458) evaluating the effectiveness of Hemoccult or Hemoccult II are described in Table 9. The Finland trial is ongoing; however, interim findings^132^ with a median 4.5 years of followup did not find a reduction in CRC mortality using biennial gFOBT (Table 10). Based on five RCTs (n=419,966) that used intention-to-screen analyses, biennial screening with gFOBT resulted in a reduction of CRC-specific mortality compared with no screening, ranging from 9 to 22 percentage points after two to nine rounds of screening with 11 to 30 years of followup (RR 0.91 [95% CI, 0.84 to 0.98] at 19.5 years; RR 0.78 [95% CI, 0.65 to 0.93] at 30 years) (Table 10). Based on one of these trials, conducted in the United States, annual screening with gFOBT after 11 rounds of screening resulted in non-statistically significant greater reductions in CRC-specific mortality (RR 0.68 [95% CI, 0.56 to 0.82]) at 30 years than biennial screening (RR 0.78 [95% CI, 0.74, 0.96]). For the same five RCTs with 11 to 28 years of followup, screening did not consistently reduce CRC incidence (RR range from 0.81 to 1.02), with only the trial conducted in Minnesota reporting a statistically significant reduction in CRC incidence (Table 10). None of the trials reported an association of gFOBT screening with all-cause mortality (Table 10). Detailed results are provided in our previous review.^82,^ ^83^ We found no prospective studies evaluating the effectiveness of HSgFOBT on cancer incidence or mortality.

Table 9 Key Question 1: Study and Population Characteristics of Screening gFOBT Trials

Trial, year of publication | Start year | Country | Targeted age, years | Screen frequency | Program n | Rounds | Followup, years | Attendance, round 1 | Attendance, at least 1 round | Test positivity, round 1, pct | Test positivity, all rounds, pct
Burgundy, 2004^124^ | 1988 | FRA | 45–74 | Biennial | IG: 45,642; CG: 45,557 | 6 | 11 | 53 | 70 | 2.1 | 1.5
Funen, 2004^128^ | 1985 | DNK | 45–75 | Biennial | IG: 30,967; CG: 30,966 | 9 | 17 | 67 | 67 | 1.0 | 1.5
Göteborg, 2008^129^ | 1982 | SWE | 60–64 | Varied; (1 to 9 years) | IG: 34,144; CG: 34,164 | 2–3 | 19 | 62 | 70 | 3.8^‡^ | 4.1
Finland, 2015^132^ | 2004 | FIN | 60–69 | Biennial | IG: 180,210; CG: 180,282 | 4^*^ | 4.5 | NR | 69 | NR | 3.6
Nottingham, 2012^138^ | 1981 | GBR | 45–74 | Biennial | IG: 76,056; CG: 75,919 | 3–5 | 28 | 53 | 60 | 2.1 | NR
Minnesota Colon Cancer Control Study, 2013^143^ | 1975 | US | 50–80 | Biennial | IG: 15,587; CG: 15,394 | 6 | 30 (18 for incidence) | NR | 90 | NR^‡^ | NR^†^
Minnesota Colon Cancer Control Study, 2013^143^ | 1975 | US | 50–80 | Annual | IG: 15,570; CG: 15,394 | 11 | 30 (18 for incidence) | NR | 90 | NR^‡^ | NR^†^

* Estimated based on 8.5 years followup and biennial screening

† From 1976 through 1982, the positivity for rehydrated tests was 9.8% and for tests without rehydration was 2.4%.

‡ Study included rehydrated tests: Göteborg – 91.7% of all tests were rehydrated; Minnesota Colon Cancer Control Study – 82.5% of all tests were rehydrated

Abbreviations: CG = control group; CI = confidence interval; CRC = colorectal cancer; DNK = Denmark; FIN = Finland; FRA = France; GBR = Great Britain; IG = intervention group; n = number; NR = not reported; RR = relative risk; SWE = Sweden; US = United States

Table 10 Key Question 1: Results of Screening gFOBT Trials

Trial | Median followup, years | Screening frequency | IG n analyzed | CG n analyzed | CRC Incidence | | | CRC Mortality | | | All-cause Mortality
Trial | Median followup, years | Screening frequency | IG n analyzed | CG n analyzed | IG n | CG n | RR (95% CI) | IG n | CG n | RR (95% CI) | IG n | CG n | RR (95% CI)
Burgundy, 2004^124^ | 11 | Biennial | 45642 | 45557 | 699 | 696 | 1.01; (0.91, 1.12) | 254 | 304 | 0.84; (0.71, 0.99) | NR | NR | NR
Funen, 2004^128^ | 17 | Biennial | 30967 | 30966 | 889 | 874 | 1.02; (0.93, 1.12) | 362 | 431 | 0.84; (0.73, 0.96) | 12,205 | 12,248 | 0.99; (0.97, 1.02)
Göteborg, 2008^129^ | 19 | Variable^*^ | 34144 | 34164 | 721 | 754 | 0.96; (0.86, 1.06) | 252 | 300 | 0.84; (0.71, 0.99) | 10,591 | 10,432 | 1.02; (0.99, 1.06)
Finland, 2015^132^ | 4.5 | Biennial | 180210 | 180282 | 903 | 811 | 1.11^**^; (1.01, 1.23) | 170 | 164 | 1.04^**^; (0.84, 1.28) | 8000 | 7963 | 1.00; (0.97, 1.04)
Nottingham, 2012^138^ | 28 | Biennial | 76056 | 75919 | 2279 | 2354 | 0.97; (0.91, 1.03) | 1176 | 1300 | 0.91; (0.84, 0.98) | 40,681 | 40,550 | 1.00; (0.99, 1.02)
Minnesota Colon Cancer Control Study, 2013^143^ | 30^‡^ | Biennial | 15587 | 15394 | 435 | 507 | 0.85; (0.74, 0.96)^†^ | 237 | 295 | 0.78; (0.65, 0.93) | 11,004 | 10,944 | 0.99; (0.98, 1.01)
Minnesota Colon Cancer Control Study, 2013^143^ | 30^‡^ | Annual | 15570 | 15394 | 417 | 507 | 0.81; (0.71, 0.93)^†^ | 200 | 295 | 0.68; (0.56, 0.82) | 11,072 | 10,944 | 1.00; (0.99, 1.01)

* 1–9 years

† Calculated in Stata using iri; exact confidence interval

** Rate ratio

‡ For CRC incidence, followup was 18 years and IG n analyzed=15550 and CG n analyzed=15363

Abbreviations: CG = control group; CI = confidence interval; CRC = colorectal cancer; IG = intervention group; n = number; NR = not reported; RR = relative risk.

##### By Age, Sex, Race/Ethnicity, or Family History

In three trials—those set in Denmark, Finland, and the United Kingdom— CRC-specific mortality reductions were similar for both males and females.^128,^ ^132,^ ^138^ However, the difference between males and females in the Finland trial^132^ was of borderline significance (p=0.06 for interaction), with a relative risk favoring the screening group for men and a relative risk favoring the unscreened group for women. Similarly, in the Minnesota trial,^143^ men in the biennial screening group had greater CRC-specific mortality reductions compared to women in the biennial screening group at 30 years of followup (p=0.04 for interaction), but this result was not found for the annual screening group (p=0.30 for interaction).

While three trials^124,^ ^128,^ ^138^ recruited adults aged less than 50 years (with 4 to16 percent of the recruited participants aged 45–49 years at the initial screen), none stratified their results by that age group. Two trials^138,^ ^143^ found no statistically significant difference in CRC-specific mortality for those younger than 60 years compared with those older than 60 years.

No subgroup analyses by race/ethnicity or family history were reported.

#### FIT

We found no trials that evaluated the effectiveness of FIT on CRC incidence or mortality. We found one fair-quality prospective cohort study (n=5,417,699) that evaluated a national screening program in Taiwan using biennial FIT in residents ages 50 to 69 years.^122^ This screening program was implemented in a gradual manner due to financial resources and capacity for public health and colonoscopy. The study evaluated the initial 20 percent coverage rate over the first 5 years in which 1,160,895 participants underwent one to three rounds of FIT (OC-Sensor or HM-JACK) and followed for up to 6 years (mean followup time 3.09 years). Outcomes of CRC incidence and CRC deaths were ascertained from the screening database linked to national cancer and death registries. Although the cancer registry has very good coverage and accuracy, there is a delay in reporting (typically 2–3 years). People with an abnormal FIT result were referred to colonoscopy or FS with barium enema; approximately 85 percent of confirmatory exams were colonoscopy. The test positivity rate for the initial round was 4.0 percent and 3.8 percent for those who attended subsequent screening. The CRC detection rate per 1,000 people was 2.5 cancers in the first round and 1.7 cancers in subsequent screening rounds. The unadjusted RR for CRC mortality for screened versus unscreened subjects was 0.38 (95% CI, 0.35 to 0.42) at a mean followup time of 3 years; the adjusted RR for self-selection bias and increasing CRC incidence over time was 0.90 (95% CI, 0.84 to 0.95).

Several other countries have conducted opportunistic evaluations of their regional and national screening programs using FITs. Only a few countries have published studies on the impact of FIT screening using contemporaneous control groups. Three of these studies, which evaluated invited participants versus those not yet invited to screening, were excluded for poor quality because study reporting and followup were very limited, and the only outcome evaluated was stage of CRC at diagnosis.^347–349^ These three studies demonstrated that an invitation to FIT screening resulted in a greater number of cancers detected than no invitation to screening, and/or a higher proportion of early-stage CRC with an invitation to FIT screening compared with no invitation to screening. Many other retrospective studies using historical controls or unscreened controls (without further details or adjustment for confounders) were excluded due to study design.

#### sDNA

We found no prospective studies evaluating the effectiveness of sDNA tests on CRC or mortality.

### Detailed Results for Effectiveness of Serum or Urine Tests

#### Serum Tests

We found no prospective studies evaluating the effectiveness of serum-based screening on CRC incidence or mortality.

#### Urine Tests

We found no prospective studies evaluating the effectiveness of urine-based screening on CRC incidence or mortality.

### Detailed Results for Comparative Effectiveness Trials

In addition to NORCCAP^127^ (as described under Flexible Sigmoidoscopy), we included 20 fair-quality trials (published in 29 articles) that compared different screening tests in average-risk screening populations^120,^ ^121,^ ^123,^ ^126,^ ^127,^ ^131,^ ^133–136,^ ^139,^ ^141,^ ^142,^ ^144–150^ (Table 11). Six of these trials are new since our prior review,^131,^ ^135–137,^ ^149,^ ^150^ although one study^149^ utilized participants from other previously included trials. We also included one fair-quality, large prospective cohort study that was in our previous review which compared gFOBT versus FIT in average-risk screening populations.^123^

Table 11 Key Question 1: Comparative Effectiveness Studies and Included Screening Tests

Author, year; (Trial name) | n; randomized | Colonoscopy | FS; (+/− stool testing) | CTC | gFOBT | FIT
Grobbee, 2019^149^; (COCOS and others^††^) | 30,052 | X | X | | | X
Holme, 2018^127^; (NORCCAP) | | | X
Steele, 2020^150^ | 51,769 | | X^***^ | | X
Schreuders, 2019^139^ | 13,205 | | | | | X^†^
Passamonti, 2018^*^,^131^ | 48,888 | | | | | X
Regge, 2017^*^,^135^; (Proteus 2) | 5,412 | | X | X
Sali, 2016^*^,^136^; (SAVE) | 16,087 | X | | X | | X
Santare, 2016^*^,^137^ | 9,770 | | | | | X
Zubero, 2014^148^ | 37,999 | | | | | X
van Roon, 2013^145^ | 7,501 | | | | | X^‡^
Faivre, 2012^**^,^124^ | 85,149 | | | | X | X
Quintero, 2012^133^; (COLONPREV) | 53,302 | X | | | | X
Stoop, 2012^144^; (COCOS) | 8,844 | X | | X
Hol, 2010^126^ | 15,011 | | X | | X | X
van Rossum, 2008^146^ | 20,623 | | | | X | X
Segnan, 2007^142^; (SCORE III) | 18,114 | X | X | | | X
Segnan, 2005^140^; (SCORE II) | 22,676 | | X | | | X
Rasmussen, 1999^134^ | 10,978 | | X | | X
Verne, 1998^147^ | 3,744 | | X | | X
Berry, 1997^120^ | 6,371 | | X | | X
Brevinge, 1997^121^ | 6,365 | | X | | X

* Newly identified study since the previous review

† Compares the number of samples

‡ Compares the interval of testing

** Cohort study

†† This study combines randomized arms from other included trials. The participants overlap with those in COCOS^144^ and those in Hol, 2010^126^

*** FS with gFOBT for those with a normal FS or those who refused FS

Abbreviations: COCOS = Colonoscopy or Colonography for Screening; CTC = computed tomography colonography; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; n = number; SCORE = Screening for COlon Rectum

Trials and prospective cohort studies included asymptomatic men and women ages 50 to 74 years. The mean age, when reported, ranged from 58 to 62 years. Studies generally excluded people at high risk for CRC due to their symptoms, a personal history of CRC, or a strong family history of CRC. All studies were conducted in western European countries. Most included trials were primarily designed to assess the differential uptake (adherence) of testing and relative detection of colorectal lesions. Although these trials included CRC outcomes, they were not powered to detect differences in CRC incidence and/or mortality. To illustrate, approximately 6,000 participants per arm would be needed to detect a 0.3 percent difference in CRC incidence with 80 percent power, assuming 100 percent adherence. The trials that have been conducted generally had fewer than 6,000 participants per arm with less than 60 percent adherence to testing.

In total, nine studies had explicit primary outcomes of CRC mortality and/or CRC incidence; these include three pragmatic RCTs that were part of FIT-based national screening programs evaluating different FITs or numbers of stool samples,^131,^ ^137,^ ^139^ one RCT^150^ assessing FS as an adjunct to gFOBT within a national screening program, one trial^149^ that utilized colonoscopy, FS, and FIT screening arms from three studies in the Netherlands, one randomized controlled trial^127^ that also compared FS alone to FS with a FIT (NORCCAP, as described under Flexible Sigmoidoscopy), one prospective observational study evaluating Hemoccult II versus FIT,^123^ one active trial^133^ (COLONPREV) comparing FIT with colonoscopy; and one recently completed trial^136^ (SAVE) that looked at FIT versus CTC versus colonoscopy. Several ongoing comparative effectiveness trials that are powered to detect a difference in CRC incidence and/or CRC-specific mortality have not yet reported outcomes; these trials are detailed in Appendix I.

Because most of these studies are limited to the evaluation of a single round of screening, report a low CRC yield (number of cancers detected), and do not report interval cancers, they do not provide robust direct evidence of comparative benefit on CRC incidence or mortality outcomes (Figure 10).

Figure 10 Key Question 1: Forest Plot of Comparative Effectiveness Studies on Colorectal Cancer Incidence

Notes: The sample for Grobbee, 2019 overlaps with samples in Stoop, 2012 and Hol, 2010. In the studies with 0 events, a correction factor of 0.5 was used to allow for RR calculations.

Abbreviations: CI = confidence interval; COCOS = COlonoscopy or COlonography for Screening;; Colo = colonoscopy; CRC = colorectal cancer; CTC = computed tomography colonography; FIT; FS; gFOBT; n = number; RR = relative risk; SCORE = Screening for COlon Rectum

Figure 10 shows a forest plot of comparative effectiveness studies on colorectal cancer incidence. The forest plot shows the relative comparisons between various screening modalities. These comparisons are discussed in the text starting on page 16 in the section “Detailed Results for Comparative Effectiveness Trials.”

#### Direct Visualization vs. Direct Visualization

Only five trials evaluated the comparative effectiveness between different direct visualization screening tests: COCOS^144^ (CTC vs. colonoscopy), SCORE III^142^ (FIT vs. FS vs. colonoscopy), Proteus 2^135^ (CTC vs. FS), and SAVE^136^ (FIT vs. reduced CTC vs. full CTC vs. colonoscopy), and a trial by Grobbee and colleagues that utilized screening arms from other trials (FS vs. colonoscopy) (Appendix D Table 2). None of these trials found a statistically significant difference in the number of cancers detected in each arm (Figure 10); however, they were not powered to do so.

#### Direct Visualization vs. Stool Testing

Eleven trials evaluated the comparative effectiveness between different direct visualization and stool tests (Appendix D Table 3). Nine trials evaluated a stool test versus FS (with or without stool testing). Four trials evaluated FIT versus colonoscopy or CTC: COLONPREV^133^ (FIT vs. colonoscopy), SCORE III^142^ (FIT vs. colonoscopy), SAVE^136^ (FIT vs. [reduced and full bowel prep] CTC vs. colonoscopy), and a study by Grobbee and colleagues utilizing three screening arms from other trials (4 rounds of FIT vs. one-time colonoscopy vs. one-time FS).

Most trials demonstrated that one-time screening with direct visualization detects more CRC than stool testing. However, one study comparing four rounds of FIT to one-time colonoscopy or one-time FS found no difference in CRC detection between modalities^142^ (Figure 10). COLONPREV found no statistically significant differences in the distribution of cancers in the colon between colonoscopy versus FIT; both screening tests found a greater number of distal than proximal cancers. The study by Grobbee and colleagues^149^ found no statistically significant differences between modalities for CRC stage or location. No other subgroups were reported.

#### Stool Testing vs. Stool Testing

Eight studies evaluated the comparative effectiveness between stool tests (Appendix D Table 4). Two trials and one prospective cohort study evaluated gFOBT versus FIT: the Hol trial (Hemoccult II vs. OC-Sensor), van Rossum trial (Hemoccult II vs. OC-Sensor), and Faivre study (Hemoccult II vs. OC-Sensor, FOB Gold and Magstream). These studies showed a higher number of cancers in the FIT versus Hemoccult II test over one to three rounds of screening. Results were only statistically significant in the observational study, likely owing to larger sample sizes and outcomes. None of these studies reported interval cancers. No subgroup analyses by sex or location in colon were reported.

Three trials and one prospective cohort study evaluated one FIT versus another FIT: the Passamonti trial (OC-Sensor vs. HM-JACK), Santare and Zubero trials (OC-Sensor vs. FOB Gold), and Faivre study (OC-Sensor vs. FOB Gold vs. Magstream). Among these studies there was no statistically significant differences in cancers between FIT after one or two rounds of screening, despite some differences in test positivity among the different FITs. None of these studies reported interval cancers. The Passamonti trial^131^ did not find any statistically significant differences in cancer yield by sex or location in the colon between the two FITs.

Two trials and one prospective cohort study evaluated one-sample versus two-sample FITs or FITs at different intervals of testing: the van Roon trial^145^ (OC-Sensor q1 vs. q2 vs. q3 year intervals), Schreuders trial^139^ (OC-Sensor, 1 vs. 2 samples), and Faivre study^123^ (OC-Sensor or FOB Gold, 1 vs. 2 samples). Overall, the number of cancers detected was low and there were no statistically significant differences in the number of cancers detected between the different intervals of testing or different number of samples collected. Over four rounds of screening, the collection of two samples of OC-Sensor versus one sample resulted in a higher colonoscopy demand without a significant increase in cancer yield or decrease in interval cancers.^139^ Additionally there were no meaningful differences in cancer yield by sex or location in the colon between the one-sample versus two-sample FIT.

We found no prospective studies evaluating the comparative effectiveness of sDNA screening on cancer incidence or mortality.

#### Serum or Urine Testing

We found no prospective studies evaluating the comparative effectiveness of serum- or urine-based screening on cancer incidence or mortality.

## KQ2 What Is the Accuracy of Direct Visualization, Stool-Based, or Serum-Based Screening Tests for Detecting Colorectal Cancer, Advanced Adenomas, or Adenomatous Polyps Based on Size? Does the Accuracy of the Screening Tests Vary by Subgroups (e.g., Age, Sex, Race/Ethnicity)?

### Summary of Results

Our review focuses on per-person screening test accuracy for direct visualization tests and stool-, serum- and urine-based testing to detect CRC, advanced adenomas, or both (advanced neoplasia). When available, we also include the per-person test accuracy for adenomas by size (i.e., ≥10 or ≥6 mm). Overall, we found no new studies since our prior review that add to our understanding of screening sensitivity or specificity for colonoscopy, CTC, or flexible sigmoidoscopy. We found several new studies evaluating the sensitivity and specificity of capsule endoscopy and stool-, serum-, and urine-based tests for screening.

#### Direct Visualization Tests

We included nine fair- to good-quality studies evaluating screening CTC, four of which also reported the test accuracy of colonoscopy generalizable to community practice (Table 12).

Table 12 Key Question 2: Summary of Test Accuracy Results^*^ for Direct Visualization Screening Tests

Screening test group | No. of studies | No. of participants | CRC | Adenomas ≥10 mm | | Adenomas ≥6 mm
Screening test group | No. of studies | No. of participants | Sensitivity (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | Sensitivity (95% CI) | Specificity (95% CI)
CTC^†^ | 7 | 5328 | 0.86–1.0; (0.21–1.0) | 0.89; (0.83, 0.96) | 0.94; (0.89, 1.0) | 0.86; (0.78, 0.95) | 0.88; (0.83, 0.95)
Colonoscopy | 4 | 4821 | 0.18–1.0; (0.01, 1.0) | 0.89–0.95; (0.70, 0.99) | 0.89^‡^; (0.86, 0.91) | 0.75–0.93; (0.63,0.96) | 0.94^‡^; (0.92, 0.96)
FS | 0 | NA | NA | NA | NA | NA | NA
Capsule Endoscopy | 2 | 920 | 1.0; (0.34, 1.0) | 0.92–1.0; (0.70, 1.0) | 0.95–0.98; (0.93, 0.99) | 0.91; (0.85, 0.95) | 0.83; (0.80, 0.86)

* Pooled estimates from meta-analysis when available; otherwise range of values and range of the 95% CI reported.

† CTC with bowel preparation. Two studies without bowel preparation were also included.

‡ Only one study reported specificity

Abbreviations: CI = confidence interval; CRC = colorectal cancer; CTC = computed tomography colonography; FS = flexible sigmoidoscopy; IG = intervention group; mm = millimeter; No = number; RR = relative risk

##### Flexible Sigmoidoscopy

There were no studies evaluating the test accuracy of screening flexible sigmoidoscopy.

##### Colonoscopy and CTC

Based on these studies, we know that both colonoscopy and CTC can miss cancers; however, these studies were not powered to estimate the test accuracy for CRC as the number of CRCs in these studies were low.

Based on three studies that compared colonoscopy to a reference standard of CTC-enhanced colonoscopy or repeat colonoscopy (n=2,290), the per-person sensitivity for adenomas 10 mm or larger ranged from 0.89 (95% CI, 0.78 to 0.96) to 0.95 (95% CI, 0.74 to 0.99), and the per-person sensitivity for adenomas 6 mm or larger ranged from 0.75 (95% CI, 0.63 to 0.84) to 0.93 (95% CI, 0.88 to 0.96). Specificity could only be calculated from one of the included studies; it was 0.89 (95% CI, 0.86 to 0.91) for adenomas 10 mm or larger and 0.94 (95% CI, 0.92 to 0.96) for adenomas 6 mm or larger.

Based on seven studies of CTC with bowel preparation (n=5,328), the sensitivity and specificity to detect adenomas 10 mm or larger ranged from 0.67 (95% CI, 0.45 to 0.84) to 0.94 (95% CI, 0.84 to 0.98) and 0.86 (95% CI, 0.85 to 0.87) to 0.98 (95% CI, 0.96 to 0.99), respectively. Likewise, the sensitivity and specificity to detect adenomas 6 mm or larger ranged from 0.73 (95% CI, 0.58 to 0.84) to 0.98 (95% CI, 0.91 to 0.99) and 0.80 (95% CI, 0.77 to 0.82) to 0.93 (95% CI, 0.90 to 0.96), respectively. Although there is some variation in estimates of sensitivity and specificity among included studies, it is unclear whether the variation of test performance is due to differences in study design, populations, CTC imaging, or in reader experience or reading of protocols.

##### Capsule Endoscopy

Based on two fair-quality studies (n=920) evaluating screening capsule endoscopy, the sensitivity to detect adenomas 10 mm or larger ranged from 0.92 to 1.0 (95% CI range, 0.70 to 1.0) and specificity ranged from 0.95 to 0.98 (95% CI range, 0.93 to 0.99). For adenomas 6 mm or larger, one study reported a sensitivity of 0.91 (95% CI, 0.85 to 0.95) and specificity of 0.83 (95% CI, 0.80 to 0.86). However, in both studies, there was a high proportion of persons with inadequate or incomplete capsule endoscopy.

#### Stool Tests

Stool tests to screen for CRC include HSgFOBT (Hemoccult Sensa), FIT (e.g., OC-Sensor, OC-Light), and sDNA-FIT (Cologuard). We included five fair-quality studies evaluating Hemoccult Sensa (two of which used a colonoscopy reference standard for all participants), 44 fair- to good-quality studies evaluating different FITs (25 of which used a colonoscopy reference standard for all), and four fair-quality studies evaluating Cologuard (all 4 used a colonoscopy reference standard) (Table 13).

Table 13 Key Question 2: Summary of Test Accuracy Results^*^ From Studies With Colonoscopy Follow-Up for Stool, Serum, and Urine Screening Tests

Screening test group | No. of studies | No. of participants | CRC | | AN | | AA
Screening test group | No. of studies | No. of participants | Sensitivity (95% CI) | Specificity (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | Sensitivity (95% CI) | Specificity (95% CI)
Hemoccult Sensa | 2 | 3,503 | 0.50–0.75; (0.09, 1.0) | 0.96–0.98; (0.95, 0.99) | 0.07–0.21; (0.02, 0.27) | 0.96–0.99; (0.96, 0.99) | 0.06–0.17; (0.02, 0.23) | 0.96–0.99; (0.96, 0.99)
OC-Sensor | 13^†^ | 44,887 | 0.74; (0.64, 0.83) | 0.94; (0.93, 0.96) | 0.25; (0.21, 0.31) | 0.96; (0.95, 0.97) | 0.23; (0.20, 0.25) | 0.96; (0.95, 0.97)
OC-Light | 4 | 32,424 | 0.81; (0.70, 0.91) | 0.93; (0.91, 0.96) | 0.27; (0.16, 0.38) | 0.95; (0.92, 0.98) | 0.28; (0.19, 0.37) | 0.94; (0.91 to 0.97)
Other FITs | 12^†^ | 53,527 | 0.50–0.97 (0.09, 1.00) | 0.83–0.97; (0.82, 0.97) | 0.02–0.66; (0.01, 0.99) | 0.60–0.99; (0.58, 1.0) | 0.18–0.50; (0.13 to 0.56) | 0.85–0.98; (0.84 to 0.98)
Cologuard | 4 | 12,424 | 0.93; (0.87,1.0) | 0.85; (0.84, 0.86) | 0.47; (0.44, 0.50) | 0.89; (0.87, 0.92) | 0.43; (0.40, 0.46) | 0.89; (0.86, 0.92)
Epi proColon | 1 | 6857 | 0.68; (0.53, 0.80) | 0.79; (0.77, 0.81) | 0.25; (0.22, 0.28) | 0.79; (0.76, 0.82) | 0.22; (0.18, 0.24) | 0.79; (0.76, 0.82)
PolypDx | 1 | 228 | NR | NR | 0.43; (0.30, 0.57) | 0.91; (0.87, 0.96) | NR | NR

* Pooled estimates and 95% CI from meta-analysis when available; otherwise range of values and range of the 95% CIs reported.

† One nested case control study^171^ is not represented in this table (n=516).

Abbreviations: AA = advanced adenoma; AN = advanced neoplasia; CI = confidence interval; CRC = colorectal cancer; CTC = computed tomography colonography; FIT = fecal immunochemical test; gFOBT = guaiac fecal occult blood test; No = number; NR = not reported

##### High-Sensitivity gFOBT

Based on two studies (n=3,503) of Hemoccult Sensa using colonoscopy as a reference standard, sensitivity to detect CRC ranged from 0.50 to 0.75 (95% CI range, 0.09 to 1.0) and specificity ranged from 0.96 to 0.98 (95% CI range, 0.95 to 0.99). Sensitivity to detect CRC from two studies (n=10,170) employing a cancer registry followup ranged from 0.62 to 0.79 (95% CI range, 0.36 to 0.94). Hemoccult Sensa was not sensitive to detect AA (sensitivity range 0.06 to 0.17; 95% CI range, 0.02 to 0.23).

##### FIT

A wide variety of FITs are available. Those most commonly evaluated in our review were part of the OC-Sensor family (Polymedco in the United States or Eiken Chemical outside of the United States); in the included studies they were referred to as: OC FIT-CHEK, OC-Auto, OC-Micro, OC-Sensor, and OC-Sensor Micro. Additionally, the OC-Light test (also by the same manufacturer but using a different methodology) and the OC-Hemodia (also by the same manufacturer but discontinued) tests were evaluated in more than two studies. Twenty-one other tests were evaluated in two or fewer studies. Based on nine studies (n=34,352) using OC-Sensor tests to detect CRC with a colonoscopy reference standard and the manufacturer-recommended cutoff of 20 μg Hb/g feces, pooled sensitivity was 0.74 (95% CI, 0.64 to 0.83; I^2^=31.6%) and pooled specificity was 0.94 (95% CI, 0.93 to 0.96; I^2^=96.6%). As expected at lower cutoffs (10 and 15 μg Hb/g feces), sensitivity increased and the corresponding specificities decreased. Based on 10 studies (n=40,411) using OC-Sensor tests to detect AA with a colonoscopy reference standard, sensitivity and specificity using a cutoff of 20 μg Hb/g feces were 0.23 (95% CI, 0.20 to 0.25; I^2^=47.4%) and 0.96 (95% CI, 0.95 to 0.97; I^2^=94.8), respectively. Based on three studies (n=31,803), OC-Light had similar sensitivity and specificity to detect CRC and AA compared with OC-Sensor. Only four studies using registry follow-up reported test accuracy of FITs over multiple rounds of testing; in two of these studies, sensitivity to detect cancer was lower in the second round of screening, however estimates were imprecise with confidence intervals widely overlapping. While studies examining differences in test accuracy by age, sex, and race/ethnicity were limited, we found no consistent differences by subgroup. Overall, in 10 studies there were no significant differences in test accuracy by age strata, although 2 studies suggest possible lower specificity to detect CRC in older persons (age 70 years and older). Six studies reporting test accuracy by sex had inconsistent findings, with two studies of OC-Sensor which suggest higher sensitivity with lower specificity in men compared with women.

##### sDNA

Currently, the only available sDNA screening test is one with a FIT assay marketed as Cologuard (Exact Sciences; Madison, WI), sometimes referred to as a multitarget stool DNA test. Based on four studies (n=12,424) to detect CRC using a colonoscopy, pooled sensitivity and specificity was 0.93 (95% CI, 0.87 to 1.0) and 0.85 (95% CI, 0.84 to 0.86), respectively; pooled sensitivity and specificity to detect AA was 0.43 (95% CI, 0.40 to 0.46) and 0.89 (95% CI, 0.86 to 0.92), respectively. Based on one study, the specificity to detect CRC and AA decreases with increasing age.

#### Serum Test

Currently, one serum test—Epi proColon (Epigenomics, Germantown, MD)—is available to screen average-risk adults for CRC through detection of circulating methylated SEPT9 DNA. Based on one fair-quality nested case-control study (n=6857), sensitivity and specificity to detect CRC were 0.68 (95% CI, 0.53 to 0.80) and 0.79 (95% CI, 0.77 to 0.81), respectively. The sensitivity and specificity to detect AA were 0.22 (95% CI, 0.18 to 0.24) and 0.79 (95% CI, 0.76 to 0.82), respectively.

#### Urine Test

We identified one urine test to detect adenomas, a metabolomic-based urine test called PolypDx (Metabolomic Technologies Inc., Edmonton, Canada) that combines three clinical features (age, sex, and smoking status) with three urine metabolites (succinic acid, ascorbic acid, and carnitine). Based on one fair-quality study (n=685) in average and high-risk participants (i.e., personal or family history of CRC or polyps), the sensitivity and specificity to detect AN in the testing dataset (n=228) were 0.43 (95% CI range, 0.30 to 0.57) and 0.91 (95% CI range, 0.87 to 0.96), respectively; however, multiple thresholds were evaluated and higher sensitivities could be obtained with a tradeoff in specificity.

### Detailed Results for Direct Visualization Tests

#### Flexible Sigmoidoscopy

We identified no studies evaluating the test performance of FS with a colonoscopy reference standard in average-risk screening populations.

#### CT Colonography

We found nine test accuracy studies^169,^ ^172,^ ^177,^ ^178,^ ^181,^ ^184,^ ^188,^ ^195,^ ^205^ in 10 articles^169,^ ^172,^ ^177,^ ^178,^ ^181,^ ^184,^ ^188,^ ^195,^ ^205,^ ^350^ that evaluated CTC as a screening test to detect colorectal lesions in asymptomatic average-risk people (Table 12). All of these studies were included in the previous review.^82,^ ^83^

##### Study and Population Characteristics

Six (n=5,453) of the nine studies were conducted in the United States (Table 14).^169,^ ^177,^ ^178,^ ^188,^ ^195,^ ^205^ Three of them (n=4,369) were multicenter trials.^177,^ ^195,^ ^205^ The sample sizes for the nine studies ranged from 68 to 2,531. While four studies included people age 40 years and older,^169,^ ^178,^ ^181,^ ^195^ two of them^181,^ ^195^ required a family history for people ages 40 to 50 years. The mean age spanning all studies ranged from 55 to 65 years. All trials excluded people with familial hereditary CRC syndromes, and two trials also explicitly excluded people with family history of CRC in first-degree relatives.^172,^ ^188^ The baseline prevalence of cancer in the populations ranged from 0.16 to 1.1 percent. The proportion of female participants ranged from 41 to 60 percent, except for one small trial (n=68) conducted exclusively in men in a VA medical center setting.^188^ Four studies reported race/ethnicity;^169,^ ^177,^ ^178,^ ^205^ 83 to 91 percent of participants in those studies were white.

Table 14 Key Question 2: Study and Population Characteristics for CTC and Colonoscopy Test Accuracy Studies

Bowel prep | Author, year; Quality | Country | Number screened | Prevalence, n (%) | Age, mean | Female, % | Race/Ethnicity, % | Family history^††^, % | CTC protocol | Colonoscopy Practitioners | Reference standard
With bowel prep | Lefere, 2013^184^; Fair | PRT | 496 | CRC: 4 (0.8); AA: 28 (5.6); A10: NR; A6: 49 (9.9) | 60 | 60 | NR | NR | Fecal tagging: Y; Number of Readers: 1; Training: >5000 exams; Reading strategy: 3D (with 2D) | n = 5; Experience: ≥15 years | Repeat colonoscopy if indicated
With bowel prep | Graser, 2009^172^; Good | DEU | 307 | CRC: 1 (0.3); AA: 29 (9.4); A10: 24 (7.8); A6: 45 (14.6) | 60 | 45 | NR | 0 (FDR diagnosed before 60 or 2 at any age) | Fecal tagging: N; Number of Readers: 3; Training: >300 exams; Reading strategy: 3D (with 2D) | n = 6; Experience: 1000 colonoscopies | Colonoscopy with segmental unblinding
With bowel prep | Johnson, 2008^177^; Good | US | 2531 | CRC: 7 (0.3); AA: NR; A10: 102 (4.0); A6: 203 (8.0) | 58 | 52 | White 83^*^; Black: 13; AI/AN: 0.9; Asian/PI: 3; Hispanic: 4 | 9 | Fecal tagging: Y; Number of Readers: 15; Training: >500 exams^†^; Reading strategy: 3D (with 2D) | n = NR; Experience: Performed or supervised by experience GE or surgeon | Repeat colonoscopy if indicated^‡^
With bowel prep | Kim, 2008^181^; Fair | KOR | 241 | CRC: 1 (0.4); AA: 16 (6.6); A10: 10 (4.1)^§^; A6: 44 (18.2)^∥^ | 58 | 49 | NR | 5 | Fecal tagging: N; Number of Readers: 2; Training: >100 exams; Reading strategy: 2D (with 3D) | n = 5; Experience: NR | Single colonoscopy
With bowel prep | Johnson, 2007^178^; Fair | US | 452 | CRC: 5 (1.1); AA: NR; A10: 21 (4.6); A6: 51 (11.3) | 65 | 44 | White: 85; Asian/PI: 12; Hispanic: 3; Black: 1; AI/AN: 0.2 | NR | Fecal tagging: N; Number of Readers: 3; Training: >1000 exams; Reading strategy: 3D (with 2D)^¶^ | n = NR; Experience: Performed or supervised by experience GE or surgeon | Repeat colonoscopy if indicated ^‡^
With bowel prep | Macari, 2004^188^; Fair | US | 68 | CRC: NR; AA: NR; A10: 3 (4.4)^**^; A6: NR | 55 | 0 | NR | 0 | Fecal tagging: N; Number of Readers: 1; Training: 5 years of experience; Reading strategy: NR | n = 1 GE and trainees; Experience: 5 years | Single colonoscopy
With bowel prep | Pickhardt, 2003^195^; Good | US | 1233 | CRC: 2 (0.16); AA: NR; A10: 46 (3.7); A6: 166 (13.5) | 58 | 41 | NR | 2.6 | Fecal tagging: Y; Number of Readers: 6; Training: >25 exams; Reading strategy: 3D (with 2D) | n = 17; Experience: NR | Colonoscopy with segmental unblinding^‡^
Without bowel prep | Fletcher, 2013^169^; Good | US | 564 | CRC: 1 (0.2); AA: 25 (4.4); A10: 15 (2.6); A6: 36 (6.4) | NR | 58 | White: 91; Asian/PI: 4; Black: 2; Hispanic: 2; AI/AN: 0.2 | 7 | Fecal tagging: Y; Number of Readers: 2; Training: >150 exams; Reading strategy: 2D and 3D | n = NR; Experience: NR – staff GE | Single colonoscopy
Without bowel prep | Zalis, 2012^205^; Good | US | 605 | CRC: 3 (0.5); AA: NR; A10: 19 (3.1); A6: 71 (11.7) | 60 | 47 | White: 90; Asian/PI: 2; Black: 4; AI/AN: <1; Hispanic: 2 | 18 | Fecal tagging: Y; Number of Readers: 3; Training: >200 exams; Reading strategy: 2D and 3D | n = NR; Experience: NR – GE | Colonoscopy with segmental unblinding^‡^

* Participants could select more than one race/ethnicity category

† Or 1.5 day training session

‡ Test accuracy for colonoscopy in addition to CTC.

§ Any histology ≥10 mm

∥ Any histology ≥6 mm;

¶ Study evaluated different reading strategies, data shown reflect primary 3D strategy

** For polyps ≥10 mm

†† Family history variably defined: FDR diagnosed before 60 or 2 at any age (Graser), FDR with CRC (Kim, Macari, Johnson), family history of CRC (Pickhardt), family history of colorectal neoplasia (Fletcher), family history of CRC or polyps (Zalis).

Abbreviations: AA = advanced adenoma; A6 = adenoma ≥6 mm; A10 = adenoma ≥10 mm; Adenoma CRC = colorectal cancer; DEU = Germany; GE = gastroenterologist; KOR = Korea; n = number; N = no; NR = not reported; PRT = Portugal; US = United States; Y = yes; 2D = two dimensional; 3D = three dimensional.

All included studies evaluated multidetector CTC using supine and prone imaging positions, although protocols for bowel preparation, imaging, and reading images varied among studies. Seven studies (n=5,328) evaluated CTC with bowel preparation with^177,^ ^184,^ ^195^ or without fecal tagging,^172,^ ^178,^ ^181,^ ^188^ and two studies (n=1,169) evaluated CTC without bowel preparation and with fecal tagging.^169,^ ^205^ Bowel preparation varied among studies (from full preparation with polyethylene glycol and magnesium citrate to more limited preparation using sodium phosphate and/or sodium picosulfate). One study^181^ administered intravenous contrast as part of the CTC protocol. There was also variation in the number of detectors, reconstruction interval, collimation, and slice thickness. One trial^177^ used a large sample of CTC readers (15 radiologists). While readers generally used a combination of two- and three-dimensional reading strategies, the primary reading strategy varied. The test positivity (at least one lesion 5 or 6 mm or larger) for people undergoing screening CTC ranged from 10 to 30 percent.

All nine studies used colonoscopy as the reference standard. Only three of the studies,^172,^ ^195,^ ^205^ however, used CTC-enhanced colonoscopy (i.e., colonoscopy with segmental unblinding). Colonoscopies were generally provided by staff gastroenterologists with cecal intubation ranging from 94 to 100 percent.

Five studies were good quality^169,^ ^172,^ ^177,^ ^195,^ ^205^ and the remaining four were fair quality. Limitations of fair-quality studies included limited reporting on study details (e.g., attrition, exclusions due to inadequate CTC or colonoscopy), a small number of included participants, and, in one study, attribution of lesions seen on CTC but not colonoscopy as false-positives.

#### CT Colonography With Bowel Preparation

##### Test Accuracy for CRC

Six studies reported the per-person sensitivity of CTC with bowel preparation to detect CRC; however, the number of cancers was low, ranging from one to seven (Table 15). Sensitivity ranged from 0.86 to 1.0 (95% CI range, 0.21 to 1.0).

Table 15 Key Question 2: Results for CT Colonography Test Accuracy

Bowel prep | Author, year | Number screened | Prevalence, n (%) | CRC | Advanced adenoma | | Adenoma ≥10 mm | | Adenoma ≥6 mm
Bowel prep | Author, year | Number screened | Prevalence, n (%) | Sensitivity (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | Sensitivity (95% CI) | Specificity (95% CI)
With bowel prep | Lefere, 2013^184^ | 496 | CRC: 4 (0.8); AA: 28 (5.6); A10: NR; A6: 49 (9.9) | 1.0; (0.51, 1.0) | 1.0; (0.87, 1.0) | 0.87; (0.84, 0.90) | NR | NR | 0.98; (0.89, 1.0) | 0.91; (0.88, 0.93)
With bowel prep | Graser, 2009^172^ | 307 | CRC: 1 (0.33); AA: 29 (9.4); A10: 24 (7.8); A6: 45 (14.6) | 1.0; (0.21, 1.0) | 0.97; (0.83, 0.99) | 0.39; (0.34, 0.45) | 0.92; (0.74, 0.99) | 0.98; (0.95, 0.99) | 0.91; (0.79, 0.98) | 0.93; (0.89, 0.96)
With bowel prep | Johnson, 2008^177^ | 2531 | CRC: 7 (0.28); AA: NR; A10: 102 (4.0); A6: 203 (8.0) | 0.86; (0.49, 0.97) | NR | NR | 0.90; (0.83, 0.95) | 0.86; (0.85, 0.87) | 0.78; (0.72, 0.83) | 0.88; (0.87, 0.89)
With bowel prep | Kim, 2008^181^ | 241 | CRC: 1 (0.4); AA: 16 (6.6); A10: 10 (4.1); A6: 44 (18.3) | 1.0; (0.21, 1.0) | 0.88; (0.64, 0.96) | NR | 0.87^*^,^†^; (0.62, 0.96) | 0.97^*^,^†^; (0.94, 0.99) | 0.68^*^,^†^; (0.55, 0.79) | 0.88^*^,^†^; (0.84, 0.92)
With bowel prep | Johnson, 2007^178^ | 452 | CRC: 5 (1.1); AA: NR^*^; A10: 21 (4.6); A6: NR 51 (11.3) | 1.0; (0.56, 1.0) | NR | NR | 0.67; (0.45, 0.83) | 0.98; (0.96, 0.99) | NR | NR
With bowel prep | Macari, 2004^188^ | 68 | CRC: NR; AA: NR; A10: 3 (4.4)^*^; A6: NR | NR | NR | NR | 1.0^*^; (0.44, 1.0) | 0.98^*^; (0.92, 1.0) | NR | NR
With bowel prep | Pickhardt, 2003^195^ | 1233 | CRC: 2 (0.16); AA: NR^*^; A10: 46; A6: 166 | 1.0; (0.34, 1.0) | NR | NR | 0.94; (0.82, 0.98) | 0.96; (0.95, 0.97) | 0.89; (0.83, 0.93) | 0.80; (0.77, 0.82)
Without bowel prep | Fletcher, 2013^169^ | 564 | CRC: 1 (0.18); AA: 25 (4.4); A10: 15 (2.6); A6: 36 (6.4) | 1.0; (0.03, 1.0) | 0.64; (0.44, 0.80) | NR | 0.67; (0.42, 0.85) | 0.97; (0.96, 0.98) | 0.75; (0.59, 0.86) | 0.92; (0.90, 0.94)
Without bowel prep | Zalis, 2012^205^ | 605 | CRC: 3 (0.5); AA: NR; A10: 19 (3.1); A6: 71 (11.7) | 1.0 (0.44, 1.0) | NR | NR | 0.90; (0.69, 0.97) | 0.85; (0.82, 0.88) | 0.58; (0.46, 0.69) | 0.88; (0.85, 0.91)

* Any histology

† Sensitivity for adenomas ≥6 mm 0.73 (95% CI, 0.57 to 0.85); Sensitivity for adenomas ≥10 mm 0.9 (95% CI, 0.56 to 1.0)

Abbreviations: AA = advanced adenoma; A6 = adenoma ≥6 mm; A10 = adenoma ≥10 mm; CI = confidence interval; CRC = colorectal cancer; n = number; NR = not reported.

##### Test Accuracy for AA

Three studies^172,^ ^181,^ ^184^ evaluating CTC with bowel preparation (n=1,044) reported accuracy to detect advanced adenomas, although only two of the studies^172,^ ^184^ reported both sensitivity and specificity. The per-person sensitivity and specificity to detect advanced adenomas ranged from 0.88 to 1.0 (95% CI range, 0.66 to 1.0) and 0.39 to 0.87 (95% CI range, 0.34 to 0.90), respectively.^172,^ ^181,^ ^184^ Test accuracy specifically for SSLs were not reported.

##### Test Accuracy for Adenomas by Size

Among five included studies using bowel preparation (n=4,764), the per-person sensitivity for adenomas 10 mm or larger ranged from 0.67 to 0.94 (95% CI range, 0.45 to 0.99) and specificity ranged from 0.86 to 0.98 (95% CI, 0.85 to 0.99). The pooled estimate for sensitivity was 0.89 (95% CI, 0.83, 0.96; I^2^=41.7%) and for specificity was 0.94 (95% CI, 0.89 to 1.0; I^2^=98.3%) (Figure 11).

Figure 11 Key Question 2: Forest Plot of CT Colonography With Bowel Prep Sensitivity and Specificity for Adenomas ≥10 mm

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; TN = true negative; TP = true positive

Note: I^2^=41.7% for sensitivity; I^2^=98.3% for specificity

Figure 11 shows a forest plot of CT colonography with bowel prep sensitivity and specificity for adenomas ≥10 mm. The pooled sensitivity is 0.89 with a 95% confidence interval of 0.83 to 0.96. The pooled specificity is 0.94 with a 95% confidence interval of 0.89 to 1.00.

The per-person sensitivity for adenomas 6 mm or larger among five included studies using bowel preparation (n=4,808) ranged from 0.73 to 0.98 (95% CI range, 0.57 to 1.0).^172,^ ^177,^ ^181,^ ^184,^ ^195^ Among four studies using bowel preparation (n=4,567), the per-person specificity for adenomas 6 mm or larger ranged from 0.80 to 0.93 (95% CI range, 0.77 to 0.96).^172,^ ^177,^ ^184,^ ^195^ The pooled estimate for sensitivity was 0.86 (95% CI, 0.78 to 0.95; I^2^=87.4%) and for specificity was 0.88 (95% CI, 0.83 to 93; I^2^=94.9%) (Figure 12).As described above, there is variation among CTC imaging and reading protocols, as well as variation in the study design and population characteristics among the studies. Because of the limited number of studies and the number of variables contributing to clinical heterogeneity, the key determinants accounting for the variation in test performance are still unclear. There is some evidence to suggest that fecal tagging improves sensitivity. It is unclear from this body of evidence whether primary two- or three-dimensional reading strategy or radiologist choice of primary reading strategies improves sensitivity.

Figure 12 Key Question 2: Forest Plot of CT Colonography With Bowel Prep Sensitivity and Specificity for Adenomas ≥6 mm

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; TN = true negative; TP = true positive

Note: I^2^=87.4% for sensitivity; I^2^=94.9% for specificity

Figure 12 shows a forest plot of CT colonography with bowel prep sensitivity and specificity for adenomas ≥6 mm. The pooled sensitivity is 0.86 with a 95% confidence interval of 0.78 to 0.95. The pooled specificity is 0.88 with a 95% confidence interval of 0.83 to 0.93.

##### By Stage or Location

Four studies of CTC with bowel preparation reported on the distribution of lesions in the colon.^172,^ ^177,^ ^184,^ ^195^ The percent of adenomas 10 mm or larger in the distal colon was 49 to 73 percent, and the percent of adenomas 6–9 mm was 48 to 66 percent. Only one study reported sensitivity and specificity of lesions by location in the colon^172^; the sensitivity for advanced adenomas did not vary significantly by location (proximal, 0.89% [95% CI, 0.59 to 0.99] vs. distal, 0.92 [95% CI, 0.76 to 0.98]).

##### By Age, Sex, Race/Ethnicity, or Family History

One study^177^ reported post hoc analyses for sensitivity and specificity by age in a subsequent publication.^350^ This study found nonstatistically significant lower per-person sensitivities for the detection of adenomas or cancers in people age 65 years and older (n=477) compared with those younger than age 65 years (n=2,054). The per-person sensitivity for adenomas or cancers 10 mm or larger in older adults compared with middle-aged adults was 0.82 (95% CI, 0.64 to 0.94) and 0.92 percent (95% CI, 0.84 to 0.97), respectively. Likewise, the per-person sensitivity for adenomas or cancers 6 mm or larger in older adults compared with middle-aged adults was 0.72 (95% CI, 0.56 to 0.85) and 0.81 (95% CI, 0.74 to 0.88), respectively. The authors noted that there were differences in bowel preparation and distention by age group.

No other subgroups were reported.

#### CTC Without Bowel Preparation

Two studies (n=1,169) evaluated CTC performance without bowel preparation but with fecal tagging (Tables 13 and 14).^169,^ ^205^ Both studies were good quality and conducted in the United States. Neither study was designed to estimate the test accuracy to detect CRC, as the total number of CRC cases was very low (4 cancers). One study (n=564), which was conducted by Fletcher and colleagues,^169^ reported per-person sensitivity and specificity for detection of adenomas 6 mm or larger and for adenomas 10 mm or larger that appeared comparable to those studies using bowel preparation, although the sensitivity for detection of advanced neoplasia was lower at 65.3 percent (95% CI, 44.3 to 82.8). In the second study (n=605), conducted by Zalis and colleagues,^205^ the per-person sensitivity and specificity for detection of adenomas 10 mm or larger appeared comparable to those studies using bowel preparation, although the sensitivity for adenomas 6 mm or larger was lower (57.7% [95% CI, 45.4 to 69.4]). This study did not report test performance for advanced adenomas or advanced neoplasia. Given the clinical heterogeneity among studies with and without bowel preparation, it is unclear from these two studies whether lower sensitivities for detection of certain lesions are due to lack of bowel preparation use or other differences in study design, population, or CTC protocol. No additional results by stage, location, or subgroups were reported.

#### Colonoscopy

We found no tandem colonoscopy studies that met our inclusion criteria requiring screening colonoscopy performance representative of community practice. Seven of the included diagnostic accuracy studies evaluating CTC also reported on sensitivity and/or specificity of colonoscopy. Four of these studies (n=4,821) included a larger number of endoscopists and have greater applicability to colonoscopy performance in community practice (Table 12).^177,^ ^178,^ ^195,^ ^205^ All of these studies were included in the previous review.

##### Study and Population Characteristics

All four of the included studies were conducted in the United States (Table 14). Three of these studies (n=4,369) were multicenter.^177,^ ^178,^ ^205^ All studies recruited similar populations of asymptomatic, average-risk adults age 50 years or older. Two studies also included people age 40 years and older with or without a family history.^178,^ ^195^ The mean age in studies ranged from 58 to 65 years. The baseline prevalence of cancer in the populations ranged from 0.16 to 1.1 percent. Two studies included more than 15 percent nonwhite participants.^177,^ ^178^

One study reported the number of endoscopists; the others either suggested a large number of endoscopists without reporting the actual number or were conducted in multiple clinical sites. All studies stated that colonoscopies were conducted (or supervised) by an experienced gastroenterologist or surgeon. Two studies reported the cecal intubation rate (both ≥99%).^178,^ ^195^

Studies were rated as fair- to good quality. The studies primarily aimed at determining the test accuracy of CTC, which also provided data to calculate the per-person and/or per-lesion sensitivity for CRC and adenomas. Two studies used colonoscopy enhanced with CTC as their criterion standard.^195,^ ^205^ In this study design, colonoscopy was performed after CTC examination and interpretation, with unblinding of CTC results after examination of each segment of the colon. For any suspected lesion on CTC that measured larger than 5 mm and was not seen on the initial “blinded” colonoscopy, the endoscopists re-examined that segment and could review the CTC image for guidance. In the other two studies, participants could have a repeat colonoscopy if indicated by CTC.^177,^ ^178^ Despite this approach, however, not all participants advised to have a repeat colonoscopy received one. In the American College of Radiology Imaging Network (ACRIN) National CT Colonography Trial, for example, only 12 of the 27 people who were recommended to receive a repeat colonoscopy for lesions detected on CTC actually received the second colonoscopy.^177^

##### Test Accuracy for CRC

In two trials (n=1,685), colonoscopy missed CRCs (Table 16).^178,^ ^195^ In one fair-quality study (n=452) conducted by Johnson and colleagues, the colonoscopy was performed or supervised by one of 50 staff gastroenterologists or surgeons blinded to CTC findings.^178^ In this study, repeat colonoscopy was performed on six patients in whom lesions 10 mm or larger were missed that were deemed by consensus to have a high likelihood of being a true neoplasm. Because four of the missed lesions were later determined to be adenocarcinomas, the index colonoscopy only detected one of the five CRC cases. In another study (n=1,233), conducted by Pickhardt and colleagues, colonoscopy was conducted by one of 17 experienced gastroenterologists or surgeons blinded to CTC findings.^195^ In this study, index colonoscopy results were compared with colonoscopy with segmental unblinding. Colonoscopy detected one of two CRC cases.

Table 16 Key Question 2: Results for Colonoscopy Test Accuracy

Author, year | Number screened | Prevalence, n (%) | CRC | Adenoma; ≥10 mm | | Adenoma; ≥6 mm
Author, year | Number screened | Prevalence, n (%) | Sensitivity (95% CI) | Sensitivity (95% CI) | Specificity (95% CI) | Sensitivity (95% CI) | Specificity (95% CI)
Zalis, 2012^205^ | 605 | CRC: 3 (0.5); A10: 19 (3.1); A6: 71 (11.7) | 1.0 (0.29, 1.0) | 0.95 (0.74, 0.99)^*^ | 0.89 (0.86, 0.91) | 0.75 (0.63, 0.84)^†^ | 0.94 (0.92, 0.96)
Johnson, 2008^177^ | 2531 | CRC: 7 (0.28); A10: 102 (4.0); A6: 203 (8.0) | 1.0 (0.59, 1.0)^‡^ | 0.98 (0.93, 1.0)^‡^ | NR | NR | NR
Johnson, 2007^178^ | 452 | CRC: 5 (1.1); A10: 21 (4.6); A6: NR | 0.18 (0.01, 0.72)^§^ | 0.90 (0.70, 0.99)^§^ | NR | NR | NR
Pickhardt, 2003^195^ | 1233 | CRC: 2 (0.16); A10: 46 (3.7); A6: 166 (13.5) | 0.50 (0.01, 0.99)^§^ | 0.89 (0.78, 0.96)^§^ | NR | 0.93 (0.88, 0.96)^∥^ | NR

* Per lesion = 0.96 (0.77, 1.0)

† Per lesion = 0.76 (0.66, 0.84)

‡ Per lesion

§ Same sensitivity per lesion

∥ Per lesion = 0.90 (0.86, 0.94)

Abbreviations: AA = advanced adenoma; CI = confidence interval; CRC = colorectal cancer; n = number NR = not reported.

##### Test Accuracy for AA

Sensitivity and specificity for AN or AA were not reported.

##### Test Accuracy for Adenomas by Size

Per-person and per-lesion sensitivity and specificity for adenomas did not differ significantly by study, and per-lesion accuracy was more commonly reported (Table 16). The per-person sensitivity for adenomas 10 mm or larger ranged from 0.89 to 0.95 (95% CI range, 0.70 to 0.99) and the per-person sensitivity for adenomas 6 mm or larger ranged from 0.75 to 0.93 (95% CI range, 0.63 to 0.96). The per-lesion (per-person sensitivity not reported) sensitivity of colonoscopy in ACRIN for adenomas 10 mm or larger was 0.98 percent (95% CI, 0.93 to 1.0).^177^ Specificity could only be calculated in one of the included studies. This good-quality study (n=605) by Zalis and colleagues^205^ observed a per-person specificity for adenomas 10 mm or larger of 0.89 (95% CI, 0.86 to 0.91) and 0.94 (95% CI, 0.92 to 0.96) for adenomas 6 mm or larger.^205^

##### By Stage, Location, Age, Sex, Race/Ethnicity, or Family History

No subgroup results by age, sex, race/ethnicity, or family history were reported.

#### Capsule Endoscopy

We identified two studies evaluating the test performance of the second-generation colon capsule endoscopy, or PillCam™ COLON 2 (Given Imaging Ltd., Yoqneam, Israel) in participants scheduled for a screening colonoscopy.^198^

##### Study and Population Characteristics

One study took place in the United States and Israel and analyzed 695 participants (of 884 recruited); the other was conducted in the Czech Republic and analyzed 225 participants (of 236 recruited). Mean age ranged from 57 to 59 years, and 47 to 56 percent were female. Participants with a family history were excluded from both studies. Prevalence of CRC ranged from 0.6 to 0.9 percent, and 4.0 to 6.2 percent had an adenoma 10 mm or larger.

Both studies were rated fair quality, primarily because a large proportion of the enrolled samples could not complete the capsule endoscopy procedure (e.g., inadequate cleansing, problem with transit time). The reference standard consisted of colonoscopy. The capsule endoscopy findings were unblinded when a significant finding was identified with the capsule endoscopy but not the conventional colonoscopy.

##### Test Accuracy for CRC

Capsule endoscopy identified all patients with CRC, with a per-person sensitivity of 1.00 for both studies (95% CI range, 0.34 to 1.0). Specificity was reported in one study, at 1.0 (95% CI, 0.98 to 1.0).

##### Test Accuracy for Adenomas by Size

Per-person sensitivity of capsule endoscopy to detect adenomas 10 mm or larger ranged from 0.92 to 1.0 (95% CI range, 0.70 to 1.0) and specificity ranged from 0.95 to 0.98 (95% CI range, 0.93 to 0.99). One study reported test accuracy for adenomas 6 mm or larger; sensitivity was similar at 0.91 (95% CI, 0.85 to 0.95), but specificity was lower at 0.83 (95% CI, 0.80 to 0.86).

##### By Stage, Location, Age, Sex, Race/Ethnicity, or Family History

No subgroup results by age, sex, race/ethnicity, or family history were reported.

### Detailed Results for Stool-Based Tests

#### High-Sensitivity gFOBT

Five studies^151–153,^ ^185,^ ^200^ (n=19,472) reported results of a HSgFOBT (Hemoccult Sensa, manufactured by Beckman Coulter) in adults at average risk for CRC (Table 17). Three of these studies^152,^ ^153,^ ^185^ were included in the previous systematic review.

Table 17 Key Question 2: Study and Population Characteristics for Hemoccult Sensa

Reference standard | Author, year | Quality | Country | N screened | CRC prevalence, n (%) | AA prevalence, n (%) | Age, mean | Female, % | Race/Ethnicity, % | Family history^*^, %
Colonoscopy | Ahlquist, 2008^151^ | Fair | US | 2497 | 12 (0.5) | 145 (5.8) | 60 | 54 | White: 92.7 | 0^†^
Colonoscopy | Shapiro, 2017^200^ | Fair | US | 1006 | 2 (0.2) | 53 (5.3) | NR | 54.5 | White: 87.0; Black: 10.6; Other: 2.4 | 13.2
Registry | Allison, 1996^152^ | Fair | US | 7904 | 35 (0.43) | NA | NR | 59.3 | White: 53.5; Black: 31.1; Asian: 12.0; Other: 3.3 | NR
Registry | Allison, 2007^153^ | Fair | US | 5799 | 14^‡^ (0.3) | NA | NR | 52.5 | White: 74.1; Black: 5.0; Asian: 11.8; Hispanic: 5.2; Other: 3.9 | NR
Registry | Levi, 2011^185^ | Fair | ISR, GBR | 2266 | 19 (0.55) | NA | NR | NR | NR | NR

* 1 or more FDR with CRC, unless otherwise noted.

† More than 2 FDR with colorectal neoplasia

‡ Distal CRC only

Abbreviations: GBR = Great Britain; ISR = Israel; n = number; US = United States

##### Study and Population Characteristics

Four studies took place in the United States; the fifth was in Israel and the United Kingdom (Table 17). All five were cross-sectional test-accuracy studies reporting the performance of a one-time Hemoccult Sensa. The number of people screened ranged from 1,006 to 7,904. All studies recruited only adults 50 years or older; a mean age was reported in one study (60 years). Race/ethnicity was reported in four studies in which the majority of participants were white (54 to 93%). One study^200^ reported 13 percent of participants had a first-degree relative with CRC, and a second study^151^ excluded people with two or more first-degree relatives with colorectal neoplasia. Prevalence of CRC ranged from 0.2 to 0.6 percent. Two studies^151,^ ^200^ had followup to accurately ascertain advanced adenoma prevalence; prevalence of advanced adenomas ranged from 5.3 to 5.8 percent.

Two studies used colonoscopy as the reference standard to identify colorectal lesions, regardless of the result of the gFOBT. The other three studies used a cancer registry with 2 years of followup; one also used a colonoscopy for patients with abnormal gFOBT results, another used colonoscopy for patients with abnormal gFOBT results and an FS for the other patients, and the third used a FS for all abnormal tests.

All five studies were rated fair quality due to differential verification, unclear or no blinding of the gFOBT results for those performing the colonoscopy (or other direct visualization method), or unclear methods of patient selection. Additionally, in one study^151^ a subgroup of randomized patients were not given dietary restrictions, which may have increased the rate of false positives for Hemoccult Sensa.

##### Test Accuracy for CRC

Two studies^151,^ ^200^ (n=3,503) with colonoscopy followup for all participants reported test accuracy for CRC; sensitivity ranged from 0.50 to 0.75 (95% CI range, 0.09 to 1.0) and specificity ranged from 0.96 to 0.98 (95% CI range, 0.95 to 0.99) (Table 17).

##### Test Accuracy for AN and AA

The same two studies^151,^ ^200^ (n=3,503) with colonoscopy followup for all participants reported test accuracy of Hemoccult Sensa to detect AN (including SSL for one study^200^); sensitivity ranged from 0.07 to 0.21 (95% CI range, 0.02 to 0.27) and specificity ranged from 0.96 to 0.99 (95% CI range, 0.96 to 0.99) (Table 17). The same studies also reported test accuracy for AA; sensitivity to detect AA ranged from 0.06 to 0.17 (95% CI range, 0.02 to 0.23) and specificity ranged from 0.96 to 0.99 (95% CI range, 0.96 to 0.99). One study^200^ reported sensitivity for SSL at 0.03 (95% CI, 0.0 to 0.09).

##### Alternate Study Designs

Two studies^152,^ ^185^ (n=10,170) with registry followup reported test accuracy of HSgFOBT to detect CRC; sensitivity ranged from 0.62 to 0.79 (95% CI range, 0.36 to 0.94) and specificity ranged from 0.87 to 0.96 (95% CI range, 0.86 to 0.97) (Table 17).

##### By Stage or Location

One study^153^ (n=5,799) with registry and FS followup reported only distal CRC (Table 17). Sensitivity of Hemoccult Sensa to detect distal CRC was 0.64 (95% CI, 0.36 to 0.86). No other studies reported stage or location subgroups.

##### By Age, Sex, Race/Ethnicity, or Family History

No subgroups by age, sex, race/ethnicity, or family history were reported.

#### FIT

We identified 45 studies (in 61 articles) evaluating the test accuracy of a FIT to detect CRC, AN, and/or AA; 20 of these studies were newly identified (Table 19).

Table 18 Key Question 2: Results for Hemoccult Sensa Test Accuracy

Followup | Author, year | N analyzed | CRC sensitivity (95% CI) | CRC specificity (95% CI) | AN sensitivity (95% CI) | AN specificity (95% CI) | AA sensitivity (95% CI) | AA specificity (95% CI)
Colonoscopy | Ahlquist, 2008^151^ | 2497 | 0.75; (0.51, 1.0) | 0.96; (0.95, 0.96) | 0.21; (0.15, 0.27) | 0.96; (0.96, 0.97) | 0.17; (0.11, 0.23) | 0.96; (0.96,0.97)
Colonoscopy | Shapiro, 2017^200^ | 1006 | 0.50; (0.09, 0.91) | 0.98; (0.97, 0.99) | 0.07^*^; (0.02, 0.17) | 0.99^*^; (0.98. 0.99) | 0.06^*^; (0.02, 0.15) | 0.99^*^; (0.98, 0.99)
Registry | Allison, 1996^152^ | 7904 | 0.79 (0.64, 0.94) | 0.87; (0.86, 0.87) | NA | NA | NA | NA
Registry | Allison, 2007^153^ | 5799 | 0.64^†^ (0.36, 0.86) | 0.90^†^; (0.89, 0.91) | NA | NA | NA | NA
Registry | Levi, 2011^185^ | 2266 | 0.62; (0.36, 0.82) | 0.96; (0.96, 0.97) | NA | NA | NA | NA

* Includes SSL

† Distal CRC only

Abbreviations: AA = advanced adenoma; AN = advanced neoplasia; CI = confidence interval; CRC = colorectal cancer; N = number; NA = not applicable.

Table 19 Key Question 2: Study and Population Characteristics for FITs

Reference standard | Author, year | Quality | Country | N screened | Prevalence, n (%) | Age, mean | Female, % | Race/Ethnicity, % | Family history^*^, % | FIT
Colonoscopy | Brenner, 2013^156^ | Good | DEU | 2235 | CRC: 15 (0.67); AA: 207 (9.3) | 62.7 | 50.8 | NR | NR | OC-Sensor, RIDASCREEN; Hemoglobin, RIDASCREEN; Hemoglobin-Haptoglobin Complex
Colonoscopy | Brenner, 2017^155^ | Good | DEU | 3494 | CRC: 30 (0.86); AA: 359 (10.3) | 62.1 | 50.3 | NR | NR | FOB Gold
Colonoscopy | Chang, 2017^158^ | Good | TWN | 6198 | CRC: 0 (0); AA: 339 (5.5) | 59.0 | 48.9 | Asian: 100 | 0 (Family history of CRC) | OC-Sensor
Colonoscopy | Chen, 2014^162^ | Good | TWN | 6096 | CRC: 13 (0.2); AA: 241 (4.0) | 54 | 44 | NR | NR | OC-Light
Colonoscopy | Cheng, 2002^163^ | Fair | TWN | 7411 | CRC: 16 (0.22); AA: 77 (1.0) | 47 | 44.8 | NR | NR | OC-Light
Colonoscopy | Chiu, 2013^165^ | Good | TWN | 18296 | CRC: 28 (0.15); AA: 632 (3.5) | 59.8 | 40.8 | NR | NR | OC-Light
Colonoscopy | Chiu, 2016^164^ | Fair | AUS, BRN, CHN, HKG, JPN, MYS, PAK, PHL, SGP, KOR, TWN, THA | 4434 | CRC: 16 (0.4); AA: 158 (3.6) | 58 | 49 | NR | 11.6 | OC-Sensor, Combination
Colonoscopy | Cooper, 2018^166^ | Fair | US | 760 | CRC: 2 (0.26); AA: 49 (6.44) | 56.7 | 60.2 | White: 65.1; Black: 34.9 | NR | OC FIT-CHEK
Colonoscopy | de Wijkerslooth, 2012^167^ | Good | NLD | 1256 | CRC: 8 (0.64); AA: 111 (8.8) | | 49 | White: 96; Other: 4 | 16 | OC-Sensor
Colonoscopy | Gies, 2018^171^ | Fair | DEU | 516 | CRC: 16 (3.1); AA: 200 (38.8) | 63.2 | 44.4 | NR | NR | CAREprime Hb, Eurolyser FOB test, Hb ELISA, ImmoCARE-C, OC-Sensor, QuantOn Hem, QuikRead go iFOBT, RIDASCREEN Hb, SENTiFIT-FOB Gold
Colonoscopy | Hernandez, 2014^174^ | Good | ESP | 779 | CRC: 5 (0.6); AA: 92 (11.8) | 58 | 50 | NR | 0 | OC-Sensor
Colonoscopy | Imperiale, 2014^175^ | Fair | US,CAN | 9989 | CRC: 65 (0.65); AA: 757 (7.6) | 64.2 | 53.7 | White: 84.0; Black: 10.7; Other: 5.2 | 0 | OC FIT-CHEK
Colonoscopy | Kim, 2017^180^ | Fair | KOR | 14912 | CRC: 15 (0.1); AA: 363 (2.4) | | 30 | NR | 4.7 | OC-Sensor
Colonoscopy | Lee, 2014^183^ | Good | KOR | 1397 | NR | | 52 | NR | NR | Hemo Techt NS-Plus C system
Colonoscopy | Levy, 2014^186^ | Fair | US | 621 | NR | 56.9 | 59.2 | White: 94.1; Black: 2.3; Hispanic: 1.3 | NR | A Clearview, I Clearview, OC-Light, QuickVue
Colonoscopy | Liles, 2018^187^ | Fair | US | 2771 | CRC: 2 (0.07); AA: 209 (7.5) | | 51 | White: 89.1; Black: 2.2; Asian: 3.7; AI/AN: 0.5; Other: 2.4 | 5.2 | OC-Auto
Colonoscopy | Morikawa, 2005^190^ | Fair | JPN | 21805 | CRC: 79 (0.4); AA: 648 (3.0) | 48 | 28.0 | NR | NR | Magstream 1000/Hem SP
Colonoscopy | Nakama, 1999^192^ | Fair | JPN | 4611 | CRC: 18 (0.39); AA: NR | NR | NR | NR | NR | Monohaem
Colonoscopy | Ng, 2013^193^ | Fair | HKG | 4539 | CRC: 22 (0.48); AA: 197 (4.3) | 57.7 | 54.7 | NR | 12.6 | Hemosure
Colonoscopy | Park, 2010^194^ | Fair | KOR | 770 | CRC: 13 (1.7); AA: 59 (7.7) | 59 | 49 | NR | NR | OC-Micro
Colonoscopy | Redwood, 2016^197^ | Fair | US | 661 | CRC: 10 (1.5); AA: 82 (12.4) | | 60 | AI/AN: 100 | NR | OC-Sensor
Colonoscopy | Shapiro, 2017^200^ | Fair | US | 1006 | CRC: 2 (0.2); AA: 53 (5.3) | | 54.5 | White: 87.0; Black: 10.6; Other: 2.4 | 13.2 | OC FIT-CHEK, InSure FIT
Colonoscopy | Sohn, 2005^201^ | Fair | KOR | 3794 | CRC: 12 (0.3); AA: 67 (1.8) | 49 | 43.3 | NR | NR | OC-Hemodia
Colonoscopy | Wong, 2015^204^ | Fair | HKG | 5343 | CRC: 22 (0.4); AA: 269 (5.0) | 58 | 55 | NR | 12.3 | Hemosure
Colonoscopy | Graser, 2009^172^ | Good | DEU | 307 | CRC: 307 (0.33); AA: 285 (0.084) | 60.5 | 45 | NR | 0 | FOB Gold
Registry | Allison, 1996^152^ | Fair | US | 7493 | CRC: 35 (0.43) | NR | 59.3 | White: 53.5; Black: 31.1; Asian: 12.0; Other: 3.3 | NR | HemeSelect
Registry | Allison, 2007^153^ | Fair | US | 5356 | CRC: 14 (0.3) | NA | 52.5 | White: 74.1; Black: 5.0; Asian: 11.8; Hispanic: 5.2; Other: 3.9 | NR | FlexSure OBT
Registry | Arana-Arri, 2017^154^ | Fair | ESP | 296378 | CRC: 1168 (0.39) | NR | NR | NR | 0 (hereditary or familial CRC) | OC-Sensor
Registry | Castiglione, 2007^157^ | Fair | ITA | 24913 | CRC: 83 (0.30) | NR | 52.2 | NR | NR | OC-Hemodia
Registry | Chen, 2011^160^ | Fair | TWN | 46355 | CRC: 150 (0.32) | 52.1 | 63 | NR | NR | OC-Sensor
Registry | Chen, 2016^159^ | Fair | TWN | 512066 | CRC: 921 (0.18) | NR | 52 | NR | 3 | OC-Sensor
Registry | Chen, 2018^161^ | Fair | TWN | 723113 | CRC: 2005 (0.3) | 58 | 61.7 | NR | NR | HM-Jack, OC-Sensor
Registry | Garcia, 2015^170^ | Fair | ESP | 4618 | CRC: 20 (0.43) | NR | NR | NR | 0 (high risk family history) | OC-Auto
Registry | Haug, 2017^173^ | Fair | NLD | 4523 | CRC: 36 (0.8) | 60.5 | 52 | NR | NR | OC-Sensor Micro
Registry | Itoh, 1996^176^ | Fair | JPN | 27860 | CRC: 89 (0.32) | NR | 14.0 | NR | NR | OC-Hemodia
Registry | Juul, 2018^179^ | Fair | DNK | 245299 | CRC: 976 (0.4) | | 53.7 | NR | NR | OC-Sensor
Registry | Launoy, 2005^182^ | Fair | FRA | 7421 | CRC: 28 (0.38) | NR | 56.9 | NR | NR | Magstream 1000
Registry | Levi, 2011^185^ | Fair | ISR,GBR | 1204 | CRC: 19 (0.55) | NR | NR | NR | NR | OC-Micro
Registry | Mlakar, 2018^189^ | Fair | SVN | 251948 | CRC: 572 (0.001) | | 50.3 | NR | NR | OC-Sensor
Registry | Nakama, 1996^191^ | Fair | JPN | 3365 | CRC: 14 (0.42) | NR | 51.4 | NR | NR | Monohaem
Registry | Selby, 2018^199^ | Fair | US | 640859 | CRC: 1245 (0.19) | | 53 | White: 55; Black: 7; Asian: 16; Hispanic: 18; Other: 3 | NR | OC FIT-CHEK
Registry | Stegeman, 2015^202^ | Good | NLD | 2871 | CRC: 20 (0.7) | 59 | 49 | NR | NR | OC-Sensor
Registry | van der Vlugt, 2017^203^ | Fair | NLD | 18716 | CRC: 152 (0.81) | NR | NR | NR | NR | OC-Sensor/FOB Gold

* 1 or more FDR with CRC, unless otherwise noted.

Abbreviations: AA = advanced adenoma; AUS = Australia; BRN = Brunei; CHN = China; CRC = colorectal cancer; DEU = Germany; DNK = Denmark; ESP = Spain; FIT = fecal immunochemical test; FOB = fecal occult blood; FRA = France; HKG = Hong Kong; ISR = Israel; ITA = Italy; JPN = Japan; KOR = Korea; MYS = Malaysia; n = number; NLD = Netherlands; NR = not reported; PAK = Pakistan; PHL = Philippines; SGP = Singapore; THA = Thailand; TWN = Taiwan; US = United States

##### Study and Population Characteristics

Eight studies were conducted solely in the United States, and one study was conducted in the United States and Canada (Table 19). The remaining studies were conducted in Taiwan (k=7), Germany (k=4), Japan (k=4), the Netherlands (k=5), South Korea (k=4), Spain (k=3), and Hong Kong (k=2), and one study each was conducted in Italy, Denmark, France, Slovenia, Sweden, in both Israel and the United Kingdom, and in both Australia and Asia. Twenty-eight studies were cross-sectional test accuracy studies examining a one-time FIT; these studies had sample sizes ranging from 307 to 9,989 participants except for one large study (n=21,805) recruiting people over a period of 20 years for a comprehensive health examination in Japan. Seventeen studies were conducted within the context of a screening program and their sample sizes ranged from 2,235 to 956,005 participants. One study was a nested case-control design with a sample of 516. Most studies recruited participants 40 or 50 years or older, but three studies allowed adults of any age. Mean age was reported in 24 studies and ranged from 47 to 68 years. Participants with a family history of CRC—typically defined as a first-degree relative with CRC, but not always specified—were specifically excluded in six studies. Eight studies reported that 3 to 13 percent of participants had a family history of CRC, while the remaining studies did not have any specific exclusion criteria related to family history or did not report the proportion with a family history. Race/ethnicity was sparsely reported (k=10); percent white ranged from 0 to 96. Prevalence of CRC was very low and when present, ranged from 0.001 to 1.7 percent (with the exception of 3.1% for the nested case-control study). Prevalence of advanced adenomas varied widely and ranged from 0.08 to 11.8 percent (39% for the nested case-control study).

There is wide variation in the characteristics of available FITs (Appendix D Table 1). They are available as quantitative or qualitative tests, as laboratory or point-of-care tests, and they differ in methodology. The most commonly used FITs in our included studies were part of the OC-Sensor family (Polymedco in the United States or Eiken Chemical outside of the United States); in the included studies they were referred to as OC FIT-CHEK, OC-Auto, OC-Micro, OC-Sensor Micro, and OC-Sensor. The OC-Light test—by the same manufacturer but using a different methodology—was used in four studies. The OC-Hemodia test, also manufactured by Eiken Chemical, was used in three studies; however, the test is no longer available. Many other FITs were also represented, but not robustly studied, including A Clearview, CAREprime Hb, Eurolyser FOB test, FlexSure OBT, FOB Gold, Hb ELISA, HemeSelect, Hemo Techt NS-Plus C system, Hemosure, HM-Jack, I Clearview, ImmoCARE-C, InSure FIT, Magstream tests (including Magstream 1000, Magstream 1000/Hem SP), Monohaem, QuantOn Hem, QuickVue, QuikRead go iFOBT, RIDASCREEN Hb, RIDASCREEN Hemoglobin-Haptoglobin Complex, and SENTiFIT-FOB Gold. Two studies whose results were published after the previous review accounted for seven new FITs; however, six of them were examined in one nested case-control study,^171^ and the reported test performance is likely not representative of what would be seen among average-risk adults in primary care. One multisite study^164^ used OC-Sensor plus a variety of other stool tests for different study sites and analyzed them together. Most of the sites that did not use OC-Sensor were in countries that did not meet our inclusion criteria, and we will not discuss their combined results.

Two different reference standards were used to identify colorectal lesions. In 26 studies, the FIT was followed by a colonoscopy for all participants (in one study,^172^ colonoscopy with segmental unblinding from CTC was used), regardless of the results of the FIT. Nineteen studies employed a combination of cancer registries for all participants and direct visualization for participants with an abnormal FIT result. In those studies, direct visualization was usually achieved with a colonoscopy, but sometimes CTC, FS, and/or BE were used. The studies using cancer registries to identify colorectal cancer were completed in the context of a large screening program (country, state, city, or region), sometimes using an initial round of FIT screening in a location where a colorectal cancer screening program had not yet been initiated, sometimes using a single round of screening where a cancer screening program had already been in place, and sometimes using more than one round of a screening program with the findings collapsed together.

Nine studies were rated good quality. Studies at higher risk of bias and rated as fair quality were those with differential verification, unclear or no blinding of the FIT results for those performing the colonoscopy (or other direct visualization method), unclear methods of patient selection, and concerns about patient attrition (such as a high proportion of unreadable screening tests). One new study was rated as poor quality and excluded, primarily due to a lack of reporting and therefore an inability to ascertain the risk of bias.

#### OC-Sensor Family

##### Test Accuracy for CRC

Nine studies (n=34,352)^156,^ ^164,^ ^167,^ ^174,^ ^175,^ ^180,^ ^194,^ ^197,^ ^200^ using OC-Sensor tests to detect CRC with a colonoscopy reference standard for all participants were pooled at the manufacturer-recommended cutoff of 20 μg Hb/g feces; sensitivity to detect CRC was 0.74 (95% CI, 0.64 to 0.83; I^2^=31.6%) and specificity was 0.94 (95% CI, 0.93 to 0.96; I^2^=96.6%) (Figure 13, Appendix E Figure 1, and Table 20). At lower cutoffs (15 and 10 μg Hb/g feces), the sensitivity to detect CRC increased (0.92 and 0.99, respectively) and the corresponding specificities decreased (0.92 and 0.90, respectively). These lower cutoffs, however, had few studies to pool (k=3), and the confidence intervals overlapped with those from the other cutoffs; thus, the pooled results should be interpreted with caution. Higher cutoffs for OC-Sensor tests were also reported (23, 25, 30, and 40 μg Hb/g feces), but by only one study each.

Figure 13 Key Question 2: Forest Plot of OC-Sensor Sensitivity and Specificity to Detect Colorectal Cancer (All Colonoscopy Follow-Up), by Cutoff (μg Hb/g Feces)

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; TN = true negative; TP = true positive; µg Hb per g feces = microgram hemoglobin per gram feces

Note: For 20 μg Hb/g feces cutoff, the bivariate pooled sensitivity was 0.74 (95% CI, 0.64 to 0.83; I^2^=31.6%) and specificity was 0.94 (95% CI, 0.93 to 0.96; I^2^=96.6%). For 15 μg Hb/g feces cutoff, sensitivity I^2^=0% and specificity I^2^=77.4%. For 10 μg Hb/g feces cutoff, sensitivity I^2^=0% and specificity I^2^=79.1%.

Figure 13 shows a forest plot of OC-Sensor sensitivity and specificity to detect colorectal cancer with all colonoscopy follow-up, grouped by screening test cutoff in μg Hb/g feces. For 10 μg Hb/g feces, the pooled sensitivity is 0.99 with a 95% confidence interval of 0.94 to 1.00. The pooled specificity is 0.90 with a 95% confidence interval of 0.88 to 0.93. For 15 μg Hb/g feces, the pooled sensitivity is 0.92 with a 95% confidence interval of 0.79 to 1.00. The pooled specificity is 0.92 with a 95% confidence interval of 0.89 to 0.94. For 20 μg Hb/g feces, the pooled sensitivity is 0.74 with a 95% confidence interval of 0.59 to 0.89. The pooled specificity is 0.94 with a 95% confidence interval of 0.93 to 0.96.

Table 20 Key Question 2: Results for FIT Test Accuracy (All Colonoscopy Follow-Up)

Author, year | Test name | Cutoff, μg Hb/g | Screened group | N analyzed | CRC sens (95% CI) | CRC spec (95% CI) | AN sens (95% CI) | AN spec (95% CI) | AA sens (95% CI) | AA spec (95% CI)
Brenner, 2013^156^ | RIDASCREEN Hemoglobin | 2 | All | 2235 | 0.600; (0.353, 0.812) | 0.954; (0.945, 0.962) | 0.234; (0.182, 0.293) | 0.971; (0.963, 0.977) | 0.208; (0.157, 0.267) | 0.971; (0.963, 0.977)
Brenner, 2013^156^ | OC-Sensor | 20 | All | 2235 | 0.733; (0.483, 0.902) | 0.955; (0.946, 0.963) | 0.257; (0.203, 0.317) | 0.974; (0.966, 0.980) | 0.222; (0.170, 0.282) | 0.974; (0.966, 0.980)
Brenner, 2013^156^ | RIDASCREEN Hemoglobin-Haptoglobin Complex | 2 | All | 2235 | 0.533; (0.294, 0.761) | 0.954; (0.945, 0.962) | 0.203; (0.154, 0.259) | 0.968; (0.959, 0.975) | 0.179; (0.131, 0.235) | 0.968; (0.959, 0.975)
Brenner, 2017^155^ | FOB Gold | 12 | All | 3466 | 0.97 (0.82, 1.00) | 0.90 (NR) | 0.44; (0.39, 0.49) | 0.90; (NR) | NR | NR
Brenner, 2017^155^ | FOB Gold | 12 | Recruited 2012–2014 | 1822 | NR | NR | NR | NR | 0.40; (0.35, 0.45) | 0.90 (NR)
Brenner, 2017^155^ | FOB Gold | 17 | All | 3466 | 0.967; (0.828, 0.999) | NR | 0.386; (0.337, 0.436) | 0.928; (0.918, 0.936) | 0.337; (0.288, 0.389) | 0.928; (0.918, 0.936)
Brenner, 2017^155^ | FOB Gold | 17 | Distal | 3466 | 0.969; (0.796, 0.999) | NR | 0.490; (0.428, 0.553) | NR | 0.441; (0.376, 0.507) | NR
Brenner, 2017^155^ | FOB Gold | 17 | Proximal | 3466 | 1.00; (0.478, 1.00) | NR | 0.226; (0.161, 0.303) | NR | 0.199; (0.136, 0.274) | NR
Brenner, 2017^155^ | FOB Gold | 27 | All | 3466 | 0.97 (0.82, 1.00) | 0.95 (NR) | 0.33; (0.29, 0.38) | 0.95; (NR) | 0.28; (0.23, 0.33) | 0.95 (NR)
Brenner, 2017^155^ | FOB Gold | 8 | All | 3466 | 0.97 (0.82, 1.00) | 0.85 (NR) | 0.54; (0.49, 0.59) | 0.85; (NR) | 0.50; (0.45, 0.56) | 0.85 (NR)
Brenner, 2017^155^ | FOB Gold | 8.5 | All | 3466 | 0.967; (0.828, 0.999) | NR | 0.511; (0.461, 0.562) | 0.865; (0.853, 0.877) | 0.474; (0.421, 0.527) | 0.865; (0.853, 0.877)
Brenner, 2017^155^ | FOB Gold | 8.5 | Distal | 3466 | 0.969; (0.796, 0.999) | NR | 0.598; (0.535, 0.658) | NR | 0.559; (0.493, 0.624) | NR
Brenner, 2017^155^ | FOB Gold | 8.5 | Proximal | 3466 | 1.00; (0.478, 1.00) | NR | 0.397; (0.317, 0.481) | NR | 0.376; (0.296, 0.461) | NR
Chang, 2017^158^ | OC-Sensor | 10 | All | 6198 | NR | NR | NR | NR | 0.324; (0.275, 0.378) | NR
Chang, 2017^158^ | OC-Sensor | 15 | All | 6198 | NR | NR | NR | NR | 0.245; (0.201, 0.295) | NR
Chang, 2017^158^ | OC-Sensor | 20 | All | 6198 | NR | NR | NR | NR | 0.209; (0.168, 0.257) | NR
Chen, 2014^162^ | OC-Light | 10 | All | 6096 | 0.692; (0.441, 0.943) | 0.964; (0.959, 0.969) | 0.221; (0.170, 0.272) | 0.97; (0.966, 0.975) | NR | NR
Chen, 2014^162^ | OC-Light | 10 | ≥50 years | 3874 | NR | NR | 0.192; (0.137, 0.247) | NR | NR | NR
Chen, 2014^162^ | OC-Light | 10 | >75 years | 88 | NR | NR | 0.333 (0, 0.711) | NR | 0.333 (0, 0.711) | NR
Chen, 2014^162^ | OC-Light | 10 | 40–49 years | 2214 | NR | NR | 0.321; (0.199, 0.444) | NR | NR | NR
Chen, 2014^162^ | OC-Light | 10 | 50–75 years | 3794 | NR | NR | 0.188; (0.132, 0.243) | NR | NR | NR
Cheng, 2002^163^ | OC-Light | 10 | All | 7411 | NR | NR | NR | NR | NR | NR
Chiu, 2013^165^ | OC-Light | 10 | All | 18296 | 0.786; (0.585, 0.910) | 0.928; (0.925, 0.932) | 0.302; (0.267, 0.338) | 0.936; (0.932, 0.939) | 0.280; (0.246, 0.317) | 0.935; (0.931, 0.938)
Chiu, 2013^165^ | OC-Light | 10 | Distal | 18296 | 0.823; (0.558, 0.953) | NR | 0.343; (0.292, 0.397) | NR | 0.316; (0.265, 0.372) | NR
Chiu, 2013^165^ | OC-Light | 10 | Proximal | 18296 | 0.727; (0.393, 0.927) | NR | 0.241; (0.194, 0.294) | NR | 0.225; (0.179, 0.278) | NR
Chiu, 2016^164^ | Combination | combination | All | 3873 | NR | NR | NR | NR | NR | NR
Chiu, 2016^164^ | Combination | combination | Low risk APCS | 646 | NR | NR | NR | NR | NR | NR
Chiu, 2016^164^ | Combination | combination | Moderate risk APCS | 3243 | NR | NR | NR | NR | NR | NR
Chiu, 2016^164^ | OC-Sensor | 20 | All | 2803 | NR | NR | NR | NR | NR | NR
Chiu, 2016^164^ | OC-Sensor | 20 | Low risk APCS | 416 | NR | NR | NR | NR | NR | NR
Chiu, 2016^164^ | OC-Sensor | 20 | Moderate risk APCS | 2387 | NR | NR | NR | NR | NR | NR
Cooper, 2018^*^,^166^ | OC FIT-CHEK | 20 | All | 760 | NR | NR | 0.32; (NR) | 0.97; (NR) | NR | NR
Cooper, 2018^*^,^166^ | OC FIT-CHEK | 20 | Black | 265 | NR | NR | 0.35; (NR) | 0.97; (NR) | NR | NR
Cooper, 2018^*^,^166^ | OC FIT-CHEK | 20 | White | 495 | NR | NR | 0.33; (NR) | 0.97; (NR) | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 10 | All | 1256 | 0.88 (0.47, 0.99) | 0.91 (0.89, 0.92) | 0.38; (0.29, 0.47) | 0.93; (0.92, 0.95) | 0.35; (0.27, 0.45) | 0.93 (0.91, 0.94)
de Wijkerslooth, 2012^167^ | OC-Sensor | 10 | Distal | 1256 | NR | NR | 0.37; (NR) | NR | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 10 | Proximal | 1256 | NR | NR | 0.38; (NR) | NR | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 10 | Female | 618 | NR | NR | 0.35 (0.2, 0.49) | 0.94; (0.92, 0.96) | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 10 | Male | 638 | NR | NR | 0.40; (0.29, 0.52) | 0.93; (0.90, 0.94) | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 15 | All | 1256 | 0.75 (0.36, 0.96) | 0.93 (0.92, 0.95) | 0.33; (0.25, 0.42) | 0.96; (0.94, 0.97) | 0.31; (0.23, 0.40) | 0.96 (0.94, 0.97)
de Wijkerslooth, 2012^167^ | OC-Sensor | 15 | Distal | 1256 | NR | NR | 0.31; (NR) | NR | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 15 | Proximal | 1256 | NR | NR | 0.33; (NR) | NR | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 20 | All | 1256 | 0.75 (0.36, 0.96) | 0.95 (0.93, 0.96) | 0.31; (0.23, 0.40) | 0.97; (0.96, 0.98) | 0.29; (0.21, 0.39) | 0.97 (0.95, 0.98)
de Wijkerslooth, 2012^167^ | OC-Sensor | 20 | Distal | 1256 | NR | NR | 0.29; (NR) | NR | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 20 | Proximal | 1256 | NR | NR | 0.33; (NR) | NR | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 20 | Female | 618 | NR | NR | 0.33; (0.22,0.47) | 0.98; (0.96, 0.98) | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 20 | Male | 638 | NR | NR | 0.29; (0.20, 0.41) | 0.96; (0.95, 0.98) | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 30 | All | 1256 | NR | NR | 0.28; (0.20, 0.36)^*^ | 0.98; (0.97, 0.99)^*^ | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 30 | Female | 618 | NR | NR | 0.26; (0.15, 0.39) | 0.98; (0.38, 0.77) | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 30 | Male | 638 | NR | NR | 0.29; (0.20, 0.41) | 0.98; (0.96, 0.99) | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 40 | All | 1256 | NR | NR | 0.24; (0.17, 0.32)^*^ | 0.99; (0.98, 0.99)^*^ | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 40 | Female | 618 | NR | NR | 0.22; (0.12, 0.35) | 0.98; (0.97, 0.99) | NR | NR
de Wijkerslooth, 2012^167^ | OC-Sensor | 40 | Male | 638 | NR | NR | 0.25; (0.16, 0.38) | 0.99; (0.97, 0.99) | NR | NR
Gies, 2018^171^ | CAREprime Hb | 12.35 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.236; (0.18, 0.30) | 0.967; (0.94, 0.98) | 0.20; (0.15, 0.26) | 0.967; (0.94, 0.98)
Gies, 2018^171^ | CAREprime Hb | 15 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.218; (0.16, 0.28) | 0.97; (0.94, 0.99) | 0.18; (0.13, 0.24) | 0.97 (0.94, 0.99)
Gies, 2018^171^ | CAREprime Hb | 26.22 | All | 516 | NR | NR | 0.162; (0.12, 0.22) | 0.99; (0.97, 1.0) | 0.13; (0.09, 0.18) | 0.99 (0.97, 1.0)
Gies, 2018^171^ | CAREprime Hb | 26.22 | All | 516 | NR | NR | 0.162; (0.12, 0.22) | 0.99; (0.97, 1.0) | 0.563; (0.30, 0.80) | NR
Gies, 2018^171^ | CAREprime Hb | 6.3 | All | 516 | 0.813; (0.54, 0.96) | NR | 0.347; (0.28, 0.41) | 0.913; (0.88, 0.94) | 0.31; (0.25, 0.38) | 0.913; (0.88, 0.94)
Gies, 2018^171^ | CAREprime Hb | 6.65 | All | 516 | 0.813; (0.54, 0.96) | NR | 0.333; (0.27, 0.40) | 0.93; (0.90, 0.96) | 0.295; (0.23, 0.36) | 0.93 (0.90, 0.96)
Gies, 2018^171^ | Eurolyser FOB test | 15 | All | 516 | 0.563; (0.30, 0.80) | NR | 0.167; (0.12, 0.22) | 0.98; (0.96, 0.99) | 0.135; (0.09, 0.19) | 0.98 (0.96, 0.99)
Gies, 2018^171^ | Eurolyser FOB test | 2.01 | All | 516 | 0.75; (0.48, 0.93) | NR | 0.343; (0.28, 0.41) | 0.93; (0.90, 0.96) | 0.31; (0.25, 0.38) | 0.93 (0.90, 0.96)
Gies, 2018^171^ | Eurolyser FOB test | 21.15 | All | 516 | 0.563; (0.30, 0.80) | NR | 0.144; (0.10, 0.20) | 0.99; (0.97, 1.0) | 0.11; (0.07, 0.16) | 0.99 (0.97, 1.0)
Gies, 2018^171^ | Eurolyser FOB test | 6.11 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.236; (0.18, 0.30) | 0.967; (0.94, 0.98) | 0.20; (0.15, 0.26) | 0.967; (0.94, 0.98)
Gies, 2018^171^ | Eurolyser FOB test | 8.04 | All | 516 | 0.625; (0.35, 0.85) | NR | 0.227; (0.17, 0.29) | 0.97; (0.94, 0.97) | 0.195; (0.14, 0.26) | 0.97 (0.94, 0.97)
Gies, 2018^171^ | Hb ELISA | 15 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.213; (0.16, 0.27) | 0.963; (0.94, 0.98) | 0.175; (0.13, 0.23) | 0.963; (0.94, 0.98)
Gies, 2018^171^ | Hb ELISA | 15.32 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.213; (0.16, 0.27) | 0.967; (0.94, 0.98) | 0.175; (0.13, 0.23) | 0.967; (0.94, 0.98)
Gies, 2018^171^ | Hb ELISA | 2 | All | 516 | 0.813; (0.54, 0.96) | NR | 0.463; (0.40, 0.53) | 0.857; (0.81, 0.89) | 0.435; (0.37, 0.51) | 0.857; (0.81, 0.89)
Gies, 2018^171^ | Hb ELISA | 29.16 | All | 516 | 0.625; (0.35, 0.85) | NR | 0.157; (0.11, 0.21) | 0.99; (0.97, 1.0) | 0.12; (0.08, 0.17) | 0.99 (0.97, 1.0)
Gies, 2018^171^ | Hb ELISA | 4.8 | All | 516 | 0.813; (0.54, 0.96) | NR | 0.352; (0.29, 0.42) | 0.93; (0.90, 0.96) | 0.315; (0.25, 0.38) | 0.93 (0.90, 0.96)
Gies, 2018^171^ | ImmoCare-C | 15 | All | 515 | 0.75 (0.48, 0.93) | NR | 0.27; (0.21, 0.33) | 0.96; (0.93, 0.98) | 0.231; (0.17, 0.30) | 0.96 (0.93, 0.98)
Gies, 2018^171^ | ImmoCare-C | 17.3 | All | 515 | 0.625; (0.35, 0.85) | NR | 0.233; (0.18, 0.29) | 0.967; (0.94, 0.98) | 0.201; (0.15, 0.26) | 0.967; (0.94, 0.98)
Gies, 2018^171^ | ImmoCare-C | 36.8 | All | 515 | 0.563; (0.30, 0.80) | NR | 0.163; (0.12, 0.22) | 0.99; (0.97, 1.0) | 0.131; (0.09, 0.19) | 0.99 (0.97, 1.0)
Gies, 2018^171^ | ImmoCare-C | 6.25 | All | 515 | 0.813; (0.54, 0.96) | NR | 0.386; (0.32, 0.45) | 0.90; (0.86, 0.93) | 0.352; (0.29, 0.42) | 0.90 (0.86, 0.93)
Gies, 2018^171^ | ImmoCare-C | 9.2 | All | 515 | 0.813; (0.54, 0.96) | NR | 0.335; (0.27, 0.40) | 0.93; (0.90, 0.96) | 0.297; (0.23, 0.37) | 0.93 (0.90, 0.96)
Gies, 2018^171^ | OC-Sensor | 10 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.218; (0.16, 0.28) | 0.977; (0.95, 0.99) | 0.18; (0.13, 0.24) | 0.977; (0.95, 0.99)
Gies, 2018^171^ | OC-Sensor | 15 | All | 516 | 0.563; (0.30, 0.80) | NR | 0.162; (0.12, 0.22) | 0.97; (0.94, 0.99) | 0.130; (0.09, 0.18) | 0.97 (0.94, 0.99)
Gies, 2018^171^ | OC-Sensor | 18.2 | All | 516 | 0.563; (0.30, 0.80) | NR | 0.162; (0.12, 0.22) | 0.99; (0.97, 1.0) | 0.13; (0.09, 0.18) | 0.99 (0.97, 1.0)
Gies, 2018^171^ | OC-Sensor | 3.6 | All | 516 | 0.75; (0.48, 0.93) | NR | 0.301; (0.24, 0.36) | 0.93; (0.90, 0.96) | 0.265; (0.21, 0.33) | 0.93 (0.90, 0.96)
Gies, 2018^171^ | OC-Sensor | 6.60 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.236; (0.18, 0.30) | 0.967; (0.94, 0.98) | 0.20; (0.15, 0.26) | 0.967; (0.94, 0.98)
Gies, 2018^171^ | QuantOn Hem | 15 | All | 516 | 0.75 (0.48, 0.93) | NR | 0.264; (0.21, 0.33) | 0.95; (0.92, 0.97) | 0.225; (0.17, 0.29) | 0.95 (0.92, 0.97)
Gies, 2018^171^ | QuantOn Hem | 17.73 | All | 516 | 0.75 (0.48, 0.93) | NR | 0.227; (0.17, 0.29) | 0.967; (0.94, 0.98) | 0.185; (0.13, 0.25) | 0.967; (0.94, 0.98)
Gies, 2018^171^ | QuantOn Hem | 29.81 | All | 516 | 0.625; (0.35, 0.85) | NR | 0.148; (0.10, 0.20) | 0.99; (0.97, 1.0) | 0.11; (0.07, 0.16) | 0.99 (0.97, 1.0)
Gies, 2018^171^ | QuantOn Hem | 3.7 | All | 516 | 0.813; (0.54, 0.96) | NR | 0.44; (0.38, 0.51) | 0.857; (0.81, 0.89) | 0.415; (0.35, 0.49) | 0.857; (0.81, 0.89)
Gies, 2018^171^ | QuantOn Hem | 9.59 | All | 516 | 0.75 (0.48, 0.93) | NR | 0.315; (0.25, 0.38) | 0.93; (0.90, 0.96) | 0.28; (0.22, 0.35) | 0.93 (0.90, 0.96)
Gies, 2018^171^ | QuikRead go iFOBT | 15 | All | 516 | 0.625; (0.35, 0.85) | NR | 0.218; (0.16, 0.28) | 0.967; (0.94, 0.98) | 0.185; (0.13, 0.25) | 0.967; (0.94, 0.98)
Gies, 2018^171^ | QuikRead go iFOBT | 23 | All | 516 | 0.563; (0.30, 0.80) | NR | 0.185; (0.14, 0.24) | 0.99; (0.97, 1.0) | 0.155; (0.11, 0.21) | 0.99 (0.97, 1.0)
Gies, 2018^171^ | RIDASCREEN Hb | 12.27 | All | 516 | 0.813; (0.54, 0.96) | NR | 0.347; (0.28, 0.41) | 0.93; (0.90, 0.96) | 0.31; (0.25, 0.38) | 0.93 (0.90, 0.96)
Gies, 2018^171^ | RIDASCREEN Hb | 15 | All | 516 | 0.813; (0.54, 0.96) | NR | 0.343; (0.28, 0.41) | 0.94; (0.91, 0.96) | 0.305; (0.24, 0.37) | 0.94 (0.91, 0.96)
Gies, 2018^171^ | RIDASCREEN Hb | 29.54 | All | 516 | 0.625; (0.35, 0.85) | NR | 0.222; (0.17, 0.28) | 0.967; (0.94, 0.98) | 0.19; (0.14, 0.25) | 0.967; (0.94, 0.98)
Gies, 2018^171^ | RIDASCREEN Hb | 8 | All | 516 | 0.813; (0.54, 0.96) | NR | 0.333; (0.27, 0.40) | 0.907; (0.87, 0.94) | 0.360; (0.29, 0.43) | 0.907; (0.87, 0.94)
Gies, 2018^171^ | SENTiFIT-FOB Gold | 1.7 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.315; (0.25, 0.38) | 0.933; (0.90, 0.96) | 0.285; (0.22, 0.35) | 0.933; (0.90, 0.96)
Gies, 2018^171^ | SENTiFIT-FOB Gold | 15 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.227; (0.17, 0.29) | 0.96; (0.93, 0.98) | 0.19; (0.14, 0.25) | 0.96 (0.93, 0.98)
Gies, 2018^171^ | SENTiFIT-FOB Gold | 17 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.218; (0.16, 0.28) | 0.963; (0.94, 0.98) | 0.18; (0.13, 0.24) | 0.963; (0.94, 0.98)
Gies, 2018^171^ | SENTiFIT-FOB Gold | 17.68 | All | 516 | 0.688; (0.41, 0.89) | NR | 0.218; (0.16, 0.28) | 0.967; (0.94, 0.98) | 0.18; (0.13, 0.24) | 0.967; (0.94, 0.98)
Gies, 2018^171^ | SENTiFIT-FOB Gold | 53.38 | All | 516 | 0.563; (0.30, 0.80) | NR | 0.144; (0.10, 0.20) | 0.99; (0.97, 1.0) | 0.11; (0.07, 0.16) | 0.99 (0.97, 1.0)
Graser, 2009^172^ | FOB Gold | NR | All | 285 | 1.00; (0.147, 1.00) | NR | 0.320; (0.164, 0.515) | 0.858; (0.811, 0.896) | 0.292; (0.141, 0.489) | 0.858; (0.811, 0.896)
Hernandez, 2014^174^ | OC-Sensor | 20 | All | 779 | 1.0 (0.90, 1.0) | 0.94 (0.92, 0.95) | 0.32; (0.22, 0.42) | 0.96; (0.95, 0.98) | NR | NR
Hernandez, 2014^174^ | OC-Sensor | 23 | All | 779 | NR | NR | NR | NR | NR | NR
Hernandez, 2014^174^ | OC-Sensor | 30 | All | 779 | NR | NR | NR | NR | NR | NR
Hernandez, 2014^174^ | OC-Sensor | 40 | All | 779 | NR | NR | NR | NR | NR | NR
Hernandez, 2014^174^ | OC-Sensor | 10 | All | 779 | 1.0 (0.9, 1.0) | 0.92 (0.90, 0.94) | 0.35; (0.25, 0.45) | 0.95; (0.93, 0.97) | NR | NR
Hernandez, 2014^174^ | OC-Sensor | 15 | All | 779 | NR | NR | NR | NR | NR | NR
Imperiale, 2014^175^ | OC FIT-CHEK | 20 | All | 9989 | 0.738; (0.615, 0.840) | NR | NR | NR | 0.238; (0.208, 0.270) | 0.949; (0.944, 0.953)
Kim, 2017^180^ | OC-Sensor | 20 | All | 14912 | NR | NR | NR | NR | NR | NR
Kim, 2017^180^ | OC-Sensor | 20 | ≥50 years | 4374 | 0.636; (0.308, 0.891) | 0.963; (0.957, 0.968) | 0.22; (0.163, 0.287) | 0.969; (0.964, 0.974) | NR | 0.969; (0.963, 0.974)
Kim, 2017^180^ | OC-Sensor | 20 | 40–49 years | 10538 | 0.75; (0.194, 0.994) | 0.970; (0.968, 0.974) | 0.172; (0.121, 0.233) | 0.974; (0.971, 0.977) | NR | 0.974; (0.97, 0.977)
Lee, 2014^183^ | Hemo Techt NS-Plus C system | 19 | All | 1397 | 0.714; (0.419, 0.916) | 0.955; (0.943, 0.965) | 0.619; (0.384, 0.819) | 0.963; (0.952, 0.972) | NR | NR
Liles, 2018^187^ | OC-Auto | 10 | All | 2771 | NR | NR | 0.23; (0.17, 0.28) | 0.94; (0.93, 0.95) | NR | NR
Liles, 2018^187^ | OC-Auto | 15 | All | 2771 | NR | NR | 0.16; (0.12, 0.22) | 0.96; (0.95, 0.97) | NR | NR
Liles, 2018^187^ | OC-Auto | 20 | All | 2771 | NR | NR | 0.14 (0.1, 0.19) | 0.97; (0.96, 0.97) | NR | NR
Liles, 2018^187^ | OC-Auto | 25 | All | 2771 | NR | NR | 0.14; (0.09, 0.18) | 0.97; (0.97, 0.98) | NR | NR
Liles, 2018^187^ | OC-Auto | 30 | All | 2771 | NR | NR | 0.12; (0.08, 0.17) | 0.98; (0.97, 0.98) | NR | NR
Morikawa, 2005^190^ | Magstream 1000/Hem SP | 100–200 | All | 21805 | 0.658; (0.554, 0.763) | 0.946; (0.943, 0.949) | 0.271; (0.239, 0.303) | 0.951; (0.948, 0.954) | NR | NR
Morikawa, 2005^190^ | Magstream 1000/Hem SP | 100–200 | <50 years | NR | NR | NR | NR | NR | 0.253; (NR) | NR
Morikawa, 2005^190^ | Magstream 1000/Hem SP | 100–200 | ≥60 years | NR | NR | NR | NR | NR | 0.197; (NR) | NR
Morikawa, 2005^190^ | Magstream 1000/Hem SP | 100–200 | 50–59 years | NR | NR | NR | NR | NR | 0.229; (NR) | NR
Morikawa, 2005^190^ | Magstream 1000/Hem SP | 100–200 | Distal | 21805 | NR | NR | 0.307; (0.267, 0.348) | NR | 0.261; (NR) | NR
Morikawa, 2005^190^ | Magstream 1000/Hem SP | 100–200 | Proximal | 21805 | NR | NR | 0.163; (0.113, 0.213) | NR | 0.112; (NR) | NR
Morikawa, 2005^190^ | Magstream 1000/Hem SP | 100–200 | Female | NR | NR | NR | NR | NR | 0.167; (NR) | NR
Morikawa, 2005^190^ | Magstream 1000/Hem SP | 100–200 | Male | NR | NR | NR | NR | NR | 0.239; (NR) | NR
Nakama, 1999^192^ | Monohaem | NR | 1-day collection | 4611 | 0.556 (NR) | NR | NR | 0.971; (NR) | 0.301; (NR) | NR
Nakama, 1999^192^ | Monohaem | NR | 2-day collection | 4611 | 0.833 (NR) | NR | NR | 0.960; (NR) | 0.507; (NR) | NR
Nakama, 1999^192^ | Monohaem | NR | 3-day collection | 4611 | 0.889 (NR) | NR | NR | 0.939; (NR) | 0.548; (NR) | NR
Ng, 2013^193^ | Hemosure | 50 | All | 4539 | 0.545; (0.323, 0.737) | 0.894; (0.884, 0.902) | 0.388; (0.325, 0.454) | 0.906; (0.897, 0.914) | 0.371; (0.305, 0.439) | 0.906; (0.897, 0.914)
Park, 2010^194^ | OC-Micro | 20 | All | 770 | 0.923; (0.640, 0.998) | 0.901; (0.877, 0.921) | 0.444; (0.327, 0.566) | 0.921; (0.899, 0.940) | 0.339; (0.228, 0.465) | 0.921; (0.899, 0.940)
Park, 2010^194^ | OC-Micro | 25 | All | 770 | 0.846; (0.546, 0.981) | 0.913; (0.890, 0.932) | 0.389; (0.276, 0.511) | 0.930; (0.908, 0.948) | 0.288; (0.178, 0.421) | 0.930; (0.908, 0.948)
Park, 2010^194^ | OC-Micro | 30 | All | 770 | 0.846; (0.546, 0.981) | 0.919; (0.898, 0.938) | 0.375; (0.264, 0.497) | 0.936; (0.915, 0.953) | 0.271; (0.164, 0.403) | 0.936; (0.915, 0.953)
Park, 2010^194^ | OC-Micro | 10 | All | 770 | 0.923; (0.640, 0.998) | 0.872; (0.846, 0.895) | 0.528; (0.407, 0.647) | 0.898; (0.873, 0.920) | 0.441; (0.312, 0.576) | 0.898; (0.873, 0.920)
Park, 2010^194^ | OC-Micro | 15 | All | 770 | 0.923; (0.640, 0.998) | 0.890; (0.866, 0.912) | 0.472; (0.353, 0.593) | 0.913; (0.889, 0.932) | 0.373; (0.250, 0.509) | 0.913; (0.889, 0.932)
Redwood, 2016^197^ | OC-Sensor | 20 | All | 661 | 0.80 (0.44, 0.97) | NR | 0.28; (0.19, 0.39) | 0.94; (0.91, 0.95) | NR | NR
Redwood, 2016^197^ | OC-Sensor | 20 | Screening group | 435 | 0.75 (0.20, 0.99) | NR | 0.31; (0.20, 0.44) | NR | 0.28; (0.17, 0.42) | NR
Ribbing Wilen, 2019^206^ | OC-Sensor | 10 | All | 806 | NR | NR | 0.20; (0.12, 0.30) | 0.93; (0.90, 0.94) | NR | NR
Ribbing Wilen, 2019^206^ | OC-Sensor | 20 | All | 806 | NR | NR | 0.15; (0.08, 0.24) | 0.97; (0.95, 0.98) | NR | NR
Ribbing Wilen, 2019^206^ | OC-Sensor | 40 | All | 806 | NR | NR | 0.10; (0.04, 0.18) | 0.98; (0.97, 0.99) | NR | NR
Ribbing Wilen, 2019^206^ | OC-Sensor | 60 | All | 806 | NR | NR | 0.07; (0.03, 0.15) | 0.99; (0.98, 1.0) | NR | NR
Ribbing Wilen, 2019^206^ | OC-Sensor | 80 | All | 806 | NR | NR | 0.07; (0.03, 0.15) | 0.99; (0.98, 1.0) | NR | NR
Shapiro, 2017^200^ | InSure FIT | 50 | All | 987 | NR | NR | 0.263; (0.159, 0.407) | 0.968; (0.955, 0.978) | NR | NR
Shapiro, 2017^200^ | OC FIT-CHEK | 20 | All | 947 | NR | NR | 0.151; (0.067, 0.261) | 0.978; (0.966, 0.986) | NR | NR
Sohn, 2005^201^ | OC-Hemodia | 20 | All | 3794 | 0.250 (NR) | NR | 0.024; (NR) | 0.988; (NR) | 0.024; (NR) | NR
Sohn, 2005^201^ | OC-Hemodia | 20 | Female 40–49 years | 582 | NR | NR | 0 (NR) | 0.996; (NR) | NR | NR
Sohn, 2005^201^ | OC-Hemodia | 20 | Female 50–59 years | 514 | NR | NR | 0 (NR) | 0.982; (NR) | NR | NR
Sohn, 2005^201^ | OC-Hemodia | 20 | Female 60–69 years | 233 | NR | NR | 0.02; (NR) | 0.989; (NR) | NR | NR
Sohn, 2005^201^ | OC-Hemodia | 20 | Female 70+ years | 14 | NR | NR | 0 (NR) | 1.0 (NR) | NR | NR
Sohn, 2005^201^ | OC-Hemodia | 20 | Male 40–49 years | 760 | NR | NR | 0 (NR) | 0.989; (NR) | NR | NR
Sohn, 2005^201^ | OC-Hemodia | 20 | Male 50–59 years | 617 | NR | NR | 0.028; (NR) | 0.986; (NR) | NR | NR
Sohn, 2005^201^ | OC-Hemodia | 20 | Male 60–69 years | 317 | NR | NR | 0.037; (NR) | 0.978; (NR) | NR | NR
Sohn, 2005^201^ | OC-Hemodia | 20 | Male 70+ years | 45 | NR | NR | 0.125; (NR) | 1.0 (NR) | NR | NR
Wong, 2015^204^ | Hemosure | 10 | All | 5343 | 0.545; (0.327, 0.749) | 0.905; (0.897, 0.913) | 0.347; (0.293, 0.405) | 0.917; (0.909, 0.925) | 0.331; (0.276, 0.391) | 0.915; (0.907, 0.922)
Wong, 2015^204^ | Hemosure | 10 | Distal | 5343 | 0.429; (0.188, 0.704) | NR | 0.40; (0.325, 0.479) | NR | 0.397; (0.320, 0.480) | NR
Wong, 2015^204^ | Hemosure | 10 | Proximal | 5343 | 0.714; (0.303, 0.949) | NR | 0.279; (0.20, 0.374) | NR | 0.250; (0.173, 0.346) | NR

* Calculated sensitivity, specificity, and/or confidence interval

Abbreviations: AA = advanced adenoma; AN = advanced neoplasia; CI = confidence interval; CRC = colorectal cancer; N = number; NR = not reported; sens = sensitivity; spec = specificity; µg Hb/g = micrograms hemoglobin per gram feces

##### Test Accuracy for AN and AA

Twelve studies (n=38,689)^156,^ ^164,^ ^166,^ ^167,^ ^174,^ ^175,^ ^180,^ ^187,^ ^194,^ ^197,^ ^200,^ ^206^ using OC-Sensor tests to detect AN with a colonoscopy reference standard for all participants were pooled at a cutoff of 20 μg Hb/g feces; sensitivity to detect AN was 0.25 (95% CI, 0.21 to 0.30; I^2^=78.1%) and specificity was 0.96 (95% CI, 0.95 to 0.97; I^2^=93.9%) (Figure 14 and Table 20). Similar to the results for CRC, at lower cutoffs sensitivity increased and specificity decreased. Again, few studies per cutoff and overlapping confidence intervals mean these results should be interpreted with caution.

Figure 14 Key Question 2: Forest Plot of OC-Sensor Sensitivity and Specificity to Detect Advanced Neoplasia (All Colonoscopy Follow-Up), by Cutoff (μg Hb/g Feces)

Abbreviations: AN = advanced adenoma; CI = confidence interval; FN = false negative; FP = false positive; TN = true negative; TP = true positive; µg Hb per g feces = microgram hemoglobin per gram feces

Note: For 20 μg Hb/g feces cutoff, the bivariate pooled sensitivity was 0.25 (95% CI, 0.21 to 0.30; I^2^=78.1%) and specificity was 0.96 (95% CI, 0.95 to 0.97; I^2^=93.9%). For 15 μg Hb/g feces cutoff, the bivariate pooled sensitivity was 0.31 (95% CI, 0.21 to 0.44; I^2^=89.8%) and specificity was 0.95 (95% CI, 0.93 to 0.96; I^2^=89.0%). For 10 μg Hb/g feces cutoff, the bivariate pooled sensitivity was 0.33 (95% CI, 0.23 to 0.44; I^2^=87.0%) and specificity was 0.93 (95% CI, 0.92 to 0.94; I^2^=77.8%).

Figure 14 shows a forest plot of OC-Sensor sensitivity and specificity to detect advanced neoplasia with all colonoscopy follow-up, grouped by screening test cutoff in μg Hb/g feces. For 10 μg Hb/g feces, the pooled sensitivity is 0.33 with a 95% confidence interval of 0.22 to 0.44. The pooled specificity is 0.93 with a 95% confidence interval of 0.92 to 0.94. For 15 μg Hb/g feces, the pooled sensitivity is 0.32 with a 95% confidence interval of 0.19 to 0.45. The pooled specificity is 0.95 with a 95% confidence interval of 0.93 to 0.97. For 20 μg Hb/g feces, the pooled sensitivity is 0.25 with a 95% confidence interval of 0.21 to 0.29. The pooled specificity is 0.96 with a 95% confidence interval of 0.95 to 0.97.

Ten studies (n=40,411)^156,^ ^158,^ ^164,^ ^167,^ ^174,^ ^175,^ ^180,^ ^194,^ ^197,^ ^200^ using OC-Sensor tests to detect advanced adenomas with a colonoscopy reference standard for all participants were pooled at a cutoff of 20 μg Hb/g feces; sensitivity to detect AA was 0.23 (95% CI, 0.20 to 0.25; I^2^=47.4%) and specificity was 0.96 (95% CI, 0.95 to 0.97; I^2^=94.8) (Figure 15 and Table 20). All but one of these studies^158^ also reported test accuracy to detect AN. Since most of the lesions were advanced adenomas and not cancers, the AA data are similar to the AN data. Advanced adenomas were usually defined as adenomas 1 cm or larger in size, with tubulovillous or villous components, or high-grade dysplasia, but three studies^175,^ ^197,^ ^200^ also grouped SSL with advanced adenomas. For the three studies including SSLs, sensitivity was similar to the other studies (ranging from 0.16 to 0.24) and their removal from the pooled analysis did not affect the overall sensitivity (0.24 [95% CI, 0.20 to 0.28]).

Figure 15 Key Question 2: Forest Plot of OC-Sensor Sensitivity and Specificity to Detect Advanced Adenomas (All Colonoscopy Follow-Up), by Cutoff (μg Hb/g Feces)

Abbreviations: CI = confidence interval; FN = false negative; FP = false positive; TN = true negative; TP = true positive; µg Hb per g feces = microgram hemoglobin per gram feces

Note: For 20 μg Hb/g feces cutoff, the bivariate pooled sensitivity was 0.23 (95% CI, 0.20 to 0.25; I^2^=47.4%) and specificity was 0.96 (95% CI, 0.95 to 0.97; I^2^=94.8%). For 15 μg Hb/g feces cutoff, sensitivity I^2^=34.4% and specificity I^2^=78.7%. For 10 μg Hb/g feces cutoff, sensitivity I^2^=0% and specificity I^2^=89.1%.

Figure 15 shows a forest plot of OC-Sensor sensitivity and specificity to detect advanced adenomas with all colonoscopy follow-up, grouped by screening test cutoff in μg Hb/g feces. For 10 μg Hb/g feces, the pooled sensitivity is 0.34 with a 95% confidence interval of 0.30 to 0.38. The pooled specificity is 0.92 with a 95% confidence interval of 0.90 to 0.94. For 15 μg Hb/g feces, the pooled sensitivity is 0.29 with a 95% confidence interval of 0.24 to 0.34. The pooled specificity is 0.95 with a 95% confidence interval of 0.93 to 0.96. For 20 μg Hb/g feces, the pooled sensitivity is 0.23 with a 95% confidence interval of 0.20 to 0.25. The pooled specificity is 0.96 with a 95% confidence interval of 0.95 to 0.97.

Four studies^158,^ ^166,^ ^175,^ ^200^ also reported sensitivity for sessile serrated lesions alone (with one study^175^ examining only sessile serrated polyps 1 cm or larger). At a cutoff of 20 μg Hb/g feces, sensitivity to detect SSLs ranged from 0.02 to 0.07 (95% CI range, 0.0 to 0.15).

##### Alternate Study Designs

Eight studies (n=2,476,032)^154,^ ^159–161,^ ^170,^ ^173,^ ^179,^ ^189^ using OC-Sensor tests to detect CRC, with cancer registry followup to identify CRC, were pooled at a cutoff of 20 μg Hb/g feces (Appendix D Table 5 and Appendix E Figure 2). The pooled estimate of sensitivity to detect CRC (0.81 [95% CI 0.74 to 0.88]) for these studies with registry followup was higher than that of the studies with colonoscopy provided to all participants; however, the confidence intervals overlapped. The pooled specificity was consistent with the studies with colonoscopy for all participants (0.95 [95% CI, 0.94 to 0.96]). Two of the studies reported cutoffs at 10 and/or 15 μg Hb/g feces; one study reporting all three cutoffs (10, 15, and 20 μg Hb/g feces) showed the same trend of increasing sensitivity and decreasing specificity as the cutoff was lowered. In another study^173^ with multiple cutoffs (2.2, 2.8, 4.4, 7.2, 9, and 10 μg Hb/g feces) sensitivity appeared to increase for lower test cutoffs as well.

One nested case-control study^171^ in Germany compared the performance of nine quantitative FITs, including OC-Sensor. The sensitivity of OC-Sensor to detect colorectal lesions was lower than that found in our other included studies. However, within that study, OC-Sensor had similar test performance compared with the other FITs and the confidence intervals for all FITs overlapped with one another. The authors reported that a desired specificity could be achieved with similar sensitivities for all tests by adjusting cutoffs.

Three studies^173,^ ^199,^ ^202^ using OC-Sensor reported sensitivity for more than one round of screening. Two of these studies^173,^ ^202^ suggested that the sensitivity to detect CRC in the second round of screening was lower than in the initial round of screening; however, estimates of sensitivity were imprecise with 95 percent confidence intervals for both rounds widely overlapping.

##### By Location or Stage

Three studies^167,^ ^189,^ ^202^ examined the test accuracy of OC-Sensor tests to detect CRC by location in the colon (distal or proximal). The findings were inconsistent among the three studies. One of the studies^167^ had colonoscopy followup for all participants, but the number of cancers was low (6 distal CRCs and 2 proximal CRCs). The other two studies utilized cancer registries to identify cancers (11 and 419 distal CRCs; 9 and 153 proximal CRCs). Confidence intervals for sensitivity to detect proximal and distal CRC were very wide and overlapped in the two studies with a low number of cancers, but point estimates indicated OC-Sensor was more sensitive for proximal cancers. The largest study indicated OC-Sensor had a higher sensitivity to detect distal CRC at 20 μg Hb/g feces (0.91 [95% CI, 0.88 to 0.93]), than for proximal CRC (0.74 [95% CI, 0.66 to 0.80]).

Two studies^189,^ ^202^ presented the test accuracy of OC-Sensor to detect CRC by stage; both studies used cancer registries to identify cancers. In general, there appeared to be a trend of decreasing sensitivity as stage increased, but confidence intervals overlapped and one of the studies^202^ had a very low number of CRCs (9 Stage I, 3 Stage II, 6 Stage III, 2 Stage IV), prohibiting making any definitive conclusions.

##### By Age, Sex, Race/Ethnicity, or Family History

Six studies^154,^ ^159,^ ^161,^ ^180,^ ^189,^ ^199^ using either colonoscopy or registry reference standards reported the test accuracy of OC-Sensor for a variety of age groups (i.e., 40–49 years, <50 years, ≥50 years, 50–59 years, 50–75 years, 50–54 years, 55–59 years, 60–64 years, 60–69 years, ≥65 years, 65–69 years, 70–75 years); only two studies^159,^ ^180^ stratified their results by age groups under 50 years. Among all studies, there were no patterns or differences in the sensitivity and specificity to detect CRC among different age groups, although one study^199^ demonstrated that programmatic sensitivity and specificity both decreased with age.

Three studies reported test accuracy for OC-Sensor by sex.^159,^ ^167,^ ^199^ Two large registry followup studies reported the test accuracy of OC-Sensor to detect CRC had different findings. At a cutoff of 20 μg Hb/g feces, one study found no differences between male and female subgroups.^159^ A second study consistently found an increased sensitivity and decreased specificity in men compared with women at a variety of cutoffs (p<0.05 for sensitivity and specificity at a cutoff of 20 μg Hb/g feces).^199^ One additional study with a colonoscopy reference standard reported the test accuracy of OC-Sensor to detect AN, generally reporting higher sensitivities and lower specificities for males at a variety of cutoffs, but these results were not statistically significant.^167^

One study^166^ provided a direct within study comparison of Black and white race, although one additional study^197^ was limited to Alaska Natives and another^158^ was limited to ethnic Chinese. All three studies used colonoscopy reference standards. When stratified by Black and white race, there were no differences between groups for OC-Sensor detection of advanced neoplasia.

No studies provided test accuracy stratified by family history of CRC.

#### Other FITs

##### Test Accuracy for CRC

Nine additional FITs to detect CRC were assessed in 11 studies^155,^ ^156,^ ^162,^ ^163,^ ^165,^ ^183,^ ^190,^ ^192,^ ^193,^ ^200,^ ^204^ with a colonoscopy reference standard for all participants (Figure 16 and Table 20). OC-Light was the only FIT reported in more than one study (k=3),^162,^ ^163,^ ^165^ with pooled sensitivity to detect CRC of 0.81 (95% CI, 0.70 to 0.91; I^2^=0%) and specificity of 0.93 (95% CI, 0.91 to 0.96; I^2^=99.0%). For other FITs, cutoffs varied from 2 to 100 ug/g and sensitivity ranged from 0.50 to 0.97 (95% CI range, 0.09 to 1.00). Specificity had less variation, ranging from 0.83 to 0.97 (95% CI range, 0.82 to 0.97).

Figure 16 Key Question 2: Forest Plot of Other FITs Sensitivity and Specificity to Detect Colorectal Cancer (All Colonoscopy Follow-Up)

Abbreviations: CI = confidence interval; CRC = colorectal cancer; µg Hb per g feces = microgram hemoglobin per gram feces

Figure 16 shows a forest plot of other FITs sensitivity and specificity to detect colorectal cancer (all colonoscopy follow-up). The sensitivity ranged from 0.50 to 0.97 and specificity ranged from 0.83 to 0.97.

##### Test Accuracy for AN

We identified 13 studies^155,^ ^156,^ ^162,^ ^163,^ ^165,^ ^183,^ ^186,^ ^190,^ ^192,^ ^193,^ ^200,^ ^201,^ ^204^ with 13 FITs to detect advanced neoplasia with a colonoscopy reference standard for all participants (Table 20). OC-Light was used in four studies,^162,^ ^163,^ ^165,^ ^186^ with pooled sensitivity to detect AN of 0.27 (95% CI, 0.16 to 0.38; I^2^=91.4%) and specificity of 0.95 (95% CI, 0.92 to 0.98; I^2^=98.8%) at a cutoff of 10 μg Hb/g feces. The only other FIT reported in more than one study was Hemosure (k=2). For the other tests cutoffs varied from 6 to 100 μg Hb/g feces, and the sensitivity to detect AN ranged from 0.02 to 0.66 (95% CI range, 0.01 to 0.99) and specificity ranged from 0.60 to 0.99 (95% CI range, 0.58 to 1.0).

##### Test Accuracy for AA

Nine studies^155,^ ^156,^ ^162,^ ^163,^ ^165,^ ^190,^ ^193,^ ^200,^ ^204^ reported the test accuracy of seven FITs to detect advanced adenomas (Table 20). Two studies grouped SSPs with advanced adenomas. Two FITs were reported in more than one study: OC-Light (k=3) and Hemosure (k=2). The pooled sensitivity and specificity of OC-Light to detect AA were 0.28 (95% CI, 0.19 to 0.37; I^2^=86.3%) and 0.94 (95% CI, 0.91 to 0.97; I^2^=99.2%), respectively. For the other FITs, cutoffs varied from 2 to 100 μg Hb/g feces and sensitivity to detect AA ranged from 0.18 to 0.50 (95% CI range, 0.13 to 0.56), but specificity was more consistent between studies (range 0.85 to 0.98 [95% CI range, 0.84 to 0.98]).

##### Alternate Study Designs

We identified ten additional studies using eight FITs (OC-Hemodia, OC-Sensor combined with FOB Gold, FOB Gold, HM-Jack, Monohaem, Magstream, HemeSelect, and FlexSure OBT) to screen for CRC with cancer registry followup to identify CRC cases (Appendix E Figure 3 and Appendix D Table 5); only OC-Hemodia tests were reported in more than one study (k=2).^176^ The cutoff for the OC-Hemodia tests ranged from 2.2 to 20 μg Hb/g feces, and sensitivity to detect CRC ranged from 0.81 to 0.87 (95% CI range, 0.75 to 0.92). The remaining FITs had sensitivity to detect CRC ranging from 0.69 to 0.90 (95% CI range, 0.45 to 0.94) and specificity ranging from 0.84 to 0.96 (95% CI range, 0.84 to 0.96).

One study^153^ reported the sensitivity of a FIT (FlexSure OBT) to detect distal CRC only, with a sensitivity of 0.82 (95% CI, 0.48 to 0.97) and a specificity of 0.97 (95% CI, 0.96 to 0.97). One nested case-control study^171^ in Germany (described earlier for OC-Sensor) compared the performance of nine quantitative FITs. The authors reported that a desired specificity could be achieved with similar sensitivities for all FITs by adjusting cutoffs.

One study^154^ using OC-Sensor combined with FOB Gold reported sensitivity over two rounds of screening. The sensitivity to detect CRC was similar in the initial and subsequent round of screening.

##### By Location or Stage

No clear patterns were identified for distal versus proximal CRC detection. One study^204^ using Hemosure with colonoscopy followup reported higher sensitivity for proximal versus distal CRC detection, but the confidence intervals overlapped. A study^165^ using OC-Light reported higher distal sensitivity, but confidence intervals again overlapped. Two additional studies (one using FOB Gold with colonoscopy followup^155^ and the other using OC-Sensor or FOB Gold with registry followup^203^) did not find differences in distal and proximal sensitivity. One other study^153^ only reported distal sensitivity for FlexSure OBT (no proximal sensitivity reported); the sensitivity was consistent with the other registry followup study. For advanced neoplasia, five studies^155,^ ^156,^ ^165,^ ^190,^ ^204^ of five FITs with colonoscopy followup consistently showed higher sensitivity to detect distal versus proximal neoplasia; three of these studies did not have overlapping confidence intervals. Similarly, sensitivity of distal advanced adenomas was higher than proximal advanced adenomas.

One study^203^ using OC-Sensor or FOB Gold for four rounds of screening with registry followup reported higher sensitivity for Stage I versus Stage IV detection, however, there were few Stage IV CRC cases (n=13) and the confidence intervals overlapped.

##### By Age, Sex, Race/Ethnicity, or Family History

No clear difference in test accuracy by age was found. One study^203^ using OC-Sensor or FOB Gold for four rounds of screening with registry followup reported no difference in sensitivity by age groups. OC-Light had lower sensitivity at younger ages in one study,^162^ but the study was limited by few CRC cases (n=5 for ages 40–49, n=16 for older ages) and confidence intervals overlapped. For advanced neoplasia and advanced adenomas, two studies with colonoscopy followup^190,^ ^201^ reported sensitivity by age; no statistically significant difference was found by age groups.

One study^203^ using OC-Sensor or FOB Gold for four rounds of screening with registry followup reported no differences by sex. One study^208^ using FOB Gold with registry followup found that sensitivity to detect CRC for females was lower than males at higher cutoffs, but did not differ at lower cutoffs. Two studies^190,^ ^201^ with colonoscopy followup also reported no differences in sensitivity for the detection of AA or AN by sex.

There were no race/ethnicity or family history subgroup results reported for other FITs.

#### sDNA

We identified four studies^166,^ ^175,^ ^197,^ ^209^ reporting test accuracy for a sDNA test; all were evaluating a multitarget sDNA test known as Cologuard from a single manufacturer (Exact Sciences). This test evaluates 10 DNA methylation and mutation markers plus the hemoglobin protein using immunochemical testing, therefore in this report is referred to as sDNA-FIT. Three studies^166,^ ^197,^ ^209^ published their results after the 2016 review (Table 13).

##### Study and Population Characteristics

Three of the four studies were conducted fully or partially in the United States, the other was conducted in the Netherlands as part of the COCOS trial^209^ (Table 21). One study had a large sample size of 9,989 participants; the other three studies were smaller and had sample sizes ranging from 661 to 1,014. Prevalence of CRC ranged from 0.3 to 1.5 percent, and prevalence of advanced adenomas ranged from 6.7 to 13.9 percent. Mean or median age ranged from 55 to 64 years; two of the smaller U.S.-based studies recruited participants age 40 years and older; the other two studies recruited participants age 50 years and older. Participants in the largest study and the study conducted in the Netherlands were primarily white (84% and 96%, respectively). This was also true in one of the smaller studies (65% white), which also had a large proportion of Black participants (35%). The remaining study was conducted exclusively among Alaska Natives.

Table 21 Key Question 2: Study and Population Characteristics for sDNA

Reference standard | Author, year | Quality | Country | N screened | Prevalence, n (%) | Age, mean | Female, % | Race/Ethnicity, % | Family history, %
Colonoscopy | Cooper, 2018^*^,^166^ | Fair | US | 760 | CRC: 2 (0.3); AA: 49 (6.4) | 56.7 | 60.2 | White: 65.1; Black: 34.9 | NR
Colonoscopy | Bosch, 2019^209^ | Good | NLD | 1014 | CRC: 7 (0.7); AA: 119 (11.7) | 60 | 49 | White: 96 | 16 (1+ FDR)
Colonoscopy | Redwood, 2016^*^,^197^ | Fair | US | 661 | CRC: 10 (1.5); AA: 82 (12.4) | 55 (median) | 60 | AN: 100 | NR
Colonoscopy | Imperiale, 2014^175^ | Fair | US, CAN | 9,989 | CRC: 65 (0.6); AA: 757 (7.6) | 64.2 | 53.7 | White: 84.0; Black: 10.7; Other: 5.2 | 0 (no specific definition reported)

* Newly identified study since the previous review

Abbreviations: AA = advanced adenoma; CAN = CAN; CRC = colorectal cancer; FDR = first-degree relative; n = number; NLD = the Netherlands; US = United States

All four studies used colonoscopy as the reference standard for all participants, and all three conducted in the United States were rated as fair quality. These studies were at a higher risk of bias due to patient selection or patient attrition (small differences in the participants who were evaluated versus those who did not have evaluable data). The study conducted in the Netherlands was rated as good quality.

##### Test Accuracy for CRC

Three studies reported the test accuracy of Cologuard to identify CRC (Figure 17 and Table 22). The pooled sensitivity to detect CRC was 0.93 (95% CI, 0.87 to 1.0; I^2^=0%) and the pooled specificity was 0.85 (95% CI, 0.84 to 0.86; I^2^=37.7%).

Figure 17 Key Question 2: Forest Plot of Cologuard Sensitivity and Specificity to Detect Colorectal Cancer, Advanced Neoplasia, and Advanced Adenomas

Abbreviations: CI = confidence interval; CRC = colorectal cancer; FN = false negative; FP = false positive; TN = true negative; TP = true positive

Note: For CRC, sensitivity I^2^=0% and specificity I^2^=37.7%. For advanced neoplasia, sensitivity I^2^=0% and specificity I^2^=88.8%. For advanced adenoma, sensitivity I^2^=0% and specificity I^2^=87.8%.

Figure 17 shows a forest plot of Cologuard sensitivity and specificity to detect colorectal cancer, advanced neoplasia, and advanced adenomas. The pooled sensitivity to detect CRC is 0.93 with a 95% confidence interval of 0.87 to 1.0; the pooled specificity is 0.85 with a 95% confidence interval of 0.84 to 0.86. For advanced neoplasia, the pooled sensitivity is 0.47 with a 95% confidence interval of 0.44 to 0.50; the pooled specificity is 0.89 with a 95% confidence interval of 0.87 to 0.92. For advanced adenomas, the pooled sensitivity to is 0.43 with a 95% confidence interval of 0.40 to 0.46; the pooled specificity is 0.89 with a 95% confidence interval of 0.86 to 0.92.

Table 22 Key Question 2: Results for sDNA Test Accuracy

Author, year | Screened group | N analyzed | CRC sens (95% CI) | CRC spec (95% CI) | AN sens (95% CI) | AN spec (95% CI) | AA sens (95% CI) | AA spec (95% CI)
Cooper, 2018^*^,^166^ | All | 760 | NR | NR | 0.43 (0.31, 0.57) | 0.91 (0.88, 0.95) | NR | NR
Cooper, 2018^*^,^166^ | Black | 265 | NR | NR | 0.50 (0.29, 0.71) | 0.92 (0.88, 0.95) | NR | NR
Cooper, 2018^*^,^166^ | White | 495 | NR | NR | 0.39 (0.25, 0.56) | 0.91 (0.89, 0.93) | NR | NR
Bosch, 2019^209^ | All | 1014 | 0.86 (0.42, 1.0) | 0.85 (0.84, 0.86) | 0.48 (0.40, 0.57) | 0.89 (0.87, 0.92) | 0.46 (0.37, 0.56) | 0.89 (0.87, 0.91)
Redwood, 2016^*^,^197^ | All | 661 | 1.0 (0.69, 1.0) | 0.87 (0.84, 0.89) | 0.49 (0.38, 0.60) | 0.91 (0.88, 0.93) | 0.43 (0.33, 0.53) | 0.91 (0.88, 0.93)
Imperiale, 2014^175^ | All | 9989 | 0.92 (0.83, 0.98) | 0.84; (0.84,0.85) | 0.46 (0.43, 0.50) | 0.87 (0.86, 0.87) | 0.42 (0.39, 0.46) | 0.87 (0.86, 0.87)
Imperiale, 2014^175^ | Female | 5408 | 0.84 (0.67, 0.93) | 0.85 (0.83, 0.86) | NR | NR | 0.39 (0.34, 0.45) | 0.87 (0.85, 0.89)
Imperiale, 2014^175^ | Male | 4645 | 1.00; (0.90,1.00) | 0.85 (0.84, 0.86) | NR | NR | 0.45 (0.40, 0.49) | 0.87 (0.86, 0.88)
Imperiale, 2014^175^ | White | 8422 | 0.96 (0.88, 0.99) | 0.84 (0.83, 0.85) | NR | NR | 0.42 (0.39, 0.46) | 0.86 (0.85, 0.87)
Imperiale, 2014^175^ | Black | 1071 | 0.63 (0.31, 0.86) | 0.87 (0.85, 0.89) | NR | NR | 0.42 (0.32, 0.53) | 0.90 (0.88, 0.92)
Imperiale, 2014^175^ | Asian | 259 | 1.00 (0.21, 1.00) | 0.92 (0.88, 0.95) | NR | NR | 0.31 (0.13, 0.58) | 0.94 (0.90, 0.96)
Imperiale, 2014^175^ | AI/AN | 36 | NA | 0.69 (0.53, 0.82) | NR | NR | 0.75 (0.30, 0.95) | 0.75 (0.58, 0.87)
Imperiale, 2014^175^ | Hawaiian/PI | 23 | NA | 0.91 (0.73, 0.98 | NR | NR | NA | 0.91 (0.73, 0.98)
Imperiale, 2014^175^ | Other race | 206 | 1.00 (0.21, 1.00) | 0.88 (0.83, 0.92) | NR | NR | 0.44 (0.23, 0.67) | 0.90 (0.85, 0.94)
Imperiale, 2014^175^ | Hispanic | 991 | 0.89 (0.57, 0.98) | 0.89 (0.87, 0.91) | NR | NR | 0.39 (0.28, 0.52) | 0.91 (0.89, 0.92)
Imperiale, 2014^175^ | Non-Hispanic | 9028 | 0.93 (0.83, 0.97) | 0.84 (0.83, 0.85) | NR | NR | 0.43 (0.39, 0.46) | 0.86 (0.85, 0.87)
Imperiale, 2014^175^ | <60 years | 2881 | 1.00 (0.65, 1.00) | 0.90 (0.89, 0.91) | NR | NR | 0.38 (0.31, 0.45) | 0.92 (0.91, 0.93
Imperiale, 2014^175^ | 60–64 yeas | 826 | 0.75 (0.30, 0.95) | 0.87 (0.84, 0.89) | NR | NR | 0.42 (0.30, 0.55) | 0.89 (0.87, 0.91)
Imperiale, 2014^175^ | 65–69 years | 3673 | 0.95 (0.76, 0.99) | 0.83 (0.82, 0.85) | NR | NR | 0.41 (0.36, 0.47) | 0.86 (0.84, 0.87)
Imperiale, 2014^175^ | 70–74 years | 1738 | 0.89 (0.67, 0.97) | 0.80 (0.78, 0.82) | NR | NR | 0.47 (0.39, 0.55) | 0.82 (0.81, 0.84)
Imperiale, 2014^175^ | 75–79 years | 685 | 1.00 (0.61, 1.00) | 0.76 (0.72, 0.79) | NR | NR | 0.47 (0.35, 0.59) | 0.78 (0.74, 0.81)
Imperiale, 2014^175^ | >79 years | 220 | 0.90 (0.60, 0.98) | 0.76 (0.70, 0.81) | NR | NR | 0.47 (0.25, 0.70) | 0.78 (0.72, 0.83)

* Newly identified study since the previous review

Abbreviations: AA = advanced adenoma; AN = advanced neoplasia; CI = confidence interval; CRC = colorectal cancer; N = number; NR = not reported; sens = sensitivity; spec = specificity

##### Test Accuracy for AN and AA

Four studies reported the test accuracy of Cologuard to identify AN (three studies^175,^ ^197,^ ^209^ categorized SSLs—as well as advanced adenomas and CRC—as advanced neoplasia). The pooled sensitivity was 0.47 (95% CI, 0.44 to 0.50; I^2^=0%) and the pooled specificity was 0.89 (95% CI, 0.87 to 0.92; I^2^=88.8%) (Figure 17).

Three studies^175,^ ^197^ reported the test accuracy of Cologuard to detect AA. Advanced adenomas were defined as adenomas 1 cm or larger, containing >25% villous component, or high-grade dysplasia, or SSL 1 cm or larger. The pooled sensitivity to detect AA was 0.43 (95% CI, 0.40 to 0.46; I^2^=0%) and the pooled specificity was 0.89 (95% CI, 0.86 to 0.92; I^2^=87.8%) (Figure 17 and Table 22). For large SSL (sessile serrated adenomas or polyps 1 cm or larger plus serrated polyps with dysplasia in one study^209^) alone, three studies^166,^ ^175^ reported sensitivity ranging from 0.40 to 0.42 (95% CI range, 0.22 to 0.61). For any size SSL, one study^166^ reported a sensitivity of 0.28 (95% CI, 0.16 to 0.43).

##### By Location or Stage

One study^175^ reported sensitivity of Cologuard to detect advanced adenomas by location. For distal advanced adenomas, sensitivity was 0.54 (95% CI, 0.49 to 0.60) and for proximal advanced adenomas, sensitivity was 0.33 (95% CI, 0.29 to 0.38).

##### By Age, Sex, Race/Ethnicity, or Family History

The largest study^175,^ ^351^ on Cologuard reported test accuracy by age, sex, and race/ethnicity groups, although it was not designed to examine these differences. This study found that the specificity to detect CRC and AA decreases with increasing age, but there was not a clear pattern for increasing sensitivity with increasing age. Differences in test accuracy by sex—higher sensitivity and lower specificity in men compared to women— were not statistically significant. Findings were inconsistent in two studies reporting test accuracy for white participants compared to Black participants; one study^175,^ ^351^ reported lower sensitivity for Black participants and the other^166^ found no statistically significant differences between white and Black participants.

Subgroups results by family history were not reported.

### Detailed Results for Serum-Based Tests

We identified one fair-quality study^196^ that reported the test characteristics of a blood serum test to screen for CRC in average-risk adults (Table 13). This nested case-control study included participants from the PRESEPT study (Prospective Evaluation of Septin 9) and evaluated the mSEPT9 marker using Epi proColon. Our previous review^82,^ ^83^ included the original prospective analysis of PRESEPT,^352^ which examined the first generation of Epi proColon. The first generation of the test is no longer available, and results from that article are not discussed further here.

#### Study and Population Characteristics

The PRESEPT study enrolled 7,941 participants from the United States and Germany; 6,857 participants met all criteria and had samples that could be re-analyzed in this retrospective analysis. All valid available samples from participants with CRC (44 of 50) and advanced adenoma (621 of 653) were selected and a stratified random sample was selected of participants of those with small polyps (435 of 2,369) and those with no evidence of disease (444 of 3,785). Among the 6,857 participants, CRC prevalence was 0.7 percent and prevalence of advanced adenomas was 9.5 percent. For the final case-control sample (n=1,544), prevalence of CRC was 2.8 percent and prevalence of advanced adenomas was 40.2 percent. Participants were all 50 years or older, 47 percent were female, and 73 percent were white. Eighty-one percent were recruited from the United States.

#### Test Accuracy for CRC

Sensitivity of Epi proColon to detect CRC was 0.68 (95% CI, 0.53 to 0.80) and specificity was 0.79 (95% CI, 0.77 to 0.81).

#### Test Accuracy for AN and AA

For the detection of AN, sensitivity was 0.25 (95% CI, 0.22, 0.28) and specificity was 0.79 (95% CI, 0.76 to 0.82). Due to the low number of CRCs, the sensitivity and specificity to detect AA were similar to those for AN, at 0.22 (95% CI, 0.18 to 0.24) and 0.79 (95% CI, 0.76 to 0.82), respectively.

#### By Stage or Location

In general, sensitivity of Epi proColon to detect CRC by stage increased as the stage of CRC increased; however, confidence intervals for the sensitivity to detect CRC at all stages overlapped. For Stage I, sensitivity was 0.41 (95% CI, 0.22 to 0.64) and for Stage IV sensitivity was 1.00 (95% CI, 0.57 to 1.00). Location-specific results were not reported.

#### By Age, Sex, Race/Ethnicity, or Family History

No subgroup results by age, sex, race/ethnicity, or family history were reported.

### Detailed Results for Urine-Based Tests

We identified one study^168^ in two publications^168,^ ^353^ that developed a metabolomic-based urine test, PolypDx, to detect adenomas (Table 13). Originally the test was developed on a nuclear magnetic resonance (NMR) platform and found 14 metabolites to distinguish people with adenomas from people without adenomas.^353^ Since NMR is mainly used for research and is less suitable for clinical tests due to cost and expertise required, a mass spectrometry-based urine metabolomic test was subsequently developed using three clinical features (age, sex, and smoking status) and three metabolites (succinic acid, ascorbic acid, and carnitine).^168^

#### Study and Population Characteristics

The study used urine samples from 685 average- and high-risk participants recruited to SCOPE (Stop Colorectal Cancer through Prevention and Education), a regional colon cancer screening program in Edmonton, Canada. Fifty-nine percent were high-risk participants, defined as having a personal or family history of CRC or polyps. Results are not reported separately for non-high-risk participants. All participants provided a mid-stream urine sample and a stool sample, and completed a colonoscopy. The mean age for the 685 participants was 57 years, and 54 percent were female. Only one participant was diagnosed with CRC (0.1%); colonoscopy identified adenomas for 22.5 percent of participants.

The study was rated fair quality. Risk of bias concerns included unclear blinding of the endoscopist and patient attrition (loss of urine samples no longer valid for analysis).

#### Test Accuracy for AN and AA

The authors split the sample into a training data set with two-thirds of the sample (n=457) and a testing data set with the remaining one-third (n=228). The two datasets were balanced for age, sex, and class. Among the testing dataset, sensitivity to detect AN at various thresholds ranged from 0.43 to 0.92 (95% CI range, 0.30 to 1.00) and specificity ranged from 0.19 to 0.91 (95% CI range, 0.13 to 1.00). Thresholds were selected to obtain either high sensitivity (0.7, 0.8, or 0.9) or high specificity (0.7, 0.8, or 0.9); when high sensitivity was selected, the corresponding specificity was low, and when high specificity was selected, the corresponding sensitivity was low. The study compared the test performance of PolypDx to two FITs (Immune ICT and Immune MagSt); at similar specificities (>0.90), PolypDx had higher sensitivity (0.43, 95% CI: 0.30, 0.57) and similar specificity (0.91; 95% CI: 0.87, 0.96) compared with the FITs (sensitivity: 0.18 and 0.21, specificity: 0.97 and 0.92), but confidence intervals for the FITs and statistical significance of the differences between tests were not reported.

#### By Stage, Location, Age, Sex, Race/Ethnicity, or Family History

No subgroup results by age, sex, race/ethnicity, or family history were reported.

## KQ3 What Are the Serious Harms of the Different Screening Tests? Do the Serious Harms of Screening Tests Vary by Subgroups (e.g., Age, Sex, Race/Ethnicity)?

### Summary of Results

We included 131 fair- or good-quality studies (in 162 articles) (Table 4). Among these were 18 studies that evaluated serious harms from screening flexible sigmoidoscopy, 67 studies on screening colonoscopy, 21 studies on followup colonoscopy (colonoscopy that follows an abnormal result from a stool test, FS, or CTC), and 38 studies that evaluated CTC. Of the studies evaluating CTC, seven provided estimates of radiation exposure and 27 reported extracolonic findings. Sixty-eight studies included asymptomatic (screening) populations, and 63 studies included both asymptomatic and symptomatic (mixed) populations. Thirty-seven studies are new since the previous review.

Serious adverse events from colonoscopy are estimated at 3.1 perforations (95% CI, 2.3 to 4.0) and 14.6 major bleeds (95% CI, 9.4 to 19.9) per 10,000 procedures for screening populations. Serious adverse events from screening FS alone are less common, with a pooled estimate of 0.2 perforations (95% CI, 0.1 to 0.4) and 0.5 major bleeds (95% CI, 0 to 1.3) per 10,000 procedures. However, the pooled estimates are 12.0 perforations (95% CI, 7.5 to 16.5) and 20.7 major bleeds (95% CI, 8.2 to 33.2) per 10,000 colonoscopy procedures following an abnormal FS screening result. Serious adverse events from colonoscopy following stool testing with an abnormal result are estimated at 5.4 perforations (95% CI 3.4 to 7.4) and 17.5 serious bleeds (95% CI, 7.6 to 27.5) per 10,000 colonoscopy procedures.

Twenty-three studies provided analyses of differential harms of colonoscopy by age. These studies generally found increasing rates of serious adverse events with increasing age, including perforation and bleeding.

Other harms besides bleeding and perforation, such as cardiopulmonary events or infections, may result from screening but are best assessed in studies with comparison groups since they may occur for reasons other than screening. Only four studies^125,^ ^294,^ ^304,^ ^309^ reported harms in a cohort that received colonoscopy compared with a cohort that did not. These studies did not find a higher risk of serious harms associated with colonoscopy.

Data from 17 studies show there is little to no risk of serious adverse events (e.g., symptomatic perforation) for screening CTC. While CTC may also require followup or therapeutic colonoscopy, we did not find sufficient evidence to estimate serious adverse events from colonoscopy followup. CTC also entails exposure to low-dose ionizing radiation (range 0.8 to 5.3 mSv) which may increase the risk of malignancy. Additionally, extracolonic findings on CTC are very common. Approximately 1.3 to 11.4 percent of examinations have extracolonic findings that necessitate diagnostic followup. From empirical evidence to date, it remains unclear whether detection of extracolonic findings represents an overall true benefit (from detection and treatment of clinically significant disease) or harm (from unnecessary diagnostic workup or identification of disease without clinical intervention).

No serious harms were reported in one small study of capsule endoscopy. We found no studies examining the harms of stool, serum, or urine testing, but neither do we hypothesize serious harms for these noninvasive tests other than diagnostic inaccuracy (i.e., false-positive or false-negative testing) or downstream harms of followup testing.

### Detailed Results for the Harms of Direct Visualization Tests

#### Harms of Flexible Sigmoidoscopy Screening

We found 18 fair- or good-quality studies (n=395,077) that evaluated serious harms from screening FS in a general-risk population (Table 23). Five studies^130,^ ^249,^ ^264,^ ^297,^ ^301^ were conducted in the United States. The length of followup was not commonly reported, but when reported was approximately 1 month. No studies reported harms in comparison groups. One additional study^129^ (n=2,108) reported perforations associated with FS post FOBT/FIT.

Table 23 Key Question 3: Harms of Flexible Sigmoidoscopy Screening

Author, year | Country | Female, % | Mean age, years | Followup | Group | n | n with serious bleeding events | n with perforation events | n with other SAEs
Miller, 2019^130^ | US | 51 | NR | Not specified | Total | 107236 | NR | 3 | NR
Steele, 2020^150^ | GBR | 50 | NR | Not specified | Total | 25851 | NR | NR | SAE: 0
Holme, 2018^127^ | NOR | 50 | 56 | Not specified | Total^*^ | 12960 | NR | 0 | NR
Holme, 2018^127^ | NOR | 50 | 56 | Not specified | 55–64 years^*^ | 13653 | NR | NR | SAE: 0
Atkin, 2017^119^ | GBR | 51 | 60 | 30 days | Total | 40332 | 12^#^ | 1 | MI - non-fatal: 2
Atkin, 2017^119^ | GBR | 51 | 60 | 30 days | Total | 40332 | 12^#^ | 1 | Pulmonary embolism: 1
Atkin, 2017^119^ | GBR | 51 | 60 | 30 days | Total | 40332 | 12^#^ | 1 | Glutaraldehyde-induced colitis: 5
Atkin, 2017^119^ | GBR | 51 | 60 | 30 days | Total | 40332 | 12^#^ | 1 | Mortality - possibly from screening: 6
Kim, 2013^255^ | KOR | 63 | 68^†^ | Not specified | Total | 20653 | NR | 1 | NR
Tam, 2013^297^ | US | 46 | 67 | Not specified | Total | 46158 | NR | 1 | NR
Segnan, 2011^140^ | ITA | 50 | 60 | 30 days | Total | 9911 | 0 | 1 | Seizures: 2
Segnan, 2011^140^ | ITA | 50 | 60 | 30 days | Total | 9911 | 0 | 1 | Glutaraldehyde-induced colitis: 2
Segnan, 2007^142^ | ITA | 51 | NR | 30 days | Total | 1197 | NR | NR | Total hospitalizations: 16
Segnan, 2007^142^ | ITA | 51 | NR | 30 days | Total | 1197 | NR | NR | Hospitalization - due to cardiovascular event: 3
Segnan, 2007^142^ | ITA | 51 | NR | 30 days | Total | 1197 | NR | NR | Hospitalization - due to rectal prolapse: 1
Segnan, 2007^142^ | ITA | 51 | NR | 30 days | Total | 1197 | NR | NR | Hospitalization - due to other GI event: 2
Viiala, 2007^300^ | AUS | 41 | 60 | Not specified | Total | 3402 | 0 | 0 | NR
MACS Group, 2006^272^ | AUS | 49 | NR | 4 weeks | Total | 52 | 0 | 0 | SAE: 0
Segnan, 2005^141^ | ITA | 53 | NR | Not specified | Total | 4466 | 0 | NR | Cardiac event: 1
Jain, 2002^249^ | US | NR | NR | Not specified | Total | 5017 | 0 | 0 | Mortality: 0
Levin, 2002^264^ | US | 49 | 61 | 4 weeks | Total | 109534 | 2 | 2 | MI: 33^‡^
Levin, 2002^264^ | US | 49 | 61 | 4 weeks | Total | 109534 | 2 | 2 | Other serious GI AEs: 3
Levin, 2002^264^ | US | 49 | 61 | 4 weeks | Total | 109534 | 2 | 2 | Mortality: 10
Hoff, 2001^245^ | NOR | NR | NR | Not specified | Total | 775 | 0 | 0 | Hospitalization: 1^§^
Hoff, 2001^245^ | NOR | NR | NR | Not specified | Total | 775 | 0 | 0 | SAE: 0
Wallace, 1999^301^ | US | 50 | 59 | Not specified | Total | 3701 | 0 | 0 | Mortality: 0
Atkin, 1998^213^ | GBR | NR | NR | Not specified | Total | 1285 | 0 | NR | Mortality - screening-related: 1
Atkin, 1998^213^ | GBR | NR | NR | Not specified | Total | 1285 | 0 | NR | MI: 1
Atkin, 1998^213^ | GBR | NR | NR | Not specified | Total | 1285 | 0 | NR | Hospitalization: 1
Verne, 1998^147^ | GBR | 50 | NR | 0 | Total | 1116 | NR | NR | SAE: 0
Brevinge, 1997^121^ | SWE | 49 | NR | 0 | Total | 1431 | 1 | NR | Diverticulitis: 1
Lindholm, 2008^**^,^129^ | SWE | NR | NR | Not specified | Total | 2108 | 0 | 3 | NR

* The Norwegian Colorectal Cancer Prevention (NORCCAP) study reported no serious complications from flexible sigmoidoscopy in an analysis (n=12960) published in 2003^342^ as well as in a later analysis in participants age 55–64 (n=13653) published in 2009.^343^

† Refers to participants with perforations only

# Hospitalization due to bleeding

‡ Study reports that 478 MIs occurred within one year after FS

§ Unclear if this hospitalization is from the bowel prep for FS or colonoscopy

** FS following an abnormal FOBT/FIT

Abbreviations: AUS = Australia; GBR = Great Britain; ITA = Italy; KOR = Republic of Korea; MI = myocardial infarction; n = number; NOR = Norway; NR = not reported; SAE = serious adverse event; SWE = Sweden; US = United States

##### Bleeding and Perforations

Serious bleeds from FS, from either screening or mixed populations, were rare. Based on 10 studies (n=179,854), the pooled estimate was 0.5 bleeds per 10,000 procedures (95% CI, 0 to 1.3, I^2^=19.4%) (Figure 18).

Figure 18 Key Question 3: Serious Bleeding Events From Flexible Sigmoidoscopy Screening

Abbreviations: CI = confidence interval; ES = effect size; n = number; SCORE = Screening for COlon Rectum; UKFSST = United Kingdom Flexible Sigmoidoscopy Screening Trial

Figure 18 shows a forest plot of serious bleeding events from flexible sigmoidoscopy screening. The pooled effect size is 0.5 per 10,000 procedures with a 95% confidence interval of 0.0 to 1.3.

Perforations following FS were also rare. In 11 studies (n=359,679) of mixed populations, the pooled estimate was 0.2 perforations per 10,000 procedures (95% CI, 0.1 to 0.4; range 0, 1.0 per 10,000; I^2^=0%).

The single study^129^ (n=2,108) reporting perforations associated with FS post gFOBT/FIT reported three perforations.

##### Other Serious Harms

Other commonly reported harms included mortality, MI, GI complications, and hospitalizations. However, no studies of screening FS reported harms in unscreened comparison groups, so it is uncertain if and/or to what degree these events were due to screening.

##### Harms by Age, Sex, Race/Ethnicity, or Family History

No studies reported harms of screening FS by any of these subgroups.

#### Harms of Screening Colonoscopy

We included 67 fair- or good-quality studies that evaluated serious harms from colonoscopy as a primary screening procedure (Table 24, Table 25). The majority of studies were fair quality, primarily due to lack of a comparison group. Thirty-four studies were conducted in the United States. Twenty-nine of 67 studies were conducted exclusively in screening populations or reported harms specific to the screening subgroup; the remaining 38 studies were conducted in mixed populations (including both screening populations and populations receiving colonoscopies due to symptoms or abnormal screening tests). Followup time, when reported, was 1 to 30 days for most studies. Four studies reported harms in addition to bleeds or perforations in unscreened comparison groups.^125,^ ^294,^ ^304,^ ^309^

Table 24 Key Question 3: Harms of Screening Colonoscopy

Author, year | Country | Female, pct | Age, mean | Followup | Group | n | n with serious bleeding events | n with perforation events | n with other SAEs
Penz, 2020^311^; (Newly identified) | AUT | 51 | 65 | Not specified | Total | 218193 | 207^*^ | 29 | Cardiopulmonary complication: 169; Other events (not specified): 59
Grossberg, 2019^310^; (Newly identified) | US | 49 | 60 (median) | 7 days | Total | 30409^†^ | 45^†^ | NR | Hospitalization: 54^†^; ED visit: 188^†^; ED visit – cardiopulmonary 35^†^; ED visit - syncope, loss of consciousness, altered mental status: 5^†^; ED visit - abdominal CT (splenic injury): 2^†^
Kobiela, 2019^309^; (Newly identified) | POL | 54 | 59 | 30 days | Total - intention to screen | 338477 (IG); 338557 (CG) | NR | NR | Hospitalization - directly or potentially related to colonoscopy: 827 (IG); 748 (CG); p=0.046; Mortality: 327 (IG); 312 (CG); p=0.551
Kobiela, 2019^309^; (Newly identified) | POL | 54 | 59 | 30 days | Total - as screened | 54743 (IG); 54743 (CG) | NR | NR | Hospitalization - directly or potentially related to colonoscopy: 172 (IG); 76 (CG); p<0.001; Mortality: 11 (IG); 49 (CG); p<0.001
Basson, 2018^308^; (Newly identified) | US | NR | NR | 7 days | Total | 392485 | NR | NR | Appendicitis: 26; Appendectomy: 19
Wang, 2018^303^; (Newly identified) | US | 57 | NR | 7 days | Total | 462068 | NR | NR | Hospitalizations (all cause): 5366
Wang, 2018^303^; (Newly identified) | US | 57 | NR | 7 days | Total | 462068 | NR | NR | Hospitalization - due to infection: 521
Wang, 2018^303^; (Newly identified) | US | 57 | NR | 7 days | Total | 462068 | NR | NR | GI infections: 74
Wang, 2018^303^; (Newly identified) | US | 57 | NR | 7 days | Total | 462068 | NR | NR | Infection - non-GI: 447
Wang, 2018^303^; (Newly identified) | US | 57 | NR | 7 days | Total | 462068 | NR | NR | Infection - respiratory: 242
Wang, 2018^303^; (Newly identified) | US | 57 | NR | 7 days | Total | 462068 | NR | NR | Infection - genitourinary: 21
Wang, 2018^303^; (Newly identified) | US | 57 | NR | 7 days | Total | 462068 | NR | NR | Septicemia: 88
Wang, 2018^303^; (Newly identified) | US | 57 | NR | 30 days | Total | 462068 | NR | NR | Hospitalization: 14637
Wang, 2018^303^; (Newly identified) | US | 57 | NR | 30 days | Total | 462068 | NR | NR | Hospitalization - due to infection: 1841
Wang, 2018^302^; (Newly identified) | US | 51 | 60 | 30 days | Total | 1580318 | 3745^*^,^†^ | 772^†^ | Upper GI bleeding: 232^†^
Wang, 2018^302^; (Newly identified) | US | 51 | 60 | 30 days | Total | 1580318 | 3745^*^,^†^ | 772^†^ | Diverticulitis - colonic: 3703^†^
Wang, 2018^302^; (Newly identified) | US | 51 | 60 | 30 days | Total | 1580318 | 3745^*^,^†^ | 772^†^ | Diverticulitis - small bowel: 28^†^
Wang, 2018^302^; (Newly identified) | US | 51 | 60 | 30 days | Total | 1580318 | 3745^*^,^†^ | 772^†^ | Cardiac event: 11499^†^
Wang, 2018^302^; (Newly identified) | US | 51 | 60 | 30 days | Total | 1580318 | 3745^*^,^†^ | 772^†^ | Cerebrovascular event: 2696^†^
Wang, 2018^302^; (Newly identified) | US | 51 | 60 | 30 days | Total | 1580318 | 3745^*^,^†^ | 772^†^ | Pulmonary event: 4901^†^
Wang, 2018^302^; (Newly identified) | US | 51 | 60 | 30 days | Total | 1580318 | 3745^*^,^†^ | 772^†^ | Infectious event: 1376^†^
Wang, 2018^302^; (Newly identified) | US | 51 | 60 | 30 days | Total | 1580318 | 3745^*^,^†^ | 772^†^ | Mortality: 512^†^
Zwink, 2017^307^; (Newly identified) | DEU | 52 | 61^‡^ | 4 weeks | Total | 5252 | 5^§^ | 2^§^ | NR
Zwink, 2017^307^; (Newly identified) | DEU | 52 | 61^‡^ | 3 months | Total | 5252 | NR | NR | Mortality - from screening: 0
Bretthauer, 2016^221^; (Newly identified) | NLD, NOR, POL, SWE | 50 | 60^‡^ | 30 days | Total | 12574 | 18 | 1 | Mortality - from screening: 0
Kubisch, 2016^260^; (Newly identified) | DEU | 55 | NR | 0 | Total | 250776 | 430^*^ | 54 | Cardiopulmonary event: 83
Sali, 2016^136^; (Newly identified) | ITA | 54 | 59 | 0 | Total | 153 | 0^*^ | 0 | Post-polypectomy syndrome: 1
Layton, 2014^263^ | US | 55 | 59 | 6 months | Total | 550696 | NR | NR | Acute kidney injury: 1595
Zafar, 2014^306ǁ¶^ | US | 55 | 74 | 30 days | Total | 54039 | 371 | 46 | Ileus: 76
Zafar, 2014^306ǁ¶^ | US | 55 | 74 | 30 days | Total | 54039 | 371 | 46 | Any cardiovascular event: 610
Zafar, 2014^306ǁ¶^ | US | 55 | 74 | 30 days | Total | 54039 | 371 | 46 | MI or angina: 176
Zafar, 2014^306ǁ¶^ | US | 55 | 74 | 30 days | Total | 54039 | 371 | 46 | Arrhythmia: 329
Zafar, 2014^306ǁ¶^ | US | 55 | 74 | 30 days | Total | 54039 | 371 | 46 | Congestive heart failure: 94
Zafar, 2014^306ǁ¶^ | US | 55 | 74 | 30 days | Total | 54039 | 371 | 46 | Cardiac or respiratory arrest: 43
Zafar, 2014^306ǁ¶^ | US | 55 | 74 | 30 days | Total | 54039 | 371 | 46 | Syncope, hypotension/shock: 149
Stock, 2013^294^ | DEU | 55 | 66 | 30 days | Total | 8658 (IG); 8658 (CG) | 4 (IG); 1 (CG) | 7 (IG); 0 (CG) | MI: 2 (IG); 5 (CG)
Stock, 2013^294^ | DEU | 55 | 66 | 30 days | Total | 8658 (IG); 8658 (CG) | 4 (IG); 1 (CG) | 7 (IG); 0 (CG) | Stroke: 3 (IG); 9 (CG)
Stock, 2013^294^ | DEU | 55 | 66 | 30 days | Total | 8658 (IG); 8658 (CG) | 4 (IG); 1 (CG) | 7 (IG); 0 (CG) | Splenic injury: 0 (IG); 0 (CG)
Stock, 2013^294^ | DEU | 55 | 66 | 30 days | Total | 8658 (IG); 8658 (CG) | 4 (IG); 1 (CG) | 7 (IG); 0 (CG) | Other SAE: 5 (IG); 4 (CG)
Stock, 2013^294^ | DEU | 55 | 66 | 30 days | Total | 8658 (IG); 8658 (CG) | 4 (IG); 1 (CG) | 7 (IG); 0 (CG) | Mortality - any: 5 (IG); 21 (CG)
Stock, 2013^294^ | DEU | 55 | 66 | 30 days | Total | 8658 (IG); 8658 (CG) | 4 (IG); 1 (CG) | 7 (IG); 0 (CG) | Mortality - in hospital: 5 (IG); 14 (CG)
Pox, 2012^283^,^#^ | DEU | 56 | 65 | Not specified | Total | 2821392 | 573 | 439 | Cardiopulmonary event: 83
Pox, 2012^283^,^#^ | DEU | 56 | 65 | Not specified | Total | 2821392 | 573 | 439 | Mortality - from screening: 2
Pox, 2012^283^,^#^ | DEU | 56 | 65 | Not specified | Total | 2821392 | 573 | 439 | Other SAE: 45
Quintero, 2012^133^ | ESP | 54 | 59 | 0 | Total | 4953 | 12 | 1 | Hypotension or bradycardia: 10
Rutter, 2012^288^ | US | 52 | NR | 30 days | Total | 38472 | 103^*^,^†^ | 15^†^ | Diverticulitis: 71^†^
Rutter, 2012^288^ | US | 52 | NR | 30 days | Total | 38472 | 103^*^,^†^ | 15^†^ | Hospitalization: 428^†^
Rutter, 2012^288^ | US | 52 | NR | 30 days | Total | 38472 | 103^*^,^†^ | 15^†^ | ED visit: 869^†^
Rutter, 2012^288^ | US | 52 | NR | 30 days | Total | 38472 | 103^*^,^†^ | 15^†^ | Mortality: 12^†^
Suissa, 2012^296^ | ISR | NR | 58 | Not specified | Total | 839 | 0 | 0 | NR
Ferlitsch, 2011^235,**^ | AUT | 51 | 61 | Not specified | Total | 44350 | 54^*^ | 3 | Cardiopulmonary event: 46^††^
Ferlitsch, 2011^235,**^ | AUT | 51 | 61 | Not specified | Total | 44350 | 54^*^ | 3 | Other SAE: 8
Ferlitsch, 2011^235,**^ | AUT | 51 | 61 | Not specified | Total | 44350 | 54^*^ | 3 | Mortality - from screening: 0
Arora, 2009^212^ | US | NR | NR | 7 days | Total | 58457 | NR | 39 | NR
Bair, 2009^214^ | CAN | 52 | 57 | Not specified | Total | 3741 | 2 | 1 | NR
Berhane, 2009^215^ | US | NR | NR | Not specified | Total | 11808 | 5 | 2 | Hemodynamically unstable: 8
Berhane, 2009^215^ | US | NR | NR | Not specified | Total | 11808 | 5 | 2 | MI: 1
Berhane, 2009^215^ | US | NR | NR | Not specified | Total | 11808 | 5 | 2 | Mortality - from screening: 0
Bokemeyer, 2009^220^ | DEU | 56 | NR | Not specified | Total | 269144 | 442 | 55 | Cardiopulmonary event: 222
Bokemeyer, 2009^220^ | DEU | 56 | NR | Not specified | Total | 269144 | 442 | 55 | Surgery - due to bleeding: 19
Crispin, 2009^229^ | DEU | 56 | 64^‡^ | Not specified | Total | 55993 | 10 | 22 | Cardiopulmonary event: 39
Warren, 2009^304^ | US | 62 | NR | 30 days | Total | 5349 (IG); 5349 (CG) | 11 (IG); 7 (CG)^†^ | 3 (IG); 1 (CG)^†^ | Any cardiovascular event: 53 (IG); 80 (CG)^†^
Warren, 2009^304^ | US | 62 | NR | 30 days | Total | 5349 (IG); 5349 (CG) | 11 (IG); 7 (CG)^†^ | 3 (IG); 1 (CG)^†^ | MI or angina: 13 (IG); 18 (CG)^†^
Warren, 2009^304^ | US | 62 | NR | 30 days | Total | 5349 (IG); 5349 (CG) | 11 (IG); 7 (CG)^†^ | 3 (IG); 1 (CG)^†^ | Arrhythmia: 30 (IG); 37 (CG)^†^
Warren, 2009^304^ | US | 62 | NR | 30 days | Total | 5349 (IG); 5349 (CG) | 11 (IG); 7 (CG)^†^ | 3 (IG); 1 (CG)^†^ | Congestive heart failure: 8 (IG); 30 (CG)^†^
Warren, 2009^304^ | US | 62 | NR | 30 days | Total | 5349 (IG); 5349 (CG) | 11 (IG); 7 (CG)^†^ | 3 (IG); 1 (CG)^†^ | Syncope, hypotension/shock: 8 (IG); 14 (CG)^†^
Warren, 2009^304^ | US | 62 | NR | 30 days | Total | 5349 (IG); 5349 (CG) | 11 (IG); 7 (CG)^†^ | 3 (IG); 1 (CG)^†^ | Cardiac or respiratory arrest: 8 (IG); 8 (CG)^†^
Kim, 2007^254^ | US | 56 | 58 | Not specified | Total | 3163 | NR | 7 | NR
MACS Group, 2006^272^ | AUS | 49 | NR | 4 weeks | Total | 63 | 0 | 0 | Other SAE: 0
Strul, 2006^295^ | ISR | 53 | 60 | Not specified | Total | 1177 | 0 | 0 | Severe abdominal pain requiring hospitalization: 1
Strul, 2006^295^ | ISR | 53 | 60 | Not specified | Total | 1177 | 0 | 0 | Mortality - from screening: 0
Cotterill, 2005^228^ | CAN | 44 | NR | Not specified | Total | 324 | 0 | 0 | NR
Nelson, 2002^273^ | US | 3 | 63 | 30 days | Total | 3196 | 7 | 0 | Arrhythmia: 1
Nelson, 2002^273^ | US | 3 | 63 | 30 days | Total | 3196 | 7 | 0 | MI or cerebrovascular accident: 4
Nelson, 2002^273^ | US | 3 | 63 | 30 days | Total | 3196 | 7 | 0 | Mortality: 1
Nelson, 2002^273^ | US | 3 | 63 | 30 days | Total | 3196 | 7 | 0 | Other SAE: 4

* Unspecified bleeding

† Number of procedures or events (rather than number of people)

‡ Median age

§ Physician confirmed hospitalizations due to bleeding and/or perforation

ǁ Increasing risk of bleeding, perforation, and other GI events with older ages (only odds ratios presented; not statistically significant; also includes 1384 people total who received CT colonography)

¶ Increasing risk of cardiovascular events with older ages (only odds ratios presented; statistically significant; also includes 1384 people total who received CT colonography)

# Increasing major and minor complications with increasing age. Statistically significant for both males and females with 55–59 years (by sex) as the reference group

** Bleeding events were unchanged by age (p=0.23)

†† Cardiopulmonary adverse events increased with age, from 0.05% in patients age 50–60 years to 0.25% in patients age 70–80 years (p<0.001)

Abbreviations: AUS = Australia; CAN = Canada; CG = control (no screening) group; DEU = Germany; ESP = Spain; GI = gastrointestinal; IG = intervention (screening) group; ISR = Israel; ITA = Italy; MI = myocardial infarction; NLD = Netherlands; NOR = Norway; NR = not reported; POL = Poland; SAE = serious adverse events; SWE = Sweden; AUT = Austria

Table 25 Key Question 3: Harms of Mixed Colonoscopies

Author, year | Country | Female, pct | Age, mean | Followup | Group | n | n with serious bleeding events | n with perforation events | n with other SAEs
Chukmaitov, 2019^312^; (Newly identified) | US | 54 | NR | 30 days | Total | 1020372 | NR | NR | Hospitalization due to perforations and GI bleeding: 1199
Laanani, 2019^261^; (Newly identified) | FRA | 55 | NR | 5 days | Total | 4088799 | 2655 (minimum); 9459 (maximum)^*^ | 1436 (minimum); 2998 (maximum)^*^ | Splenic injury: 83 (minimum); 139 (maximum)^*^
Laanani, 2019^261^; (Newly identified) | FRA | 55 | NR | 5 days | Total | 4088799 | 2655 (minimum); 9459 (maximum)^*^ | 1436 (minimum); 2998 (maximum)^*^ | Mortality - due to splenic injury: 0 (minimum); 0 (maximum)^*^
Laanani, 2019^261^; (Newly identified) | FRA | 55 | NR | 5 days | Total | 4088799 | 2655 (minimum); 9459 (maximum)^*^ | 1436 (minimum); 2998 (maximum)^*^ | Mortality - due to serious bleed: 1 (minimum); 8 (maximum)^*^
Laanani, 2019^261^; (Newly identified) | FRA | 55 | NR | 5 days | Total | 4088799 | 2655 (minimum); 9459 (maximum)^*^ | 1436 (minimum); 2998 (maximum)^*^ | Mortality - due to perforations: 9 (minimum); 34 (maximum)^*^
Laanani, 2019^261^; (Newly identified) | FRA | 55 | NR | 30 days | Total | 4088799 | NR | NR | Mortality - due to splenic injury: 3 (minimum); 4 (maximum)^*^
Laanani, 2019^261^; (Newly identified) | FRA | 55 | NR | 30 days | Total | 4088799 | NR | NR | Mortality - due to serious bleed: 35 (minimum); 66 (maximum)^*^
Laanani, 2019^261^; (Newly identified) | FRA | 55 | NR | 30 days | Total | 4088799 | NR | NR | Mortality - due to perforations: 42 (minimum); 124 (maximum)^*^
Thulin, 2019^313^; (Newly identified) | SWE | 54 | 63 | 30 days | Total | 593308 | 983^ǁ^ | 667 | NR
Bielawska, 2018^217^; (Newly identified) | CAN | 51 | NR | 7 days | Total | 3059045 | NR | 1396 | Splenic injury: 138
Bielawska, 2018^217^; (Newly identified) | CAN | 51 | NR | 14 days | Total | 3059045 | NR | NR | Aspiration pneumonia: 186
Bielawska, 2018^217^; (Newly identified) | CAN | 51 | NR | 14 days | Anesthesia | 862817 | NR | NR | Aspiration pneumonia: 74
Bielawska, 2018^217^; (Newly identified) | CAN | 51 | NR | 14 days | No anesthesia | 2196228 | NR | NR | Aspiration pneumonia: 112
Grossberg, 2018^240^; (Newly identified) | US | 53 | 59^†^ | 2 days | Total | 50319 | NR | NR | ED visit - related to colonoscopy - cardiopulmonary: 33
Grossberg, 2018^240^; (Newly identified) | US | 53 | 59^†^ | 2 days | Total | 50319 | NR | NR | ED visit - related to colonoscopy - loss of consciousness: 9
Grossberg, 2018^240^; (Newly identified) | US | 53 | 59^†^ | 7 days | Total | 50319 | 77^‡^ | NR | Any ED visit - related to colonoscopy: 260
Grossberg, 2018^240^; (Newly identified) | US | 53 | 59^†^ | 7 days | Total | 50319 | 77^‡^ | NR | ED visit - related to colonoscopy - cerebrovascular: 1
Forsberg, 2017^237^,^¶^; (Newly identified) | SWE | 56 | 63 | 30 days | Total | 593315^§^ | 972^ǁ^ | 661 | Splenic injury: 31
Forsberg, 2017^237^,^¶^; (Newly identified) | SWE | 56 | 63 | 30 days | Total | 593315^§^ | 972^ǁ^ | 661 | Mortality: 80
Garcia-Albeniz, 2017^125^; (Newly identified) | US | 50 | NR | 30 days | Total | 78065 | 34 | 31 | Other GI events: 463
Garcia-Albeniz, 2017^125^; (Newly identified) | US | 50 | NR | 30 days | Total | 78065 | 34 | 31 | Cardiovascular event: 1011^††^
Hoff, 2017^244^; (Newly identified) | NOR | NR | NR | 1 days | Total | 11248 | 2^#^ | 1 | Hospitalization: 18
Hoff, 2017^244^; (Newly identified) | NOR | NR | NR | 1 days | Total | 11248 | 2^#^ | 1 | Syncope: 6
Hoff, 2017^244^; (Newly identified) | NOR | NR | NR | 1 days | Total | 11248 | 2^#^ | 1 | Stroke: 1
Hoff, 2017^244^; (Newly identified) | NOR | NR | NR | 1 days | Total | 11248 | 2^#^ | 1 | Bradycardia: 2
Hoff, 2017^244^; (Newly identified) | NOR | NR | NR | 1 days | Total | 11248 | 2^#^ | 1 | Hypoxia: 1
Hoff, 2017^244^; (Newly identified) | NOR | NR | NR | 1 days | Total | 11248 | 2^#^ | 1 | Technical failure: 1
Johnson, 2017^250^; (Newly identified) | US | 46 | NR | 30 days | Total^**^ | 480688 | NR | NR | Cardiac event: 4053
Johnson, 2017^250^; (Newly identified) | US | 46 | NR | 30 days | Total^**^ | 480688 | NR | NR | Pulmonary event: 710
Johnson, 2017^250^; (Newly identified) | US | 46 | NR | 30 days | Total^**^ | 480688 | NR | NR | Neurovascular: 963
Chukmaitov, 2016^226^; (Newly identified) | US | 54 | NR | 30 days | Total | 4234084 | NR | NR | SAE^‡‡^: 1471
Polter, 2015^281^; (Newly identified) | US | NR | NR | 30 days | Total | 10534 | NR | 5 | NR
Adeyemo, 2014^210^ | US | 54 | 61 | Not specified | Total | 118004 | NR | 48 | NR
Bielawska, 2014^216^ | US | 48 | NR | Not specified | Total | 1144900 | NR | 192 | NR
Blotiere, 2014^219^,^§§^ | FRA | 56 | NR | 3 days | Total | 947061 | 182 | 424 | NR
Castro, 2013^223^ | US | 74 | 56 | 30 days | Total | 3355 | 1^#^ | 3 | Post-polypectomy syndrome: 0
Castro, 2013^223^ | US | 74 | 56 | 30 days | Total | 3355 | 1^#^ | 3 | Excessive abdominal pain: 1
Castro, 2013^223^ | US | 74 | 56 | 30 days | Total | 3355 | 1^#^ | 3 | Cardiopulmonary complication: 3
Castro, 2013^223^ | US | 74 | 56 | 30 days | Total | 3355 | 1^#^ | 3 | Surgery - due to perforations: 3
Castro, 2013^223^ | US | 74 | 56 | 30 days | Total | 3355 | 1^#^ | 3 | Mortality - from screening: 0
Chukmaitov, 2013^225^,^##^ | US | 54 | NR | 30 days | Total | 2315126 | 3822^#ǁǁ^ | 773^¶¶ǁǁ^ | NR
Cooper, 2013^227,***^ | US | 55 | 76 | 30 days | Total | 100359 | NR | 101^ǁǁ^ | Splenic injury: 12^ǁǁ^
Cooper, 2013^227,***^ | US | 55 | 76 | 30 days | Total | 100359 | NR | 101^ǁǁ^ | Aspiration pneumonia: 173^ǁǁ^
Cooper, 2013^227,***^ | US | 55 | 76 | 30 days | Total | 100359 | NR | 101^ǁǁ^ | Mortality: 291
Cooper, 2013^227,***^ | US | 55 | 76 | 30 days | Anesthesia | 35128^ǁǁ^ | NR | NR | Aspiration pneumonia: 48^ǁǁ^
Cooper, 2013^227,***^ | US | 55 | 76 | 30 days | No anesthesia | 130399^ǁǁ^ | NR | NR | Aspiration pneumonia: 125^ǁǁ^
Dominitz, 2013^232^ | US | 58 | NR | 30 days | Total | 328167 | 2299 | 374 | ED visit: 14278
Dominitz, 2013^232^ | US | 58 | NR | 30 days | Total | 328167 | 2299 | 374 | Hospitalization: 10478
Hamdani, 2013^241^ | US | 51 | NR | 7 days | Total | 80118 | NR | 50 | NR
Kim, 2013^255^ | KOR | 63 | 68^†††^ | Not specified | Total | 94632 | NR | 26 | NR
Loffeld, 2013^266^ | NLD | 65^†††^ | 75^†††^ | Not specified | Total | 19135 | NR | 26 | NR
Tam, 2013^297^ | US | 46 | 67 | Not specified | Total | 86101 | NR | 25 | NR
Ho, 2012^243^ | CAN | 52 | 73^†^ | 7 days | Total^‡‡‡^ | 50660 | NR | NR | Hospitalization: 534
Ho, 2012^243^ | CAN | 52 | 73^†^ | 7 days | Total^‡‡‡^ | 50660 | NR | NR | Mortality - from screening: 13
Ho, 2012^243^ | CAN | 52 | 73^†^ | 7 days | Total^‡‡‡^ | 50660 | NR | NR | Other SAEs^§§§^: 1218
Ho, 2012^243^ | CAN | 52 | 73^†^ | 7 days | Total^‡‡‡^ | 50660 | NR | NR | ED visit: 682
Sagawa, 2012^289^ | JPN | 38 | 67 | Not specified | Total | 10826 | NR | 8 | NR
Ko, 2010^257^ | US | 45 | NR | 30 days | Total | 21375 | 34^#^ | 4^¶¶^ | Diverticulitis: 18^ǁǁǁ^
Ko, 2010^257^ | US | 45 | NR | 30 days | Total | 21375 | 34^#^ | 4^¶¶^ | Post-polypectomy syndrome: 2
Ko, 2010^257^ | US | 45 | NR | 30 days | Total | 21375 | 34^#^ | 4^¶¶^ | Hospitalization - due to MI or angina: 12
Ko, 2010^257^ | US | 45 | NR | 30 days | Total | 21375 | 34^#^ | 4^¶¶^ | Hospitalization - due to stroke or TIA: 7
Ko, 2010^257^ | US | 45 | NR | 30 days | Total | 21375 | 34^#^ | 4^¶¶^ | Mortality: 3
Lorenzo-Zuniga, 2010^267^ | ESP | NR | 57 | Not specified | Total | 25214 | 59 | 13 | NR
Xirasagar, 2010^305^ | US | 52 | 58 | Not specified | Total | 10958 | 1 | 2 | Aspiration: 1
Xirasagar, 2010^305^ | US | 52 | 58 | Not specified | Total | 10958 | 1 | 2 | Post-polypectomy syndrome: 1
Xirasagar, 2010^305^ | US | 52 | 58 | Not specified | Total | 10958 | 1 | 2 | Renal failure: 1
Hsieh, 2009^246^ | TWN | 42 | 51 | Not specified | Total | 9501 | NR | 3 | NR
Kamath, 2009^251^ | US | 71^††††^ | 54^††††^ | 22 months^****^ | Total | 296248 | NR | NR | Splenic injury during colonoscopy: 7
Quallick, 2009^284^ | US | 50^†††^ | 65^†††^ | Not specified | Total | 39054 | NR | 4 | NR
Singh, 2009^292^ | CAN | 56 | 59 | 30 days | Total | 24509 | 21^‡‡‡‡^ | 29 | Diverticulitis - acute: 2
Singh, 2009^292^ | CAN | 56 | 59 | 30 days | Total | 24509 | 21^‡‡‡‡^ | 29 | Intestinal obstruction: 3
Singh, 2009^292^ | CAN | 56 | 59 | 30 days | Total | 24509 | 21^‡‡‡‡^ | 29 | MI - acute: 3
Singh, 2009^292^ | CAN | 56 | 59 | 30 days | Total | 24509 | 21^‡‡‡‡^ | 29 | Pneumonia: 1
Singh, 2009^292^ | CAN | 56 | 59 | 30 days | Total | 24509 | 21^‡‡‡‡^ | 29 | Post-polypectomy syndrome: 9
Singh, 2009^292^ | CAN | 56 | 59 | 30 days | Total | 24509 | 21^‡‡‡‡^ | 29 | Acute renal failure: 1
Mansmann, 2008^269^ | DEU | 57 | 59 | Not specified | Total | 236087 | 10 | 69 | Cardiopulmonary event: 152
Mansmann, 2008^269^ | DEU | 57 | 59 | Not specified | Total | 236087 | 10 | 69 | Mortality from cardiopulmonary event: 3
Rabeneck, 2008^285^,^§§§§^ | CAN | 54 | 61 | 30 days | Total | 97091 | 137 | 54 | Mortality: 51
Rabeneck, 2008^285^,^§§§§^ | CAN | 54 | 61 | 30 days | Total | 97091 | 137 | 54 | Mortality - from screening: 3
Ko, 2007^258^ | US | 51 | NR | 30 days | Total | 502 | 3 | 0 | ED visit: 2
Ko, 2007^258^ | US | 51 | NR | 30 days | Total | 502 | 3 | 0 | Hospitalization: 2
Ko, 2007^258^ | US | 51 | NR | 30 days | Total | 502 | 3 | 0 | Unplanned physician visit: 1
Levin, 2006^265ǁǁǁǁ^ | US | 40 | 62 | 30 days | Total | 16318 | 15 | 15 | Post-polypectomy syndrome: 6
Levin, 2006^265ǁǁǁǁ^ | US | 40 | 62 | 30 days | Total | 16318 | 15 | 15 | MI: 9
Levin, 2006^265ǁǁǁǁ^ | US | 40 | 62 | 30 days | Total | 16318 | 15 | 15 | Mortality - from screening: 1
Rathgaber, 2006^286^ | US | 52 | 60 | 30 days | Total | 12407 | 25^¶¶¶¶^ | 2 | Cerebrovascular event: 1
Rathgaber, 2006^286^ | US | 52 | 60 | 30 days | Total | 12407 | 25^¶¶¶¶^ | 2 | Mortality: 0
Korman, 2003^259^ | US | 73 | 69 | Not specified | Total | 116000 | NR | 37 | NR
Sieg, 2001^291^ | DEU | NR | NR | Not specified | Total | 96665 | 17 | 13 | AE - due to medication: 12
Sieg, 2001^291^ | DEU | NR | NR | Not specified | Total | 96665 | 17 | 13 | Cardiopulmonary event: 12
Sieg, 2001^291^ | DEU | NR | NR | Not specified | Total | 96665 | 17 | 13 | Mortality - from screening: 2

* Study estimated a minimum and a maximum rate estimated respectively by stringent and broad definition for each SAE. Stringent definitions included specific ICD-10 codes of colonoscopy SAEs, while broad definitions included less specific ICD-10 codes and procedures that could identify SAEs not captured by stringent definitions.

† Median age

‡ ED visit for GI bleeding

§ N=593315 colonoscopies performed on 426560 individuals

ǁ Unspecified bleeding

¶ Study presents risk ratios for risk of bleeding and perforation by sex. Male sex was associated with a higher risk of bleeding compared with female sex; no significant differences by sex were found for perforations

# Hospitalizations due to bleeding

** Study also reports AEs in subgroups who: are taking antithrombotic medications; have pulmonary risk factors; or have neither of these preconditions

†† Includes cardiac events, pulmonary events, and neurovascular events

‡‡ Hospitalizations due to colonic perforation and GI bleeding

§§ Study reports odds ratios for risk of bleeding and perforation by age subgroups with 0–39 as reference group. Older age groups (e.g., age >=70) were associated with higher risks of bleeding and perforation

ǁǁ Number of events (rather than number of people)

¶¶ Hospitalization due to perforation

## Study reports odds ratios for risk of bleeding and perforation by age, sex, and race/ethnicity subgroups. Older age groups (e.g., age >=65) were associated with higher risks of bleeding and perforation compared with age 19–49, and Hispanic ethnicity and Black or African American race were associated with higher risks of bleeding compared with white race. No significant differences were found for perforation by race/ethnicity, and no significant differences were found for bleeding or perforation by sex

*** Study reports odds ratios for risk of complications (defined as perforation, splenic injury, or aspiration pneumonia) by age subgroups. Older age groups (e.g., age >=70 years) were associated with higher risks of complications compared with age 66–69 years

††† Refers to patients with perforations only

‡‡‡ Study also reports AEs by subgroups receiving either polyethylene glycol or sodium picosulfate bowel preparation

§§§ Includes electrolyte disturbances, congestive heart failure, syncope, dehydration, and falls

ǁǁǁ N=5 required hospitalization

**** Median followup; range 1–164 months

†††† Refers to patients with splenic injury only

‡‡‡‡ N=21 post-polypectomy bleeding; n=1 bleeding after biopsy

§§§§ Study reports odds ratios for risk of bleeding and perforation by age and sex groups. Older age groups (e.g., age 60–75) were associated with higher risk of bleeding and perforation compared with age 50–59 years. Male sex was associated with a higher risk of bleeding compared with female sex; the study found no significant differences in perforations by sex.

ǁǁǁǁ Study reports rate ratios for risk of perforation, bleeding with transfusion, and diverticulitis requiring surgery by age and sex groups. Older age groups (e.g., age >= 60 years) were associated with higher risk of these complications compared with age 40–59 years. No significant differences were found by sex

¶¶¶¶ 23 were postpolypectomy bleedings

Abbreviations: CAN = Canada; CG = control (no screening) group; DEU = Germany; ED = emergency department; ESP = Spain; GI = gastrointestinal; FRA = France; IG = intervention (screening) group; JPN = Japan; KOR = Republic of Korea; MI = myocardial infarction; NLD = Netherland; NOR = Norway; NR = not reported; SAE = serious adverse events; SWE = Sweden; TWN = Taiwan; US = United States

##### Bleeding and Perforations

Rates of serious bleeding were similar across colonoscopy indication. Based on 22 studies (n=5.4 million) reporting serious bleeding complications in people receiving screening colonoscopies, the pooled estimate was 14.6 bleeds per 10,000 procedures (95% CI, 9.4 to 19.9; I^2^=99.5%, range of estimates from individual studies 0 to 68.7 bleeds per 10,000) (Figure 19). In the single study that was an outlier,^306^ the older age of the study population (mean 74.4 years; range 66–104 years) may reflect the increasing risk of colonoscopy bleeds with increasing age. Serious bleeds in populations with both screening and followup or diagnostic colonoscopies (mixed populations) were similar: based on 22 studies with mixed populations (n=10.6 million) the pooled estimate was 16.4 serious bleeds per 10,000 (95% CI, 12.1 to 20.8; I^2^=99.8%) (Figure 20). Study estimates were generally similar to the pooled estimate, with the exception of three studies that had small sample sizes,^258^ much older populations,^304^ or used a broader definition of major bleeding.^232^

Figure 19 Key Question 3: Serious Bleeding Events From Screening Colonoscopy

Abbreviations: CI = confidence interval; ES = effect size; n = number

Figure 19 shows a forest plot of serious bleeding events from screening colonoscopies. The pooled effect size is 14.6 per 10,000 procedures with a 95% confidence interval of 9.4 to 19.9.

Figure 20 Key Question 3: Serious Bleeding Events From Mixed Colonoscopies^*^ * Mixed are screening and symptomatic

Abbreviations: CI = confidence interval; ES = effect size; n = number

Figure 20 shows a forest plot of serious bleeding events from mixed colonoscopies. The pooled effect size is 16.4 per 10,000 procedures with a 95% confidence interval of 12.1 to 20.8.

Based on 23 studies (n=5.4 million) in screening populations, the pooled estimate for perforations was 3.1 per 10,000 (95% CI, 2.3 to 4.0; I^2^=93.6%) (Figure 21). Results were similar across studies (range 0 to 22.1 per 10,000). Based on 33 studies (n=14.4 million) of mixed screening and symptomatic populations, the pooled estimate was similar at 5.0 perforations per 10,000 procedures (95% CI, 4.0 to 6.0; I^2^=98.3%) (Figure 22).

Figure 21 Key Question 3: Perforation Events From Screening Colonoscopies

Abbreviations: CI = confidence interval; ES = effect size; n = number

Figure 21 shows a forest plot of perforation events from screening colonoscopies. The pooled effect size is 3.1 per 10,000 procedures with a 95% confidence interval of 2.3 to 4.0.

Figure 22 Key Question 3: Perforation Events From Mixed Colonoscopies^*^ * Mixed are screening and symptomatic

Abbreviations: CI = confidence interval; ES = effect size; n = number

Figure 22 shows a forest plot of perforation events from mixed colonoscopies. The pooled effect size is 5.0 per 10,000 procedures with a 95% confidence interval of 4.0 to 6.0.

##### Other Serious Harms

Serious harms from screening colonoscopy other than bleeding and perforation were not routinely reported. Other serious harms reported included cardiopulmonary events other gastrointestinal events, infections (including diverticulitis), and unspecified serious complications (Table 24, Table 25). The most commonly reported events were infection and gastrointestinal events (other than bleeding or perforation); events reported more rarely were cardiovascular events. Because these were not commonly reported, we do not provide a summary estimate of their likelihood of occurrence. Six studies^215,^ ^221,^ ^235,^ ^283,^ ^295,^ ^307^ in screening populations (n= 2,896,553) reported frequency of mortality related to colonoscopy screening. Across these studies, two deaths were reported, for a mortality rate of 0.007 per 10,000 people screened. Four studies^223,^ ^243,^ ^285,^ ^291^ in mixed populations (n=166,998) reported a total of 16 screening-related deaths, for a mortality rate of 0.96 per 10,000 people screened.

Since most studies had no comparator arm (unscreened group), it is unclear whether serious harms were related to the receipt of colonoscopy. Only three studies in screening populations (n=705,048)^294,^ ^304,^ ^309^ and one study in mixed populations (n=3,468,901)^125^ compared other serious harms (such as cardiovascular events, stroke, and mortality) in people who had a colonoscopy versus those who did not. These studies found either similar or less frequent serious adverse events in the screened group compared with the control group (Table 24, Table 25). For example, one study in screening populations (n=10,698) found the rate of cardiovascular events was 99 per 10,000 people in the screening group compared with 150 per 10,000 people in the unscreened group.^304^ Another study in screening populations (n=17,316) found the rate of stroke was 3 per 10,000 people in the screened group compared with 10 per 10,000 people in the unscreened group, and the mortality rate was 6 per 10,000 people in the screened group compared with 24 per 10,000 people in the unscreened group.^294^ In an intention-to-treat analysis, a Polish population-based screening study^309^ (n=677,034) reported similar mortality rates in screened and unscreened groups (10 per 10,000 people in the screened group compared with 9 per 10,000 people in the unscreened group, not statistically significant). In the study’s as-screened analysis (n=109,486), mortality rates were lower in the screened group (2.0 per 10,000 people) compared with the unscreened group (9.0 per 10,000 people, p<0.001). The single study in mixed populations with a comparison arm (n=3,468,901) found the rate of cardiovascular events was 130 per 10,000 people in the screened group compared with 93 per 10,000 people in the unscreened group.

##### Harms of Screening Colonoscopy by Age, Sex, Race/Ethnicity, or Family History

Twenty-three studies^125,^ ^212,^ ^216,^ ^219,^ ^225,^ ^227,^ ^229,^ ^235,^ ^237,^ ^241,^ ^250,^ ^257,^ ^261,^ ^265,^ ^283,^ ^285,^ ^288,^ ^303,^ ^304,^ ^306,^ ^310,^ ^312,^ ^313^ provided data by age subgroups (Appendix D, Tables 6 and 7).

Based on 19 studies^125,^ ^212,^ ^216,^ ^219,^ ^225,^ ^227,^ ^235,^ ^237,^ ^241,^ ^257,^ ^261,^ ^283,^ ^288,^ ^303,^ ^304,^ ^306,^ ^310,^ ^312,^ ^313^ reporting harms in people up to age 80, risk for bleeds, perforation, or other harms appeared to increase with age. For example, a study^237^ of colonoscopy in a mixed population conducted in Sweden (n=593,315) found 0.24 percent of people ages 70 to 80 years experienced a serious bleed, higher than the 0.17 and 0.13 percent in age groups 60–70 years and 50–60 years, respectively. Similar patterns were observed for perforation (0.16% vs. 0.12% and 0.07%, respectively).

Six studies^212,^ ^219,^ ^237,^ ^241,^ ^261,^ ^313^ assessed perforations in people under age 50 years who received colonoscopy (all were in mixed populations), and generally found the risk of perforations increased with increasing age. For example, one of these studies^219^ suggested a higher odds of perforations in people age 60 to 69 relative to people under age 40 years (OR 2.89; 95% CI 1.66, 5.05).

Sex differences in serious harms, when reported, suggested little differential risk between males and females. One study^235^ in a screening population provided bleeding and perforation estimates by sex, finding slightly higher rates of serious bleeds for male compared with female participants (0.18% for males, 0.06% for females) and slightly higher rates of perforations (0.009% for males, 0.004% for females); another study in a screening population^229^ reported a similar bleeding risk by sex (OR 1.0001 [95% CI, 1.0001, 1.0002] for female vs. male participants). Two studies^237,^ ^285^ in mixed populations demonstrate that males had a higher risk of bleeding compared with females while another study^313^ in a mixed population found male sex was associated with a lower risk of bleeding compared with female sex; no significant differences by sex were found for perforations. However, in seven studies^210,^ ^216,^ ^219,^ ^225,^ ^241,^ ^265,^ ^286^ of mixed populations, no differences in either bleeds or perforations were observed.

Four studies reported harms stratified by race/ethnicity, with mixed findings.^212,^ ^225,^ ^257,^ ^303^ A study^225^ in a mixed population reported that participants of Hispanic ethnicity (OR: 1.23, 95% CI 1.08, 1.39) and Black race had higher risks of bleeding compared with whites (OR 1.32, 95% CI 1.13, 1.53), while two studies in mixed populations found similar frequencies of perforations (<1%)^212^ and similar rates of colonoscopy-related hospitalizations (<0.5%)^257^among white, Black, Hispanic, and other groups. One study ^303^ in a screening population reported a higher risk of risk of infection-related hospitalization among Black [OR: 1.57 (1.22, 2.01)] compared with white people.

No studies reported serious harms stratified by family history.

#### Harms of Followup Colonoscopy

We included 14 fair- or good-quality studies that evaluated serious harms from colonoscopy following an abnormal stool test result, six studies that evaluated harms from colonoscopy following an abnormal flexible sigmoidoscopy result, and one study that evaluated harms from colonoscopy following an abnormal CTC result (Table 26). Eighteen of these studies (n=131,455) were part of included screening programs for KQ1.^119,^ ^121,^ ^124,^ ^125,^ ^127,^ ^129,^ ^130,^ ^133–136,^ ^138,^ ^140–144,^ ^147^ Three studies reported harms from a gFOBT/FIT screening program but did not report the number of participants receiving a followup colonoscopy. Followup time, when reported, was 30 days for most studies.

Table 26 Key Question 3: Harms From Other Screening Procedures

| Author, year | Country | Female pct | Age mean | Followup | Group | n | n with serious bleeding events | n with perforation events | n with other SAEs
Colonoscopy, post CTC | Sali, 2016^136^; (Newly identified) | ITA | 54^*^ | 59 | Time of procedure | Total | 126 | 0^†^ | 0 | NR
Colonoscopy, post FOBT/FIT | Derbyshire, 2018^231^; (Newly identified) | GBR | 39 | 66 | 30 days | Total | 263129 | NR | 147 | Mortality - due to perforation: 1
Colonoscopy, post FOBT/FIT | Derbyshire, 2018^231^; (Newly identified) | GBR | 39 | 66 | 30 days | Female | 103934 | NR | 53 | NR
Colonoscopy, post FOBT/FIT | Derbyshire, 2018^231^; (Newly identified) | GBR | 39 | 66 | 30 days | Male | 159193 | NR | 92 | NR
Colonoscopy, post FOBT/FIT | Derbyshire, 2018^231^; (Newly identified) | GBR | 39 | 66 | 30 days | North East region | 11564 | NR | NR | Mortality - due to post-polypectomy bleeding: 0
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | Total | 8831 | 10 | 13 | Hospitalization: 142
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | Total | 8831 | 10 | 13 | Mortality: 0
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | Total | 8831 | 10 | 13 | Peritonitis: 0
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | Male | 5126 | NR | NR | Any SAE: 15
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | Male | 5126 | NR | NR | SAE - immediate: 8
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | Male | 5126 | NR | NR | SAE - late: 7
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | Female | 3705 | NR | NR | Any SAE: 8
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | Female | 3705 | NR | NR | SAE - immediate: 6
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | Female | 3705 | NR | NR | SAE - late: 2
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | ≤59 years | 3541 | NR | NR | Any SAE: 7
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | ≤59 years | 3541 | NR | NR | SAE - immediate: 6
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | ≤59 years | 3541 | NR | NR | SAE - late: 1
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | ≥60 years | 5290 | NR | NR | Any SAE: 16
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | ≥60 years | 5290 | NR | NR | SAE - immediate: 8
Colonoscopy, post FOBT/FIT | Ibanez, 2018^248^; (Newly identified) | ESP | 42 | NR | 30 days | ≥60 years | 5290 | NR | NR | SAE - late: 8
Colonoscopy, post FOBT/FIT | Mikkelsen, 2018^270^; (Newly identified) | DNK | 44 | 64 | 30 days | Total | 14671 | 28 | 15^‡^ | Post-polypectomy syndrome: 24
Colonoscopy, post FOBT/FIT | Mikkelsen, 2018^270^; (Newly identified) | DNK | 44 | 64 | 30 days | Total | 14671 | 28 | 15^‡^ | Mortality: 11
Colonoscopy, post FOBT/FIT | Mikkelsen, 2018^270^; (Newly identified) | DNK | 44 | 64 | 30 days | Total | 14671 | 28 | 15^‡^ | Mortality, screening-related: 0
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Total | 473960 | 393^†^ | 294 | Infectious event: 76
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Total | 473960 | 393^†^ | 294 | Other SAE: 22
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Female | NR | 122^†^ | 81 | Infectious event: 25
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Female | NR | 122^†^ | 81 | Other SAE: 7
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Male | NR | 271^†^ | 213 | Infectious event: 51
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Male | NR | 271^†^ | 213 | Other SAE: 15
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Female 50–59 years | NR | 47^†^ | 30 | Infectious event: 13
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Female 50–59 years | NR | 47^†^ | 30 | Other SAE: 4
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Female 60–69 years | NR | 54^†^ | 32 | Infectious event: 8
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Female 60–69 years | NR | 54^†^ | 32 | Other SAE: 2
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Female ≥70 years | NR | 21^†^ | 19 | Infectious event: 4
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Female ≥70 years | NR | 21^†^ | 19 | Other SAE: 1
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Male 50–59 years | NR | 107^†^ | 68 | Infectious event: 27
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Male 50–59 years | NR | 107^†^ | 68 | Other SAE: 5
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Male 60–69 years | NR | 97^†^ | 86 | Infectious event: 13
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Male 60–69 years | NR | 97^†^ | 86 | Other SAE: 7
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Male ≥70 years | NR | 67^†^ | 59 | Infectious event: 11
Colonoscopy, post FOBT/FIT | Rim, 2017^287^; (Newly identified) | KOR | NR | NR | 3 months | Male ≥70 years | NR | 67^†^ | 59 | Other SAE: 3
Colonoscopy, post FOBT/FIT | Kubisch, 2016^260^; (Newly identified) | DEU | 55 | NR | Not specified | Total | 30907 | 128^†^ | 10 | Cardiopulmonary complication: 23
Colonoscopy, post FOBT/FIT | Sali, 2016^136^; (Newly identified) | ITA | 54^*^ | 59 | Time of procedure | Total | 217 | 2^§^ | 0 | NR
Colonoscopy, post FOBT/FIT | Saraste, 2016^290^; (Newly identified) | SWE | NR | NR | 30 days | Total | 2984 | 18^§^ | 3 | Infectious event: 3
Colonoscopy, post FOBT/FIT | Saraste, 2016^290^; (Newly identified) | SWE | NR | NR | 30 days | Total | 2984 | 18^§^ | 3 | Thromboembolic event: 6
Colonoscopy, post FOBT/FIT | Saraste, 2016^290^; (Newly identified) | SWE | NR | NR | 30 days | Total | 2984 | 18^§^ | 3 | Re-operations post-colonoscopy: 6
Colonoscopy, post FOBT/FIT | Saraste, 2016^290^; (Newly identified) | SWE | NR | NR | 30 days | Total | 2984 | 18^§^ | 3 | Re-admissions, miscellaneous: 11
Colonoscopy, post FOBT/FIT | Saraste, 2016^290^; (Newly identified) | SWE | NR | NR | 30 days | Total | 2984 | 18^§^ | 3 | Mortality: 1
Colonoscopy, post FOBT/FIT | Binefa, 2015^218^; (Newly identified) | ESP | NR | NR | 30 days | 1st round^ǁ^ | 63880 | NR | NR | SAE^¶^: 3
Colonoscopy, post FOBT/FIT | Binefa, 2015^218^; (Newly identified) | ESP | NR | NR | 30 days | 2nd round^ǁ^ | 66534 | NR | NR | SAE^¶^: 0
Colonoscopy, post FOBT/FIT | Binefa, 2015^218^; (Newly identified) | ESP | NR | NR | 30 days | 3rd round^ǁ^ | 65142 | NR | NR | SAE^¶^: 2
Colonoscopy, post FOBT/FIT | Binefa, 2015^218^; (Newly identified) | ESP | NR | NR | 30 days | 4th round^ǁ^ | 62934 | NR | NR | SAE^¶^: 4
Colonoscopy, post FOBT/FIT | Binefa, 2015^218^; (Newly identified) | ESP | NR | NR | 30 days | 5th round^ǁ^ | 64117 | NR | NR | SAE^¶^: 10
Colonoscopy, post FOBT/FIT | Parente, 2013^275^ | ITA | NR | NR | Not specified | Total | 4373 | 5 | 2 | Other SAEs: 0
Colonoscopy, post FOBT/FIT | Shaukat, 2013^143^ | US | 52 | 62^*^ | Not specified | Total | 12246 | 11 | 4 | NR
Colonoscopy, post FOBT/FIT | Quintero, 2012^133^ | ESP | 54 | 59 | Not specified | Total | 587 | 8 | 0 | Hypotension or bradycardia: 2
Colonoscopy, post FOBT/FIT | Scholefield, 2012^138^ | GBR | NR | NR | Not specified | Total | 1474 | 1 | 5 | NR
Colonoscopy, post FOBT/FIT | Dancourt, 2008^230^ | FRA | 54 | NR | Not specified | Total | 1205 | 0 | 0 | NR
Colonoscopy, post FOBT/FIT | Faivre, 2004^124^ | FRA | 53 | NR | Not specified | Total | 1298 | 0 | 0 | NR
Colonoscopy, post FS | Miller, 2019^130^ | US | 51 | NR | Not specified | Total | 17672 | NR | 19 | NR
Colonoscopy, post FS | Steele, 2020^150^ | GBR | 50 | NR | Not specified | Total | 440 | 1 | NR | NR
Colonoscopy, post FS | Holme, 2018^127^ | NOR | 50 | 56 | Not specified | Total | 2524 | 4^#^ | 6 | Post-polypectomy syndrome: 24
Colonoscopy, post FS | Atkin, 2017^119^ | GBR | 51 | 60 | 30 days | Total | 2051 | 9^#^ | 4 | Mortality - possibly from screening: 1
Colonoscopy, post FS | Segnan, 2011^140^ | ITA | 50 | 60 | 30 days | Total | 775 | 1 | 1 | NR
Colonoscopy, post FS | Lindholm, 2008^129^ | SWE | NR | NR | Not specified | Total | 190 | 1 | 2 | NR
Colonoscopy, post FS or FOBT | Segnan, 2005^141^ | ITA | 53 | NR | Not specified | Total | 332 | 1^#^ | NR | NR
Colonoscopy or FS, screening or mixed | Kang, 2008^252^ | KOR | 36 | 60 | Not specified | Total | 44534 | NR | 53 | NR
Colonoscopy or FS, screening or mixed | Kang, 2008^252^ | KOR | 36 | 60 | Not specified | Followup colonoscopy | 37762 | NR | 26 | NR
Colonoscopy or FS, screening or mixed | Kang, 2008^252^ | KOR | 36 | 60 | Not specified | Therapeutic colonoscopy | 6772 | NR | 27 | NR
CTC, screening or mixed | Sali, 2016^136^; (Newly identified) | ITA | 54^*^ | 59 | Time of procedure | Total | 1286 | 0^†^ | 0 | NR
CTC, screening or mixed | Zafar, 2014^306^ | US | 64 | 77 | 30 days | Total | 1384 | 4 | 1 | Ileus: 0
CTC, screening or mixed | Zafar, 2014^306^ | US | 64 | 77 | 30 days | Total | 1384 | 4 | 1 | Any cardiovascular event: 26
CTC, screening or mixed | Zafar, 2014^306^ | US | 64 | 77 | 30 days | Total | 1384 | 4 | 1 | MI or angina: 4
CTC, screening or mixed | Zafar, 2014^306^ | US | 64 | 77 | 30 days | Total | 1384 | 4 | 1 | Arrhythmia: 14
CTC, screening or mixed | Zafar, 2014^306^ | US | 64 | 77 | 30 days | Total | 1384 | 4 | 1 | Cardiac or respiratory arrest: 1
CTC, screening or mixed | Zafar, 2014^306^ | US | 64 | 77 | 30 days | Total | 1384 | 4 | 1 | Congestive heart failure: 5
CTC, screening or mixed | Zafar, 2014^306^ | US | 64 | 77 | 30 days | Total | 1384 | 4 | 1 | Syncope, hypotension/shock: 9
CTC, screening or mixed | Iafrate, 2013^247^ | ITA | NR | NR | Not specified | Total | 40121 | NR | 7 | Mortality - screening-related: 0
CTC, screening or mixed | Cash, 2012^222^ | US | 42 | 75 | Not specified | Total | 1410 | NR | NR | CTC-related complications: 0
CTC, screening or mixed | Zalis, 2012^205^ | US | 47 | 60 | Not specified | Total | 605 | NR | NR | Events that required treatment: 0
CTC, screening or mixed | Kim, 2010^253^ | US | 48 | 69 | Not specified | Total | 577 | 0 | 0 | NR
CTC, screening or mixed | Pickhardt, 2010^279^ | US | 48 | 60 | Not specified | Total | 10286 | NR | NR | Mortality: 3
CTC, screening or mixed | Graser, 2009^172^ | DEU | 45 | 61 | Not specified | Total | 309 | NR | NR | SAE: 0
CTC, screening or mixed | An, 2008^211^ | KOR | 40 | 51 | Not specified | Total | 1015 | NR | NR | SAE: 0
CTC, screening or mixed | Johnson, 2008^177^ | US | 52 | 58 | Not specified | Total | 2534 | NR | NR | Hospitalization due to e. coli bacteremia: 1
CTC, screening or mixed | Kim, 2008^256^ | KOR | 40 | 58 | Not specified | Total | 2230 | NR | NR | Severe reaction to contrast media: 0
CTC, screening or mixed | Kim, 2008^181^ | KOR | 49 | 58 | Not specified | Total | 241 | NR | NR | Urticaria (contrast medium induced): 2
CTC, screening or mixed | Kim, 2008^181^ | KOR | 49 | 58 | Not specified | Total | 241 | NR | NR | Clinically important complication: 0
CTC, screening or mixed | Kim, 2007^254^ | US | 56 | 57 | Not specified | Total | 3120 | NR | 0 | NR
CTC, screening or mixed | MACS Group, 2006^272^ | AUS | 49 | NR | 4 weeks | Total | 38 | 0 | 0 | SAE: 0
CTC, screening or mixed | Pickhardt, 2006^276^ | US, BEL, IRL, ITA, NLD | NR | NR | Not specified | Total | 11707 | NR | 0 | NR
CTC, screening or mixed | Sosna, 2006^293^ | ISR | 42 | 60 | Not specified | Total | 11870 | NR | 7 | Mortality - screening-related: 0
CTC, screening or mixed | Edwards, 2004^234^ | AUS | 46 | NR | Not specified | Total | 340 | NR | NR | SAE: 0
FOBT/FIT, screening | Segnan, 2007^142^ | ITA | 51 | NR | 30 days | Total | 1363 | NR | NR | Hospitalization: 12
FOBT/FIT, screening | Segnan, 2007^142^ | ITA | 51 | NR | 30 days | Total | 1363 | NR | NR | Hospitalization - due to rectal prolapse: 0
FOBT/FIT, screening | Segnan, 2007^142^ | ITA | 51 | NR | 30 days | Total | 1363 | NR | NR | Hospitalization - due to cardiovascular event: 1
FOBT/FIT, screening | Segnan, 2007^142^ | ITA | 51 | NR | 30 days | Total | 1363 | NR | NR | Hospitalization - due to other GI event: 0
FOBT/FIT, screening | MACS Group, 2006^272^ | AUS | 49 | NR | 4 weeks | Total | 125 | 0 | 0 | SAE: 0
FOBT/FIT, screening | Rasmussen, 1999^134^ | DNK | NR | NR | 0 | Total | 2235 | 0 | 0 | Mortality - from screening: 0
Capsule endoscopy | Rex, 2015^198^; (Newly identified) | US, ISR | 56 | 57 | Not specified | Total | 689 | NR | NR | SAE: 0
Capsule endoscopy | Rex, 2015^198^; (Newly identified) | US, ISR | 56 | 57 | Not specified | Total | 689 | NR | NR | Non-serious AE related to the capsule procedure: 3

* Refers to participants at randomization

† Unspecified bleeding

‡ Perforation or lesion

§ Post-polypectomy bleeding

ǁ The screening program included 5 rounds of screening with an approximately 2-year interval between screening rounds

¶ Defined as severe complications requiring hospitalization, including serious bleeding, perforation, vagal syndrome, peritonitis-like syndrome

# Hospitalization due to bleeding

Abbreviations: AUS = Australia; AE = adverse event; BEL = Belgium; CTC = Computed tomographic colonography; DEU = Denmark; DNK = Denmark; ESP = Spain; FRA = France; GI = gastrointestinal; IRL = Ireland; ISR = Israel; ITA = Italy; IV = intravenous; KOR = Republic of Korea; MI = myocardial infarction; NLD = Netherlands; NOR = Norway; NR = not reported; SAE = serious adverse event; SWE = Sweden; US = United States

##### Bleeding and Perforations

Following abnormal stool testing. Based on 11 studies of colonoscopy conducted after abnormal gFOBT/FIT result (n=78,793), the pooled estimate was 17.5 serious bleeds per 10,000 (95% CI, 7.6 to 27.5, I^2^=89.3%) (Figure 23). Serious bleeding was slightly higher in two studies^136,^ ^290^ that were conducted postpolypectomy, but the confidence intervals were wide, likely due to smaller sample size. Based 12 studies (n=341,922), the pooled estimate of perforations following abnormal gFOBT/FIT was 5.4 per 10,000 procedures (95% CI, 3.4 to 7.4; I^2^=47.8%).

Figure 23 Key Question 3: Serious Bleeding Events From Colonoscopy Following an Abnormal FOBT/FIT*

Abbreviations: CI = confidence interval; ES = effect size; n = number

Figure 23 shows a forest plot of serious bleeding events from colonoscopy following an abnormal guaiac fecal occult blood test/fecal immunochemical test. The pooled effect size is 17.5 per 10,000 followup colonoscopy procedures with a 95% confidence interval of 7.6 to 27.5.

Following abnormal flexible sigmoidoscopy. Six studies reported serious bleeds or perforations in populations receiving colonoscopy following an abnormal FS result. Based on four of these where data could be pooled (n=23,022), the pooled estimate was 12.0 perforations (95% CI, 7.5 to 16.5, I^2^=0%) (Figure 24). Based on four studies (n=5,790), the pooled estimate is 20.7 major bleeds (95% CI, 8.2 to 33.2, I^2^=8.2%) (Figure 25) per 10,000 followup colonoscopy procedures after abnormal screening FS.

Figure 24 Key Question 3: Perforations From Colonoscopy After an Abnormal FS

Abbreviations: CI = confidence interval; ES = effect size; n = number; NORCCAP = Norwegian Colorectal Cancer Prevention; PLCO = Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial; SCORE = Screening for COlon Rectum; UKFSST = United Kingdom Flexible Sigmoidoscopy Screening Trial

Figure 24 shows a forest plot of perforations from colonoscopy following an abnormal flexible sigmoidoscopy. The pooled effect size is 12.0 per 10,000 followup colonoscopy procedures with a 95% confidence interval of 7.5 to 16.5.

Figure 25 Key Question 3: Serious Bleeding Events From Colonoscopy Following an Abnormal FS

Abbreviations: CI = confidence interval; ES = effect size; n = number; NORCCAP = Norwegian Colorectal Cancer Prevention; SCORE = Screening for COlon Rectum; UKFSST = United Kingdom Flexible Sigmoidoscopy Screening Trial

Figure 25 shows a forest plot of serious bleeding events from colonoscopy following an abnormal flexible sigmoidoscopy. The pooled effect size is 20.7 per 10,000 followup colonoscopy procedures with a 95% confidence interval of 8.2 to 33.2.

Following abnormal CTC. One study^136^ (n=126) conducted in Italy reported no cases of serious bleeds, perforation, or other serious adverse events.

##### Other Serious Harms

Following abnormal stool testing. There were limited data on other serious harms related to colonoscopy following an abnormal gFOBT/FIT result—and no studies with a comparator group. Based on three studies^133,^ ^260,^ ^290^ in screening populations (n=34,478), cardiopulmonary events were rare. In two of these studies^287,^ ^290^ (n=2984), infectious events were also rare (<0.5% of procedures). Two^248,^ ^270^ of four studies reporting mortality found zero screening-related deaths; one death due to perforation was reported in one study^231^ (n=263,129); and one death was reported in another study^290^ (n=2,984), but it was not clear whether it was screening-related.

In three studies^134,^ ^142,^ ^272^ of stool-based testing used as a primary screening test, either hospitalizations, screening-related mortality, or other unspecified serious adverse events were reported. No mortality, serious bleeds, perforations, or other serious adverse events were reported, and no comparison hospitalization rates for unscreened individuals were provided that would allow attribution of hospitalization to screening.

Following abnormal flexible sigmoidoscopy. In six studies, a single mortality event was reported in one study (n=2,051) that the authors judged was possibly related to screening.^119^ One other study^127^ (n=2,524) reported 24 cases of post-polypectomy syndrome (defined as abdominal pain, fever, leukocytosis, and peritoneal inflammation after polypectomy with electrocoagulation, in the absence of bowel perforation^354^).

Following abnormal CTC. One study^136^ (n=126) conducted in Italy reported no cases of serious bleeds, perforation, or other serious adverse events.

##### Harms by Age, Sex, Race/Ethnicity, or Family History

Two studies^231,^ ^287^ reported perforation of bleeding harms stratified by age or sex, finding no difference between subgroups. One study^248^ reported similar rates of severe complications (not specified) between age and sex subgroups.

No studies reported serious harms stratified by race/ethnicity or family history.

#### Harms of CTC

We identified 17 studies (n=89,073) assessing harms related to CTC (i.e., perforations, serious bleeds, and other serious events) and seven studies that reported radiation exposure from the CTC. Twenty-seven studies reported the prevalence of extracolonic findings on CTC, which may be either a benefit or a harm.

##### Serious Bleeds, Perforations, or Other Serious Adverse Events

In the 17 studies assessing harms related to CTC (Table 26), eight ^177,^ ^205,^ ^222,^ ^253,^ ^254,^ ^276,^ ^279,^ ^306^ were U.S.-based. The mean age ranged from 51 to 77 years. No studies included unscreened comparison groups. The most commonly reported serious adverse event was perforation, which can happen due to insufflation of the colon. The pooled estimated risk of perforations based on seven studies was 1.3 per 10,000 procedures (95% CI, 0 to 2.9; I^2^=38.9%) (Figure 26).

Figure 26 Key Question 3: Perforations From Screening or Mixed CTC

Abbreviations: CI = confidence interval; ES = effect size; n = number

Figure 26 shows a forest plot of perforations from screening or mixed CTC. The pooled effect size is 1.3 per 10,000 procedures with a 95% confidence interval of 0.0 to 2.9.

In four studies reporting serious bleeds (n=3,285), four such bleeds were reported, all in a single U.S.-based study.^306^

Of the 14 studies reporting other harms, 10 found no serious harms or mortality associated with CTC screening. Other harms (e.g., cardiopulmonary events, other GI events) were uncommonly reported and no comparisons were provided for unscreened controls. One study reported two cases of contrast-induced urticaria.^181^

##### Radiation Exposure

Seven included studies^169,^ ^172,^ ^184,^ ^205,^ ^211,^ ^234,^ ^272^ reported radiation exposure associated with one CTC examination (Table 27).

Table 27 Key Question 3: CTC Radiation Exposure

Author, year | Radiation exposure (Effective Dose)
Fletcher, 2013^169^ | 6–7 mGy^*^
Lefere, 2013^184^ | 10.56 mGy^*^
Zalis, 2012^205^ | 5.3 mSv
Graser, 2009^172^ | 4.5 mSv
An, 2008^211^ | 0.8–1.0 mSv
MACS Group, 2006^272^ | <5 mSv
Edwards, 2004^234^ | 5 mSv

* Radiation output from the CT scanner (volume CT dose index)

Relevant definitions^472^:

Volume CT dose index (CTDI_vol_) = A measure of radiation output from the CT scanner (units mGy). Linear relationship with radiation exposure, but independent of patient size and size of scanned body region. Useful for comparing different CT scanners, but not a measure of patient dose.

Absorbed dose = Amount of ionizing radiation deposited in tissues; energy absorbed per unit mass (unit mGy). Dependendent on CTDI_vol_, length of body region scanned, and patient size.

Effective dose = Uniform whole-body dose (units mSv). Useful to compare different radiologic exposures (from other medical procedures or other forms of radiation). Applicable to a population, not an individual.

Abbreviations: mSv = millisievert; mGy = milligrays

Based on two included test accuracy studies of CTC, the estimated radiation dose for one full-screening CTC examination (dual positioning supine and prone) ranged from 4.5 to 5.3 mSv. Three additional CTC screening studies reported estimated radiation dose ranging from 0.8 to 5 mSv.^211,^ ^234,^ ^272^ Two test accuracy studies reported the radiation output from the CT scanner, ranging from 6 to 10.56 mGy.

We did not identify any study that directly measured the risk for stochastic effects (e.g., cancer) caused by radiation exposure from CTC. For context, we briefly consider the indirect evidence for the potential adverse effects of low-dose ionizing radiation in the Discussion section.

##### Harms by Age, Sex, Race/Ethnicity, or Family History

We found no studies that reported on differential risk for serious harms or radiation exposure of CTC by age, sex, race/ethnicity, or family history.

##### Extracolonic Findings

We found 27 fair- to good-quality studies that addressed extracolonic findings (ECFs) associated with screening CTC (Table 28). Twenty-three studies (n=59,044) were conducted in screening populations, while three^239,^ ^268,^ ^280^ (n=3149) were in mixed populations and one^238^ (n=75) was conducted in a screen-positive population. The number of examinations ranged from 264 to 10,286. The largest study (n=10,286) represented people included in other studies but focused on different extracolonic malignancies only.^279^ Followup time was not frequently reported, but when it was ranged from 6 months to 6 years, most typically 1 to 3 years. Most studies reported ECFs using the CT Colonography Reporting and Data System (C-RADS) classification system, a well-recognized standard for reporting CTC findings. There are five categories of C-RADS findings: E0=limited examination, E1=normal examination or normal variant, E2=clinically unimportant finding for which no workup is required, E3=likely unimportant or incompletely characterized finding for which workup may be required, and E4=potentially important finding requiring followup.^355^ Alternatively, some studies instead describe extracolonic findings in terms of “high,” “moderate,” or “low” clinical significance. “High” generally includes findings that require surgical treatment, medical intervention, or further investigation (e.g., indeterminate solid organ masses or chest nodules, abdominal aortic aneurysms ≥3 cm). Findings of “moderate” clinical significance do not require immediate medical attention but likely require recognition, investigation, or treatment sometime in the future (e.g., calculi, small adrenal masses). Findings of “low” clinical significance do not require further investigation or treatment.

Table 28 Key Question 3: Extracolonic Findings

Author, year; Quality | Population | Followup | Category of ECF findings | Group | N | Prevalence of extracolonic findings | Further evaluation or medical / surgical treatment | Findings of diagnostic evaluation | Longer-term clinical followup
Taya, 2019^298^; Fair | Screening only | 2.8 yrs (mean) | C-RADS | Total | 262 | E3: 9 persons (9 findings); E3 - indeterminate renal lesion: 3 findings; E3 - lung opacity: 2 findings; E3 - lymphadenopathy: 2 findings; E3 - liver mass: 1 event; E3 - pericardial effusion: 1 event | Follow-up imaging of E3 findings: 6 persons | Benign disease: 6 (none required an invasive procedure for diagnosis of a benign condition) | NR
Taya, 2019^298^; Fair | Screening only | 2.8 yrs (mean) | C-RADS | Total | 262 | E4: 20 persons (24 findings); E4 - lung nodule: 7 findings; E4 - abdominal aortic aneurysm: 2 findings; E4 - common iliac aneurysm: 3 findings; E4 - other vascular aneurysm: 3 findings; E4 - renal mass: 3 findings; E4 - urolithiasis or hydronephrosis: 2 findings; E4 - liver mass: 1 event; E4 - mediastinal mass:1 event; E4 - lung opacity: 1 finding; E4 - avascular necrosis of hip: 1 event | Follow-up imaging of E4 findings: 18 persons | Clinically significant pathology on followup: 12 persons | NR
Taya, 2019^298^; Fair | Screening only | 2.8 yrs (mean) | C-RADS | Total | 262 | | Follow-up imaging of E4 findings: 18 persons | Benign disease: 6 persons (All 6 had imaging; none required an invasive procedure for diagnosis of a benign condition) | NR
Taya, 2019^298^; Fair | Screening only | 2.8 yrs (mean) | C-RADS | Total | 262 | | Follow-up imaging of E4 findings: 18 persons | Malignant tumor: 2 persons (1 non-small cell lung cancer, 1 renal cell carcinoma) | NR
Larson, 2018^262^; Fair | Screening only | NR | C-RADS | Cancer hx | 349 | E3: 50 persons; E4: 9 persons | NR | NR | NR
Larson, 2018^262^; Fair | Screening only | NR | C-RADS | Cancer hx, female | 234 | E3: 33 persons; E4: 8 persons | NR | NR | NR
Larson, 2018^262^; Fair | Screening only | NR | C-RADS | Cancer hx, male | 115 | E3: 17 persons; E4: 1 person | NR | NR | NR
Larson, 2018^262^; Fair | Screening only | NR | C-RADS | No cancer hx | 8859 | E3: 965 persons; E4: 166 persons | NR | NR | NR
Larson, 2018^262^; Fair | Screening only | NR | C-RADS | No cancer hx, female | 4725 | E3: 560 persons; E4: 89 persons | NR | NR | NR
Larson, 2018^262^; Fair | Screening only | NR | C-RADS | No cancer hx, male | 4134 | E3: 405 persons; E4: 77 persons | NR | NR | NR
Larson, 2018^262^; Fair | Screening only | NR | C-RADS | Non-melanoma skin cancer hx | 271 | E3: 39 persons; E5: 9 persons | NR | NR | NR
Moreno, 2018^271^; Fair | Screening only | NR | C-RADS | 45–49 yrs | 249 | E3: 8 persons; E4: 4 persons | NR | NR | NR
Moreno, 2018^271^; Fair | Screening only | NR | C-RADS | 50–75 yrs | 2404 | E3: 151 persons; E4: 94 persons | NR | NR | NR
Moreno, 2018^271^; Fair | Screening only | NR | C-RADS | 50–80 yrs | 2490 | E3: 163 persons; E4: 100 persons; E4 - Lung nodule: 5 persons; E4 - lytic or sclerotic bone lesions: 4 persons; E4 - renal mass: 4 persons; E4 - liver mass: 2 persons; E4 - adrenal mass: 2 persons | NR | NR | NR
Moreno, 2018^271^; Fair | Screening only | NR | C-RADS | 65–80 yrs | 606 | E3: 50 persons; E4: 37 persons | NR | NR | NR
Regge, 2017^135^; Fair | Screening only | 0 | C-RADS | Total | 2595 | E4 and aortic aneurysms; ≥4cm: 35 persons^*^ | NR | NR | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | E3: 725 persons | Evaluation with imaging: 608 persons | Clinically significant pathology on followup: 55 persons | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | E3: 725 persons | Evaluation with imaging: 608 persons | Malignancy: 8 persons (3 renal cell carcinoma, 3 lymphoma,1 ovarian adenocarcinoma, 1 metastatic breast cancer) | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | E3: 725 persons | Evaluation with imaging: 608 persons | Benign/borderline neoplasms: 17 persons (7 ovarian dermoid, 3 ovarian mucinous cystadenoma, 1 pancreatic mucinous cystadenoma, 1 benign gastrointestinal stromal tumor, ovarian borderline serous tumor, 1 renal oncocytoma, 1 ovarian Brenner tumor, peripheral) | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | E3: 725 persons | Evaluation with imaging: 608 persons | Benign disease: 605 persons | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | E3: 725 persons | Evaluation with imaging: 608 persons | Other significant pathology: 30 persons (9 endometriosis, 4 complicated urolithiasis, 3 porcelain gallbladder, 2 inflammatory bowel disease, 2 asbestos-related pleural plaques, 2 pneumonia, and 2 obstructing ureterocele | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | E4: 202 persons; E4 - abdominal aortic aneurysm: 35 persons; E4 - liver mass: 26 persons; E4 - renal mass: 20 persons; E4 - lung nodule: 19 persons; E4 - visceral abdominal/other aneurysm: 18 persons; E4 - adnexal mass: 14 persons; E4 - other gastrointestinal: 12 persons; E4 - gastrointestinal mass: 8 persons; E4 - lymphadenopathy: 8 persons; E4 - urolithiasis or hydronephrosis: 8 persons; E4 - other genitourinary: 8 persons; E4 - pancreas mass: 5 persons; E4 - other liver: 4 persons; E4 - adrenal mass: 2 persons; E4 - breast mass: 2 persons | Evaluation with imaging: 113 persons | Clinically significant pathology on followup: 123 persons | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | | Evaluation with imaging: 113 persons | Malignant tumor: 32 persons (7 lymphoma, 5 non-small cell lung cancer, 4 renal cell carcinoma, 1 transitional cell carcinoma, 1 ovarian adenocarcinoma, 1 appendiceal adenocarcinoma, 1 islet cell tumor, 1 pheochromocytoma, 1 adrenal cortical carcinoma, 1 nerve sheath tumor, 2 breast invasive ductal carcinoma, 7 other metastatic cancer)
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | | Evaluation with imaging: 113 persons | Other tumors: 10 persons (4 mucinous tumor, 3 mature teratoma, 3 renal oncocytoma) | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | | Evaluation with imaging: 113 persons | Vascular aneurysms: 46 persons (22 abdominal aortic aneurysms, 11 common iliac aneurysms, 13 visceral abdominal/other aneurysms) | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | | Evaluation with imaging: 113 persons | Other significant pathology: 35 persons (8 obstructing/staghorn urolithiasis, 7 intestinal malrotation, 5 polycystic kidney disease, 4 cirrhosis, 3 sarcoidosis, 2 endometriosis, 2 renal agenesis or dysgenesis, 1 IBD, 1 early acute appendicitis, 1 colovesical fistula, 1 hydrosalpinx) | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | | Evaluation with imaging: 113 persons | Benign disease: 57 persons (2 ovarian serous cystadenoma, 1 adenofibroma, 1 pancreatic serous cystadenoma, pancreas tissue with lymphoepithelial cells, 1 small bowel benign papillary choristoma, 1 small bowel lymphectasia, 1 mesenteric lipoma, 1 appendiceal diverticulum,1 hamartomas of the lung and 1 pelvis. At confirmatory imaging, all liver masses in absence of cirrhosis or 18 other primary malignancy were found to be benign cavernous hemangiomas | NR
Pooler, 2016^282^; Good | Screening only | >2 yrs | C-RADS | Total | 7952 | Other ECF: 13 persons | NR | NR | NR
Sali, 2016^136^; Fair | Screening only | 0 | C-RADS | Total | 1286 | E3–E4: 65 persons | NR | NR | NR
Cash, 2012^222^; Fair | Screening only | NR | C-RADS | Total | 1410 | E3: 196 persons (214 findings); E3 - pulmonary: 68 findings; E3 - retroperitoneal and genitourinary: 68 findings; E3 - gastrointestinal: 45 findings; E3 - Vascular: 33 persons findings; E4: 41 persons (42 findings); E4 - pulmonary: 10 findings; E4 - retroperitoneal and genitourinary: 18 findings; E4 - gastrointestinal: 4 findings; E4 - vascular: 10 findings | NR | NR | NR
Durbin, 2012^233^; Fair | Screening only | NR | Major, moderate, minor^†^ | Total | 490 | Major genitourinary findings: 10 persons; Moderate genitourinary findings: 86 persons; Minor genitourinary findings: 100 persons | Diagnostic workup: 25 persons^‡^ | Renal cell cancer: 2 persons (required surgery) | NR
Stoop, 2012^144^; Fair | Screening only | 0 | C-RADS | Total | 982 | E3–E4: 107 persons | Diagnostic followup: 94 persons | Extra-colonic cancer: 5 persons (4 renal-cell carcinoma, 1 duodenal carcinoma) | NR
Stoop, 2012^144^; Fair | Screening only | 0 | C-RADS | Total | 982 | E3–E4: 107 persons | Diagnostic followup: 94 persons | Abdominal aortic aneurysms: 7 persons | NR
Stoop, 2012^144^; Fair | Screening only | 0 | C-RADS | Total | 982 | E3–E4: 107 persons | Diagnostic followup: 94 persons | Aneurysms of a smaller vessel: 3 persons (3 underwent surgical treatment) | NR
Stoop, 2012^144^; Fair | Screening only | 0 | C-RADS | Total | 982 | E3–E4: 107 persons | Diagnostic followup: 94 persons | Low-risk myelofibrosis: 1 person | NR
Stoop, 2012^144^; Fair | Screening only | 0 | C-RADS | Total | 982 | E3–E4: 107 persons | Diagnostic followup: 94 persons | Paget’s disease: 1 person | NR
Stoop, 2012^144^; Fair | Screening only | 0 | C-RADS | Total | 982 | E3–E4: 107 persons | Diagnostic followup: 94 persons | Glandular papilloma: 1 person | NR
Stoop, 2012^144^; Fair | Screening only | 0 | C-RADS | Total | 982 | E3–E4: 107 persons | Diagnostic followup: 94 persons | Benign lesions: 76 persons (19 kidney, 12 gynecological, 7 liver, 7 lung, 5 adrenal, 26 in other organs) | NR
Zalis, 2012^205^; Good | Screening only | NR | C-RADS | All | 605 | E3: 97 persons; E4: 16 persons | Diagnostic workup: 33 persons | NR | NR
Macari, 2011^268^; Fair | Mixed (including symptomatic) | NR | C-RADS | Total | 454 | E1–E4: 298 persons; E3–E4: 24 persons | Diagnostic workup: 10 persons | NR | NR
Macari, 2011^268^; Fair | Mixed (including symptomatic) | NR | C-RADS | Age <65 | 204 | E1–E4: 113 persons; E3–E4: 9 persons | Diagnostic workup: 4 persons | NR | NR
Macari, 2011^268^; Fair | Mixed (including symptomatic) | NR | C-RADS | Age ≥65 | 250 | E1–E4: 185 persons; E3–E4: 15 persons | Diagnostic workup: 6 persons | NR | NR
O’Connor, 2011^274^,^§^; Fair | Screening only | 3 yrs | Benign, intermediate^ǁ^ | Total | 3001 | Benign renal mass: 376 persons; Indeterminate renal mass: 57 persons | Diagnostic workup: 41 persons | Renal cell cancer: 4 persons (2 additional patients who had benign index masses were found to have renal cell carcinoma 3 yrs later, but did not originate from the index mass or any other identifiable mass on the CTC) | NR
Pickhardt, 2011^277^,^§^; Fair | Screening only | NR | Small, moderate, large^#^ | Total | 3126 | Small hiatal hernia: 1281 persons; Moderate hiatal hernia: 194 persons; Large hiatal hernia: 20 persons | NR | NR | NR
Kim, 2010^253^,^§^; Fair | Screening only | 62 mos (1863 days) | C-RADS | Total | 577 | E3–E4: 89 persons | Diagnostic workup: 45 persons | Substantial but unsuspected diagnosis: 21 persons | NR
Kim, 2010^253^,^§^; Fair | Screening only | 62 mos (1863 days) | C-RADS | Total | 577 | E3–E4: 89 persons | Diagnostic workup: 45 persons | Vascular aneurysms: 18 persons | NR
Kim, 2010^253^,^§^; Fair | Screening only | 62 mos (1863 days) | C-RADS | Total | 577 | E3–E4: 89 persons | Diagnostic workup: 45 persons | Lung cancer: 1 person | NR
Kim, 2010^253^,^§^; Fair | Screening only | 62 mos (1863 days) | C-RADS | Total | 577 | E3–E4: 89 persons | Diagnostic workup: 45 persons | Malrotation: 1 person | NR
Kim, 2010^253^,^§^; Fair | Screening only | 62 mos (1863 days) | C-RADS | Total | 577 | E3–E4: 89 persons | Diagnostic workup: 45 persons | Femoral hernia: 1 person | NR
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | Any surgical or medical treatment: 33 persons; Surgery: 24 persons; Chemotherapy: 12 persons; Radiation treatment: 5 persons; Percutaneous ablation: 2 persons; Palliative: 1 person; Hormonal therapy; 1 person | Malignancy after diagnostic workup: 36 persons | Alive (13–56 mos): 33 persons; Died (21–31 mos): 3 persons; (2 of the deaths related to ECF; one death from unrelated cerebrovascular cause)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Adrenal cancer: 3 persons | All alive at followup (21–55 mos)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Appendix cancer: 1 person | Alive at followup (30 mos)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Hepatocellular cancer: 1 person | Alive at followup (17 mos)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Stomach cancer: 1 person | Alive at followup (34 mos)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Lung cancer: 8 persons | Alive at followup: 6 persons (14–43 mos); Died of lung cancer: 2 persons (21, 31 mos)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Breast cancer: 1 person | Alive at followup (28 mos)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Endometrial cancer: 1 person | Alive at followup (47 mos)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Skin cancer: 1 person | Alive at followup (18 mos)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Non-Hodgkin lymphoma: 6 persons | All alive at followup (26–56 mos)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Prostate cancer: 2 persons | All alive at followup (25–43 mos)
Pickhardt, 2010^279^,^§^; Fair | Screening only | 56 mos | C-RADS | Total | 10286 | NR | | Renal cell cancer: 11 persons | Alive: 10 persons (13–40 mos); Died (of unrelated cerebrovascular cause after 27 mos): 1 persons
Veerappan, 2010^299^; Fair | Screening only | 6 mos – 4 yrs | C-RADS | Total | 2277 | E2–E4: 1037 persons; E2: 787 persons; E3: 211 persons; E4: 39 persons | Diagnostic workup: 199 persons; Surgical or medical treatment: 19 | Cancer: 6 persons | “Curative resection”: 4 persons; Chemotherapy: 2 persons; Status at followup: NR
Veerappan, 2010^299^; Fair | Screening only | 6 mos – 4 yrs | C-RADS | Total | 2277 | E2–E4: 1037 persons; E2: 787 persons; E3: 211 persons; E4: 39 persons | Diagnostic workup: 199 persons; Surgical or medical treatment: 19 | Abdominal aortic aneurysms: 1 person | “Repaired successfully”: 1 person
Flicker, 2008^236^; Fair | Screening only | 1–76 mos | C-RADS | Total | 210 | E3: 30 persons; E3 - nephrolithiasis: 13 persons; E3 - renal complex cyst: 3 persons; E3 - pancreatic calcifications: 2 persons; E3 - fatty liver: 6 persons; E3 - large hiatal hernias: 2 persons; E3 - ovarian cyst ≥3cm: 2 persons; E3 - Abdominal aortic aneurysm ≥3cm: 2 persons | Evaluation with imaging: 6 persons | NR | NR
Flicker, 2008^236^; Fair | Screening only | 1–76 mos | C-RADS | Total | 210 | E4: 6 persons; E4 - abdominal aortic aneurysm ≥3cm: 3 persons; E4 - renal solid mass: 2 persons; E4 - liver solid mass: 1 person | Evaluation with imaging: 5 | NR | NR
Johnson, 2008^177^; Good | Screening only | NR | NR^**^ | All | 2531 | E2–E4: 1665 persons; E3–E4^††^: 428 persons; E4 (requiring urgent care): 30 persons | NR | NR | NR
Johnson, 2008^177^; Good | Screening only | NR | NR^**^ | 50–64 yrs | 2054 | E3–E4^††^: 104 persons; E4 (requiring urgent care): 26 persons | NR | NR | NR
Johnson, 2008^177^; Good | Screening only | NR | NR^**^ | ≥65 yrs | 477 | E3–E4^††^: 324 persons; E4 (requiring urgent care): 4 persons | NR | NR | NR
Kim, 2008^256^; Fair | Screening only | 1–3 yrs | C-RADS | Total | 2230 | E2–E4: 1484 persons (2186 findings); E2: 1707 findings; E3: 358 findings; E4: 115 persons (115 findings) | Diagnostic workup: 100 persons; Surgical or medical treatment: 45 persons | Renal cell cancer: 5 persons | Of 12 persons with malignancies after diagnostic workup:; “Curative surgery”: 11 persons; Treated with radiation therapy: 1 person
Kim, 2008^256^; Fair | Screening only | 1–3 yrs | C-RADS | Total | 2230 | E2–E4: 1484 persons (2186 findings); E2: 1707 findings; E3: 358 findings; E4: 115 persons (115 findings) | Diagnostic workup: 100 persons; Surgical or medical treatment: 45 persons | Hepatocellular cancer: 3 persons | Of 12 persons with malignancies after diagnostic workup:; “Curative surgery”: 11 persons; Treated with radiation therapy: 1 person
Kim, 2008^256^; Fair | Screening only | 1–3 yrs | C-RADS | Total | 2230 | E2–E4: 1484 persons (2186 findings); E2: 1707 findings; E3: 358 findings; E4: 115 persons (115 findings) | Diagnostic workup: 100 persons; Surgical or medical treatment: 45 persons | Pancreatic cancer: 1 person | Of 12 persons with malignancies after diagnostic workup:; “Curative surgery”: 11 persons; Treated with radiation therapy: 1 person
Kim, 2008^256^; Fair | Screening only | 1–3 yrs | C-RADS | Total | 2230 | E2–E4: 1484 persons (2186 findings); E2: 1707 findings; E3: 358 findings; E4: 115 persons (115 findings) | Diagnostic workup: 100 persons; Surgical or medical treatment: 45 persons | Lung cancer: 1 person | Of 12 persons with malignancies after diagnostic workup:; “Curative surgery”: 11 persons; Treated with radiation therapy: 1 person
Kim, 2008^256^; Fair | Screening only | 1–3 yrs | C-RADS | Total | 2230 | E2–E4: 1484 persons (2186 findings); E2: 1707 findings; E3: 358 findings; E4: 115 persons (115 findings) | Diagnostic workup: 100 persons; Surgical or medical treatment: 45 persons | Cervical cancer: 1 person | Of 12 persons with malignancies after diagnostic workup:; “Curative surgery”: 11 persons; Treated with radiation therapy: 1 person
Kim, 2008^256^; Fair | Screening only | 1–3 yrs | C-RADS | Total | 2230 | E2–E4: 1484 persons (2186 findings); E2: 1707 findings; E3: 358 findings; E4: 115 persons (115 findings) | Diagnostic workup: 100 persons; Surgical or medical treatment: 45 persons | Stomach cancer: 1 person | Of 12 persons with malignancies after diagnostic workup:; “Curative surgery”: 11 persons; Treated with radiation therapy: 1 person
Kim, 2008^256^; Fair | Screening only | 1–3 yrs | C-RADS | Total | 2230 | E2–E4: 1484 persons (2186 findings); E2: 1707 findings; E3: 358 findings; E4: 115 persons (115 findings) | Diagnostic workup: 100 persons; Surgical or medical treatment: 45 persons | Malignancy after diagnostic workup: 12 persons | Of 12 persons with malignancies after diagnostic workup:; “Curative surgery”: 11 persons; Treated with radiation therapy: 1 person
Kim, 2008^256^; Fair | Screening only | 1–3 yrs | C-RADS | Male | 1338 | E4: 70 findings; Any extracolonic findings: 944 persons | Diagnostic workup: 100 persons; Surgical or medical treatment: 45 persons | Malignancy after diagnostic workup: 8 persons | Of 12 persons with malignancies after diagnostic workup:; “Curative surgery”: 11 persons; Treated with radiation therapy: 1 person
Kim, 2008^256^; Fair | Screening only | 1–3 yrs | C-RADS | Female | 892 | E4: 45 findings; Any extracolonic findings: 540 persons | Diagnostic workup: 100 persons; Surgical or medical treatment: 45 persons | Malignancy after diagnostic workup: 4 persons | Of 12 persons with malignancies after diagnostic workup:; “Curative surgery”: 11 persons; Treated with radiation therapy: 1 person
Pickhardt, 2008^278^,^§^; Fair | Screening only | 1.6 (18 mos) | C-RADS | Total | 2195 | E4: 204 persons | Diagnostic workup recommended: 157 persons; Diagnostic workup: 133 persons; Surgical or medical treatment: 22 persons | Diagnosis of an unsuspected condition of at least moderate importance: 55 persons | NR
Pickhardt, 2008^278^,^§^; Fair | Screening only | 1.6 (18 mos) | C-RADS | Total | 2195 | E4: 204 persons | Diagnostic workup recommended: 157 persons; Diagnostic workup: 133 persons; Surgical or medical treatment: 22 persons | Benign ovarian tumor: 13 persons | NR
Pickhardt, 2008^278^,^§^; Fair | Screening only | 1.6 (18 mos) | C-RADS | Total | 2195 | E4: 204 persons | Diagnostic workup recommended: 157 persons; Diagnostic workup: 133 persons; Surgical or medical treatment: 22 persons | Malignant tumor: 9 persons (3 non-Hodgkin lymphoma, 3 renal cell carcinoma, 2 abdominal metastatic disease, 1 bronchogenic carcinoma) | NR
Pickhardt, 2008^278^,^§^; Fair | Screening only | 1.6 (18 mos) | C-RADS | Total | 2195 | E4: 204 persons | Diagnostic workup recommended: 157 persons; Diagnostic workup: 133 persons; Surgical or medical treatment: 22 persons | Aortoiliac aneurysm: 12 persons | NR
Pickhardt, 2008^278^,^§^; Fair | Screening only | 1.6 (18 mos) | C-RADS | Total | 2195 | E4: 204 persons | Diagnostic workup recommended: 157 persons; Diagnostic workup: 133 persons; Surgical or medical treatment: 22 persons | Congenital renal anomaly: 4 persons | NR
Pickhardt, 2008^278^,^§^; Fair | Screening only | 1.6 (18 mos) | C-RADS | Total | 2195 | E4: 204 persons | Diagnostic workup recommended: 157 persons; Diagnostic workup: 133 persons; Surgical or medical treatment: 22 persons | Obstructing urolithiasis: 3 persons | NR
Kim, 2007^254^,^§^; Fair | Screening only | NR | C-RADS | Total | 3120 | E2: 1490 persons; E3: 265 persons; E4: 70 persons | Diagnostic workup: 241 persons | Extra-colonic cancer: 8 persons (Treatment NR; 3 renal cancers, 2 bronchogenic cancers, 1 non-Hodgkin’s lymphoma, 1 endometrial cancer, 1 GI stromal tumor) | NR
Pickhardt, 2007^280^,^§^,^‡‡^; Fair | Mixed (including symptomatic) | NR | NR | Total | 2014 | Gastrointestinal: 10 persons | Diagnostic workup: 10 persons; Surgical resection: 7 persons; Endoscopic resection: 1 person | NR | NR
Chin, 2005^224^; Fair | Screening only | 2 yrs | Clinically relevant^§§,**^ | Total | 432 | E2–E4: 118 persons^ǁǁ^; E3–E4^††^: 32 persons | Diagnostic evaluation: 32 persons | Renal cell cancer: 1 person | All patients with relevant ECFs “have been followed up clinically and radiologically for a minimum of 2 years, however, none have progressed to require intervention.”; 1 person with renal cell cancer “is likely to have benefited in terms of mortality from participation in CTC screening program”
Chin, 2005^224^; Fair | Screening only | 2 yrs | Clinically relevant^§§,**^ | Total | 432 | E2–E4: 118 persons^ǁǁ^; E3–E4^††^: 32 persons | Diagnostic evaluation: 32 persons | Abdominal aortic aneurysms: 6 persons
Chin, 2005^224^; Fair | Screening only | 2 yrs | Clinically relevant^§§,**^ | Total | 432 | E2–E4: 118 persons^ǁǁ^; E3–E4^††^: 32 persons | Diagnostic evaluation: 32 persons | Benign lesions: 24 persons
Chin, 2005^224^; Fair | Screening only | 2 yrs | Clinically relevant^§§,**^ | Total | 432 | E2–E4: 118 persons^ǁǁ^; E3–E4^††^: 32 persons | Diagnostic evaluation: 32 persons | Splenic artery aneurysm: 1 person
Chin, 2005^224^; Fair | Screening only | 2 yrs | Clinically relevant^§§,**^ | Female | 202 | E3–E4: 14 persons | Diagnostic evaluation: 32 persons | NR
Chin, 2005^224^; Fair | Screening only | 2 yrs | Clinically relevant^§§,**^ | Male | 230 | E3–E4: 18 persons | Diagnostic evaluation: 32 persons | NR
Ginnerup Pedersen, 2003^238^; Fair | Screened positive (FIT+, FOBT+) | 6 mos | NR^**^ | Total | 75 | E2–E4: 49 persons; E3–E4^††^: 9 persons | Diagnostic workup: 8 persons; Underwent surgery^¶¶^: 2 persons | Lung cancer: 1 person | Lung resection. Recurrent disease, died 1 year after surgery
Ginnerup Pedersen, 2003^238^; Fair | Screened positive (FIT+, FOBT+) | 6 mos | NR^**^ | Total | 75 | E2–E4: 49 persons; E3–E4^††^: 9 persons | Diagnostic workup: 8 persons; Underwent surgery^¶¶^: 2 persons | Fatty sparing hepatic mass: 1 person | NR
Ginnerup Pedersen, 2003^238^; Fair | Screened positive (FIT+, FOBT+) | 6 mos | NR^**^ | Total | 75 | E2–E4: 49 persons; E3–E4^††^: 9 persons | Diagnostic workup: 8 persons; Underwent surgery^¶¶^: 2 persons | Renal cyst: 1 person | NR
Ginnerup Pedersen, 2003^238^; Fair | Screened positive (FIT+, FOBT+) | 6 mos | NR^**^ | Total | 75 | E2–E4: 49 persons; E3–E4^††^: 9 persons | Diagnostic workup: 8 persons; Underwent surgery^¶¶^: 2 persons | Adrenal incidentaloma: 2 persons | NR
Ginnerup Pedersen, 2003^238^; Fair | Screened positive (FIT+, FOBT+) | 6 mos | NR^**^ | Total | 75 | E2–E4: 49 persons; E3–E4^††^: 9 persons | Diagnostic workup: 8 persons; Underwent surgery^¶¶^: 2 persons | Endometrioma: 1 person | Experienced surgical draining of infection after exam
Ginnerup Pedersen, 2003^238^; Fair | Screened positive (FIT+, FOBT+) | 6 mos | NR^**^ | Total | 75 | E2–E4: 49 persons; E3–E4^††^: 9 persons | Diagnostic workup: 8 persons; Underwent surgery^¶¶^: 2 persons | Ovarian cyst ≥4cm: 1 person | NR
Ginnerup Pedersen, 2003^238^; Fair | Screened positive (FIT+, FOBT+) | 6 mos | NR^**^ | Total | 75 | E2–E4: 49 persons; E3–E4^††^: 9 persons | Diagnostic workup: 8 persons; Underwent surgery^¶¶^: 2 persons | Fibromatous uterus: 1 person | NR
Ginnerup Pedersen, 2003^238^; Fair | Screened positive (FIT+, FOBT+) | 6 mos | NR^**^ | Female | 35 | E2–E4: 23 persons; E3–E4: 5 persons | Diagnostic workup: 8 persons; Underwent surgery^¶¶^: 2 persons | NR | NR
Ginnerup Pedersen, 2003^238^; Fair | Screened positive (FIT+, FOBT+) | 6 mos | NR^**^ | Male | 40 | E2–E4: 26 persons; E3–E4: 4 persons | Diagnostic workup: 8 persons; Underwent surgery^¶¶^: 2 persons | NR | NR
Gluecker, 2003^239^; Fair | Mixed (including symptomatic) | ≥12 mos | High, moderate, low importance^##^ | Total | 681 | E2–E4: 469 persons (858 findings); E2: 341 persons (574 findings); E3: 183 persons (196 findings); E4: 71 persons (88 findings) | Diagnostic workup: 109 procedures^***^; Surgical or medical treatment: 9 persons^†††^ | NR | NR
Pickhardt, 2003^195^,^‡‡‡^; Good | Screening only | NR | High, moderate, low importance^##^ | All | 1233 | E4: 56 persons | Required diagnostic imaging: NR; Underwent successful repair of unsuspected abdominal aortic aneurysms: 2 persons | Extra-colonic malignancy: 5 persons (1 lymphoma, 2 bronchogenic carcinoma, 1 ovarian cancer, 1 renal cancer) | Underwent “successful repair” of unsuspected abdominal aortic aneurysms: 2 persons
Hara, 2000^242^; Fair | Screening only | 7–22 mos | High, moderate, low importance^##^ | Total | 264 | E2–E4: 109 persons; E2: 55 persons; E3: 46 persons; E4: 30 persons | Diagnostic workup: 18 persons; Required ongoing followup: 4 persons; Surgical or medical treatment: 6 persons | Renal cell cancer: 2 persons (required surgery) | Both patients “underwent nephrectomy and had no metastases”
Hara, 2000^242^; Fair | Screening only | 7–22 mos | High, moderate, low importance^##^ | Total | 264 | E2–E4: 109 persons; E2: 55 persons; E3: 46 persons; E4: 30 persons | Diagnostic workup: 18 persons; Required ongoing followup: 4 persons; Surgical or medical treatment: 6 persons | Abdominal aortic aneurysms: 2 persons | NR
Hara, 2000^242^; Fair | Screening only | 7–22 mos | High, moderate, low importance^##^ | Total | 264 | E2–E4: 109 persons; E2: 55 persons; E3: 46 persons; E4: 30 persons | Diagnostic workup: 18 persons; Required ongoing followup: 4 persons; Surgical or medical treatment: 6 persons | Pneumothorax: 1 person (required surgery) | NR
Hara, 2000^242^; Fair | Screening only | 7–22 mos | High, moderate, low importance^##^ | Total | 264 | E2–E4: 109 persons; E2: 55 persons; E3: 46 persons; E4: 30 persons | Diagnostic workup: 18 persons; Required ongoing followup: 4 persons; Surgical or medical treatment: 6 persons | Intermediate lesions: 4 persons (2 pulmonary nodules, 2 probable adrenal adenomas) | NR
Hara, 2000^242^; Fair | Screening only | 7–22 mos | High, moderate, low importance^##^ | Total | 264 | E2–E4: 109 persons; E2: 55 persons; E3: 46 persons; E4: 30 persons | Diagnostic workup: 18 persons; Required ongoing followup: 4 persons; Surgical or medical treatment: 6 persons | Benign lesions: 9 persons (Renal cysts 4, pulmonary granuloma 1, liver with focal fat 1, 4.2 cm AAA 1, hepatic cyst 1, splenic cyst 1) | NR

* New diagnoses were: 16 (0.54%) masses (including 3 gastrointestinal extracolonic tumors, 4 urinary tract masses, 4 ovarian masses or complex cysts, 1 adrenal mass, 2 pancreatic masses, 1 adenopathy, and 1 liver mass) and 9 (0.3%) aneurysms (including 8 aortic aneurysms).

† Evaluated genitourinary findings only. Major: high clinical importance, required definitive management; Moderate: Potential moderate clinical significance; Minor: no or little clinical importance

‡ Consists of 16 persons with adrenal masses on CTC and 9 with renal masses on CTC

§ Overlapping populations from the University of Wisconsin screening program

ǁ Evaluated renal masses only. Benign renal mass defined as masses containing fat or with attenuation less than 20 HU or greater than 70 HU without thickened walls or septations, three or more septations, mural nodules, or thick calcifications. Indeterminate renal mass defined as attenuation between 20 and 70 HU or any with without thickened walls or septations, three or more septations, mural nodules, or thick calcifications.

# Evaluated hiatal hernias only

** Definitions for extracolonic findings in the publication are similar to C-RADS E1–E4 definitions and have been labeled as such

†† Likely includes a portion of extracolonic findings corresponding to C-RADS E3

‡‡ Only evaluated extracolonic GI tumors

§§ Required medical or surgical attention, or further hematological, biochemical, and/or radiological investigation after reviewing patient’s medical history

ǁǁ All patients followed for ≥2 yrs; none progressed to require intervention

¶¶ Underwent surgery because of the workup or because of complications of the workup

## High importance: findings requiring surgical treatment, medical intervention, and/or further investigation during that patient care visit [similar to C-RADS E4], Moderate importance: benign findings that may eventually require medical or surgical intervention [similar to C-RADS E3], Low importance: unlikely to require any future treatment [similar to C-RADS E2]

*** 94 procedures in patients with high clinical importance, 15 procedures in patients with moderate clinical importance

††† 1 abdominal aortic aneurysm, 1 squamous cell carcinoma of the lung, 1 thyroid metastases to the lung, 1 renal adenocarcinoma, 1 renal oncocytoma, 3 serous cystadenoma of the ovary, 1 ileal ascariasis

‡‡‡ From University of Wisconsin screening program but in a non-overlapping time frame.

Abbreviations: Cat = Categorization; C-RADS = CT Colonography Reporting and Data System; E1 = normal examination or anatomic variant; E2 = clinically unimportant finding; E3 = findings unlikely to be clinically significant; E4 = potentially clinically important findings; ECF = Extracolonic findings; F/U = Followup; Hx = History; Mos = Months; NR = not reported; Yrs = Years

The most common ECF was E2 (clinically unimportant requiring no further workup). In 10 studies reporting E2 findings, ECFs occurred in 19.9 to 53.3 percent of examinations. ECFs requiring further workup of potentially important findings (E4) ranged from 1.3 to 11.4 percent in 11 studies. In six studies reporting E3 and E4 findings combined, the findings occurred in 4.4 to 16.9 percent of examinations. E3-level findings occurred in 3.4 to 26.9 percent of examinations in 10 studies. Based mostly on indirect comparisons, we did not find large differences in the prevalence of extracolonic findings (any or clinically significant) between studies limited to screening populations and those in asymptomatic people.

Twenty of 27 studies reported clinical followup of ECFs, typically limited to E4 findings. Among studies adequately reporting subsequent treatment, a minority of individuals screened (≤3%) required definitive medical or surgical treatment. Extracolonic cancers were not common and occurred in only 0.5 percent of people undergoing CTC examinations. In the largest series of examinations (n=10,286), which had about 4 years of followup, 36 (0.35%) examinations found an extracolonic malignancy, 32 of which received definitive treatment.^279^ Abdominal aortic aneurysm occurred in up to 1.4 percent of people. Only seven of the studies reported clinical followup beyond the diagnosis of ECF. The clinical followup varied in terms of length of followup and details of the followup (e.g., curative resection for malignancy, cancer treatment received, successful surgery for abdominal aneurysm). In the largest study (n=10,286), of the 36 people diagnosed with extracolonic malignancy, two people with lung cancer and one person with renal cell cancer died, and the rest were alive at up to 56 months.^279^ From this limited reporting of longer-term clinical followup, it is difficult to assess the net benefit to patients with incidental ECF on screening CTC.

##### Extracolonic Findings by Age, Sex, Race/Ethnicity, or Family History

Extracolonic findings may be more common with increasing age. The mean age in these studies ranged from 57 to 75 years. In the two studies with a mean age of 65 years or older, the percent with E3–E4 extracolonic findings was on average higher than in studies with younger mean ages.^222,^ ^253^ Two studies^177,^ ^268^ compared extracolonic findings in people younger than age 65 years with those of people age 65 years and older. Both studies found a higher prevalence of both any extracolonic finding and extracolonic findings that warranted further workup (E3–E4). Three studies^224,^ ^238,^ ^256^ reported ECF by sex, finding similar rates of ECFs in both groups.

#### Harms of Capsule Endoscopy

Only one study^198^ (n=689) for screening capsule endoscopy reported harms. Zero serious adverse events and three nonserious adverse events related to the capsule procedure. These events, which were all resolved on the same day, included gagging, vomiting, and abdominal cramping. One large retrospective study^356^ (n=5,428) of diagnostic capsule endoscopy was excluded because it was conducted in people with upper and lower GI symptoms; this study found approximately 0.5 percent serious adverse events (e.g., aspiration, capsule retention).