# Chapter 1 Introduction

## Purpose

This report will be used by the United States Preventive Services Task Force (USPSTF) to update the 2016 screening for colorectal cancer recommendation.^1^

## Condition Definition

Colorectal cancer (CRC), also called colorectal adenocarcinoma, is a malignant tumor that develops within the walls of the large intestine, which comprises the following segments: the cecum, ascending colon, transverse colon, descending colon, sigmoid, and rectum. CRC does not include tumors in the tissues of the anus or the small intestine. Adenomas are benign epithelial polyps that can progress to adenocarcinomas (Table 1). Adenomas can be flat, sessile, or pedunculated. Adenomas can have different degrees of dysplasia or different histologic characteristics (e.g., tubular, tubulovillous, villous). Advanced adenomas (AAs) are benign tumors with an increased likelihood to progress to CRC. Sessile serrated lesions (SSLs)—also referred to as sessile serrated adenomas or polyps—also have an increased risk of progression to CRC.^2^ However, SSL are not usually included in the definition of an advanced adenoma (AA). Although there is some variation in the exact definition of AAs, they generally refer to adenomas 1 cm or larger, with villous components (tubulovillous or villous), or with high-grade or severe dysplasia. The term advanced neoplasia (AN), on the other hand, refers to a composite outcome of AAs and all stages of CRC.

Table 1 Definitions of Terms Describing Colorectal Cancer and Its Precursor Lesions

Term | Definition
Adenoma | Benign epithelial tumor or polyp
Advanced adenoma (AA) | Adenoma ≥1 cm in size, with tubulovillous/villous histology, or with high-grade dysplasia^*^
Sessile serrated lesion (adenoma or polyp) (SSL) | Adenoma with specific morphology (sessile), histology (serrated), and characteristic molecular features (serrated polyp with at least one unequivocal aberrant crypt) with potential for malignant transformation
Carcinoma in situ | Severe dysplasia limited to the mucosa, Stage 0 colorectal cancer
Adenocarcinoma | Malignant tumor that invades the muscularis mucosa, Stage I-IV colorectal cancer
Advanced neoplasia (AN) | Advanced adenoma and all stages of colorectal cancers

* Exact definitions may vary slightly

## Prevalence and Burden

CRC causes significant morbidity and mortality in the United States: Among all cancers, it is third in incidence and cause of cancer death for both men and women.^3^ However, incidence rates have been declining for the past 20 years. According to data from the National Cancer Institute’s (NCI’s) Surveillance, Epidemiology, and End Results (SEER) Program, the age-adjusted incidence of CRC has fallen from 53.2 new cases per 100,000 people in 1995 to 36.5 new cases per 100,000 people in 2015.^4^ Approximately 94 percent of CRC diagnoses occur in adults older than age 45 years.^4^ However, cohort trends indicate that CRC incidence is decreasing only for those age 55 years and older, and increasing among those younger than 55 years.^5^ The incidence of CRC has increased by 1 to 2 percent annually since the mid-1980s in adults ages 20–39, and by 0.5 to 1.3 percent annually since the mid-1990s in adults ages 40–54.^6^ As a result, the incidence of CRC in persons age 45 years in 2011 was comparable to the incidence in persons age 50 years in 1992 prior to widespread screening (24.0 and 25.6 cases per 100,000 persons respectively), although the incidence of CRC in persons age 45 have declined somewhat since 2011 (20.8 cases per 100,000 persons in 2016).^7^

The lifetime risk of acquiring CRC in the United States is about 4.2 percent, with an age-adjusted death rate of 14.5 deaths per 100,000 people. Survival largely depends on the stage of cancer at the time of diagnosis. Patients with localized disease at diagnosis have a 5-year survival rate of 90 percent. Five-year survival rates drop to 71 percent, however, for those diagnosed with regionalized disease (cancer spread to regional lymph nodes). These rates decrease dramatically—to 14 percent—for those with distantly metastasized disease.^4^

Increasing age, male sex, and Black race are all associated with an increased incidence of CRC (Figure 1). The median age at diagnosis is 67 years, and nearly half of all new cases are diagnosed in people ages 65–84 years.^4^ Based on data from the National Cancer Database (NCDB), the trend of increasing CRC diagnoses in adults under 50 years from 2004–2015 appeared to be similar for men and women; increases in CRC diagnoses in adults under 50 years were observed in white and Latino but not Black or Asian people.^8^ Black and Latino people have higher proportions of CRC diagnosed before age 50 years (14.0 and 18.3 percent respectively) compared to white people (11.0 percent). Overall Black men and women have the highest incidence of CRC compared with other racial/ethnic subgroups. This is troubling given that Black men and women also have a disproportionately high mortality from CRC.^3,^ ^9,^ ^10^ This health disparity has increased in the past 20 years, illustrated by the fact that CRC incidence and mortality rates have decreased more among white people than Black people.^3,^ ^11,^ ^12^ The overall 5-year age-adjusted CRC-related death rate (2014–2018) is notably higher in Black, as well as American Indian and Alaskan Native, people as compared to Latino and Asian Pacific Islanders people: 22.5 deaths per 100,000 Black men and 14.8 deaths per 100,000 Black women, 18.4 deaths per 100,000 American Indian and Alaskan Native men and 12.4 deaths per 100,000 American Indian and Alaskan native women, 14.0 deaths per 100,000 Latino men and 8.6 deaths per 100,000 Latina women, and 11.2 per 100,000 Asian or Pacific Islander men and 7.9 per 100,000 Asian or Pacific Islander women.^4^

Figure 1 Age-Specific Colorectal Cancer Incidence Rates/100,000 by Race/Ethnicity, United States, 1999–2014

Note: Data combined from the Center for Disease Control and Prevention National Program of Cancer Registries and the National Cancer Institute Surveillance, Epidemiology and End Results Program.^459^

* Not mutually exclusive from race categories

Abbreviations: AI = American Indian; AN = Alaska Native; CRC = colorectal cancer; PI = Pacific Islander

Figure 1 in the age-specific colorectal cancer incidence rates per 100,000 grouped by race/ethnicity in the United States from 1999 to 2014. The graphs show the incidence for male and females together, males alone, and females alone. Briefly, increasing age, male sex, and black race are all associated with an increased incidence of CRC.

### Proximal vs. Distal Cancers

The distal large intestine can be defined as distal to the splenic flexure (including the descending colon, sigmoid colon, and rectum). The proximal large intestine or colon is generally defined as proximal to the splenic flexure (including the cecum, ascending and transverse colon).

CRC incidence differs by tumor location in the colon.^12–14^ Based on data from the NCI’s SEER Program and the North American Association of Central Cancer Registries (NAACCR) from 2009–2013, the age-adjusted incidence of cancer is 20.5 cases per 100,000 people in the distal colon/rectum and 16.9 cases per 100,000 people in the proximal colon.^15^ CRC prognosis and mortality also varies by anatomic location. Analyses of SEER data have shown a higher late- to early-stage incidence for proximal compared to distal colon/rectum cancer.^16^ Proximal cancers have lower 5-year survival (65% vs. 69%) and greater mortality compared with distal cancers.^15^ Colonoscopy may also be less effective in reducing proximal compared to distal CRC incidence and mortality.^17–21^ The reason for this finding remains unclear and we do not know if this discrepancy is due to inadequate quality/implementation of colonoscopy (e.g., failure to reach the cecum, poor bowel preparation) and/or to biologic differences in the types of lesions and natural history of lesions in the proximal versus distal large intestine. It is well-established that there are physiological differences between the proximal and distal large intestine as well as differences in proximal and distal CRC.^22^ Cancers in the proximal and distal colon appear to arise from different molecular pathways, and these molecular differences may explain differences in both morphology and natural history.^22,^ ^23^ ^16,^ ^24,^ ^25^

The distribution of CRC differs by age, sex, and race/ethnicity. The incidence of proximal cancers is higher with advancing age.^3^ A 2019 systematic review of the anatomic distribution of CRC in younger adults found that approximately 75 percent of CRC diagnosed before age 50 are in the distal colon and rectum.^26^ Based on data from the NAACCR from 2012–2016, proximal cancers are also more common in women than in men.^3^ Despite this difference, men have higher rates of CRC (distal and proximal) incidence and mortality.^3^ Based on SEER data, the overall decrease in incidence of distal cancers between 1980–1984 and 2000–2013 was greater among white people than Black people.^27^ In addition, Black men and women appear to have a higher proportion of proximal cancers and lower 5-year survival rates for proximal cancers than other racial/ethnic groups.^28^ Although poverty is a confounder for CRC incidence and survival, recent data suggest that socioeconomic status plays a more prominent role for distal colon and rectal cancers than proximal cancers in white, Black, and Asian and Pacific Islander people.^16,^ ^29,^ ^30^

## Etiology and Natural History

CRC usually develops over a period of several years, with the cancer beginning as a precancerous lesion. Experts estimate that at least 95 percent of cases of CRC arise from preexisting adenomas.^31,^ ^32^ This hypothesis that CRC arises from an adenoma-carcinoma sequence initially came from observations of a greatly elevated CRC risk status in patients with hereditary polyposis syndromes^33–35^ and from observational studies showing a reduction in CRC incidence after polypectomy.^36–43^

Colorectal adenomas are very common; a 2009 meta-analysis found that the pooled prevalence of adenomas was 30.2 percent (95% CI, 27 to 33) among people undergoing routine screening.^44^ While adenomas can develop into cancers, most do not. Each adenoma’s tendency toward net growth or regression, however, may vary by polyp size and histology, as well as by other characteristics such as patient age, tumor location, and number of lesions.^45,^ ^46^ In general, larger adenomas and those with greater dysplasia are more likely to progress to cancer.^47^ SSLs, as opposed to other adenomas, may not initially have dysplasia but do have malignant potential.^48^ These lesions are the major precursor lesion of serrated pathway cancers and are thought to represent 20 to 35 percent of CRC cases.^48^ Overall, the rate of progression of adenoma to cancer is unknown, such that some lesions grow quickly and others very slowly.

While there is general agreement that the risk of in situ cancer, or progression to cancer, for polyps 10 mm or larger is sufficiently high as to require immediate removal, the necessity and benefit of removing smaller polyps is not clear.^49,^ ^50^ A recent review found that those with low-risk adenomas (small tubular adenomas with no high-grade dysplasia) had an increased risk of developing AAs compared to those with a normal colonoscopy, but a lower risk of developing CRC and of CRC mortality when compared to the general population.^51^ Greater understanding of the natural history of small adenomas will influence choice and implementation of screening test as well as definitions of test positivity (e.g., referral, polypectomy, or surveillance criteria for endoscopy and computed tomographic colonography [CTC]). In addition, unnecessarily removing smaller polyps can increase the risk of harms, including bleeding and perforation. A systematic review by Hassan and colleagues assessed the distribution of AAs in average-risk screening populations according to polyp size and reported that the overall prevalence of AAs was 5.6 percent (95% CI, 5.3 to 5.9) in four studies (n=20,562). The prevalence of diminutive polyps (≤5 mm) was 27 percent, prevalence of small polyps (6–9 mm) was 9 percent, and prevalence of large polyps (≥10 mm) was 6 percent. Diminutive polyps (≤5 mm) accounted for 4.6 percent (95% confidence interval [CI], 3.4 to 5.8) of patients with AAs. Small polyps (6–9 mm) accounted for 7.9 percent (95% CI, 6.3 to 9.4) of patients with AAs. In contrast, large polyps (≥10 mm) accounted for 87.5 percent (95% CI, 86.0 to 89.4) of AAs.^52^

One large cohort study (n=22,006) of asymptomatic adults undergoing routine CRC screening with CTC demonstrated that 9 percent (1,982/22,006) of adults had small polyps (6–9 mm) at baseline. Of the 306 small polyps in 243 adults who were followed with CTC surveillance (mean surveillance interval 2.3 years), 22 percent (68/306) progressed (≥20% growth), 50 percent (153/306) were stable, and 28 percent (85/306) regressed (≥20% reduction). Histology was established in 43 percent of polyps (131/306) after final CTC. Ninety-one percent (21/23) of proven AAs compared to 37 percent (31/84) of proven nonadvanced adenomas progressed.

The prevalence of adenomas, as well as their tendency toward net growth, increases with aging and male sex.^45,^ ^46,^ ^53,^ ^54^ However, it is yet uncertain the role that race/ethnicity plays in the natural history of adenomas. A large cohort study among screening colonoscopy recipients through Kaiser Permanente Northern California (n=20,792) evaluated the prevalence of adenomas by age, sex, and race/ethnicity. It found that the prevalence of adenomas substantially increased with age and male sex, and also that proximal adenomas were more common in Black than white people, although the total prevalence of adenomas was similar.^53^ A cross-sectional study^55^ assessing data from the Clinical Outcomes Research Initiative (CORI) compared the prevalence of large polyps (<9 mm) in people undergoing screening colonoscopy (n=177,666). It found that men had a greater prevalence of large polyps compared with women, and Black women had a greater prevalence of large polyps than non-Black women and similarly aged men. However, a 2018 systematic review^56^ found that among average-risk individuals undergoing colonoscopy (n=302,128), the prevalence of AAs did not differ significantly between Black (6.57%) and white (6.20%) participants, although a subgroup analysis of five studies that evaluated advanced proximal lesions demonstrated a higher prevalence of AAs in Black compared with white participants. In addition, CRC screening trials have generally found similar prevalence of adenomas and AAs in Black participants compared with white participants.^57,^ ^58^

## Risk Factors

Most cases of CRC are sporadic, with 75 percent developing in average-risk people, versus about 20 percent developing in people with some type of family history. The remainder of cases develop in people who have predisposing inflammatory bowel disease or a known inherited familial syndrome (defined by mutations in known high-risk cancer susceptibility genes), including familial adenomatous polyposis and Lynch syndrome (previously known as hereditary nonpolyposis colorectal cancer).^59–62^ Family history of CRC that is not attributable to any known inherited syndromes is a well-established risk factor (Appendix H).^63^ People with a family history of CRC are commonly cited as having an average 2- to 4-fold increase in risk of CRC compared with those who do not have a family history, but there is great heterogeneity in the published literature in how family history is defined (age of relative[s] with CRC, the number of relative[s] with CRC, and relationship to relative[s] with CRC).^64–66^ As a result, the risk of developing CRC varies approximately 20-fold between people in the lowest quartile (average lifetime risk, 1.25%) and the highest quartile (average lifetime risk, 25% in people with an inherited familial syndrome).^67,^ ^68^

Some modifiable risk factors, with varying levels of evidence, have also been linked to an increased or decreased risk of developing CRC. Most notably long-term smoking, unhealthy alcohol use, being overweight or having obesity, and having type 2 diabetes appear to increase the risk of developing CRC.^69–71^

## Rationale and Current Clinical Practice

Because CRC has precursor lesions and survival largely depends on the stage at the time of diagnosis, screening can find and remove precancerous lesions that could later become malignant, and/or detect early cancers that can be more effectively treated than later stage cancers. Screening for CRC generally implies a screening program in which there is a method for identifying those eligible for (and interested in) screening and to administer repeated screening and followup testing as indicated over time. Adherence to both screening and followup testing is a critical factor in the effectiveness of a screening program.

Large, well-conducted randomized, controlled trials (RCTs) have demonstrated that screening for CRC can reduce disease incidence and disease-specific mortality. The decrease in CRC incidence and mortality in the past two decades in the United States corresponds to an increase in self-reported screening rates. In 2018, 69 percent of adults age 50 to 75 years reported they were up to date with their CRC screening.^72^ However, there is evidence of racial/ethnic and socioeconomic disparities in CRC screening, with lower rates of CRC screening in nonwhite and Hispanic populations and less-educated adults.^73,^ ^74^ Multiple patient, clinician, and healthcare delivery factors have been found to negatively influence CRC screening, including low socioeconomic or educational status, lack of physician recommendation, and lack of insurance or limited access to healthcare.^73,^ ^75^

In contrast to many other cancers, there are multiple tests that screen for CRC, including direct visualization, stool-based, serum-based, and urine-based testing (Table 2). Except for screening colonoscopy, an abnormal result on any of these screening tests necessitates a followup colonoscopy. Many of these tests have been evaluated as screening tests, but each modality has differing levels of evidence to support their use, as well as different considerations about their tradeoffs (including harms), feasibility, acceptability, and availability. Colonoscopy remains the most commonly used screening modality in the United States.^76–78^ In 2015, for example, 58.3 percent of U.S. residents had up to date screening with colonoscopy compared with 7.1 percent with a stool test (fecal occult blood test [FOBT]) and 0.7 percent with flexible sigmoidoscopy (FS) in combination with a stool test (FOBT).^76^ Biomarkers in stool, blood, and urine samples are of continued interest, and a field of active research. To date, however, only two tests incorporating biomarkers are currently FDA approved to screen for CRC (Cologuard and Epi proColon)^79^; the urine test (PolypDx) is available as a test for Clinical Laboratory Improvement Amendments (CLIA) certified laboratories.

Table 2 Available Screening Tests for Colorectal Cancer

Type of test | Screening test | Considerations on evidence and availability
Direct visualization | Flexible sigmoidoscopy | Original RCTs show effectiveness of reducing CRC mortality; modeling studies suggest that flex sig used with FIT performs better than flex sig alone; currently very limited availability in the United States.
Direct visualization | Colonoscopy | Prospective cohort study demonstrating association with reduction in CRC mortality; most commonly used screening test in the United States.
Direct visualization | CT colonography | Test performance similar to colonoscopy for larger adenomas; uncertain impact of the visualization of extra-colonic findings and radiation exposure.
Direct visualization | Capsule endoscopy | Currently used as a diagnostic test; evaluation as a screening test extremely limited with only one group recommending this as a lower tiered test. FDA approval is as an adjunctive test in patients with prior incomplete colonoscopy.
Direct visualization | MRC | Currently used as a diagnostic, not screening, test; evaluation as a screening test extremely limited.
Direct visualization | DCBE | No longer used in clinical practice for screening due to inferior test performance compared to other available direct visualization tests.
Stool-based^*^ | gFOBT | Original RCTs show effectiveness of reducing CRC mortality conducted using older guaiac-based FOBT; currently used gFOBT (HSgFOBT) have superior test performance compared with older versions.
Stool-based^*^ | FIT | Immunochemical FOBT, or FITs, are not a homogeneous class of tests, and multiple manufacturers produce different FITs with differing test performance; many available FITs have superior test performance and greater feasibility (no dietary restriction and single specimen) compared to gFOBT
Stool-based^*^ | sDNA | Stool-based DNA testing has evolved over time from single target to multi-targeted DNA tests paired with FIT (sDNA-FIT); currently only one sDNA-FIT stool test is FDA approved for CRC screening
Serum-based | mSEPT9 | Currently only one serum-based test, testing for methylated septin 9 gene, is available for use with inferior test performance to stool-based testing; FDA approval is for screening only in persons unwilling or unable to be screened by gFOBT, FIT, FS, or colonoscopy.
Urine-based | Metabolomic-based test | Only one urine-based test, testing for various metabolites in the urine and clinical risk factors, is available for use by CLIA-certified laboratories. Limited evidence on test accuracy.

* Stool testing should be performed on spontaneously voided stool samples, as opposed to in-office stool samples obtained by digital rectal examination, because of the less sensitive or unclear test performance of the latter.^460,^ ^461^

Abbreviations: CRC = colorectal cancer; CT = computed tomography; DCBE = double-contrast barium enema; DNA = deoxyribonucleic acid; FDA = Food and Drug Administration; FIT = fecal immunochemical test; FOBT = fecal occult blood test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; HS = high-sensitivity; MRC = magnetic resonance colonography; RCT = randomized controlled trial; sDNA = stool-based deoxyribonucleic acid

## Current Screening Recommendations

Most organizations strongly endorse CRC screening but there are some difference on preferred screening strategies as well as on recommendations around ages to start and stop screening. The optimal age to start screening may vary by sex or race/ethnicity based on differences in onset and incidence of CRC. When screening should stop for average-risk adults is uncertain; thus, screening from ages 76 to 85 years should be individualized based on the patients’ comorbid conditions and prior screening results.

Currently, most U.S. guideline organizations, including the USPSTF, agree that the recommended options in screening for CRC include colonoscopy every 10 years, annual high-sensitivity guaiac FOBT (gFOBT) or fecal immunochemical test (FIT), and FS every 5 to 10 years with stool blood testing (FOBT or FIT). Among professional societies in the United States and internationally, a number of important areas of disagreement remain (e.g., age to start/stop screening, risk tailored screening, interval of screening, preferred screening modalities) (Table 3). Some notable differences exist between the 2016 USPSTF recommendation and the 2018 American Cancer Society (ACS) and 2017 U.S. Multi-Society Task Force (USMSTF) recommendations. The ACS recommends CRC screening for all adults beginning at age 45 (qualified recommendation), the USMSTF recommends that African Americans begin screening at 45 years and others at age 50 years, and the USPSTF recommends that screening begin at age 50 for all people. The USPSTF and USMSTF both recommend colonoscopy, FIT, FS with or without FIT, stool DNA with FIT (sDNA-FIT), and CTC, but the USMSTF prioritizes certain strategies over others (colonoscopy and FIT as the first tier) and recommends capsule endoscopy (third tier). ACS states that clinicians should be prepared to offer both stool based or visual exam options when recommending screening. There is also variation in the recommended age to stop screening, with recommended ages to stop spanning from 74 to 85 years. Notably, two groups (CTFPHC, Council of the European Union) do not recommend colonoscopy to screen for CRC, and the American Academy of Family Physicians does not recommend CTC. One guideline panel, as part of the BMJ Rapid Recommendations series, issued a weak recommendation against screening in asymptomatic adults ages 50 to 79 with an estimated 15-year CRC risk below 3 percent using a risk calculator including a number of variables in addition to age, sex, race/ethnicity, and family history.^80^

Table 3 Recommended Screening Tests for Colorectal Cancer by Selected Society or Professional Organization Since 2008

Society or Professional Organization, Year | Age to begin screening | Age to stop screening | Screening test; (recommended interval, years)
Society or Professional Organization, Year | Age to begin screening | Age to stop screening | Colonoscopy | FS^*^ | gFOBT^†^ | FIT | CTC | FIT-DNA | mSEPT9 | Capsule
ACP, 2019^462^ | 50 | 76 | Y; (10) | Y; (10) | Y; (2) | Y | -- | -- | -- | --
BMJ International Panel, 2019^‡^ | 50^††^; (if 15-year CRC risk >3%) | 79 | Y; (15) | Y; (15) | -- | Y; (1–2) | -- | -- | -- | --
ACR, 2018^463^ | 50 | -- | -- | -- | -- | -- | Y; (5) | -- | -- | --
ACS, 2018^464^ | 45 | 85 | Y; (10) | Y; (5) | Y; (1) | Y; (1) | Y; (5) | Y; (3) | N | N
USMSTF,^***^ 2017^465^ | 50; (45 for AA) | 85 | Y; (10) | Y^**^; (5–10) | N | Y; (1) | Y^**^; (5) | Y^**^; (3) | N | Y^**^; (5)
CTFPHC, 2016^466^ | 50 | 74 | N | Y; (10) | Y; (2) | Y; (2) | -- | -- | -- | --
SIGN, 2016^467^ | -- | -- | -- | -- | Y | Y | -- | -- | -- | --
USPSTF, 2016^1^ | 50 | 85 | Y; (10) | Y; (5–10) | Y; (1) | Y; (1) | Y; (5) | Y; (1–3) | N | N
AAFP, 2015^468^ | 50 | 75 | Y; (10) | Y | Y | Y | N | N | -- | --
NCCN, 2015^469^ | 50 | -- | Y^§^; (10) | Y^§^ | Y; (1) | Y | Y^§^; (5) | N | -- | --
Council of the European Union, 2012^470^ | -- | -- | N | N | Y; (<2) | -- | -- | -- | -- | --
ICSI, 2012^471^ | 50; (45 for AA) | -- | Y; (10) | Y; (5) | Y; (1) | Y; (1) | Y; (5) | -- | -- | --

* With or without stool testing

† High sensitivity

‡ For individuals with an estimated 15-year risk above 3% (For individuals with an estimated 15-year colorectal cancer risk below 3%, BMJ suggests no screening)

** The USMSTF recommends tests in tiers. First tier is colonoscopy and FIT; second tier is CTC, FIT-DNA, and FS; and the third tier is capsule endoscopy.

§ NCNN encourages tests that are designed to detect both early cancer and adenomatous polyps.

*** USMSTF includes American Gastroenterological Association, American College of Gastroenterology, and American Society for Gastrointestinal Endoscopy

†† For those with a 15-year CRC risk below 3%, no screening was suggested

Abbreviations: AA = African American; AAFP = American Academy of Family Physicians; ACP = American College of Physicians; ACR = American College of Radiology; ACS = American Cancer Society; CTFPHC = Canadian Task Force on Preventive Health Care; CTC = computed tomography colonography; DCBE = double-contrast barium enema; DNA = deoxyribonucleic acid; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; I = insufficient evidence to evaluate; ICSI = Institute for Clinical Systems Improvement; MRC = magnetic resonance colonography; N = no, not recommended; NCCN = National Comprehensive Cancer Network; SIGN = Scottish Intercollegiate Guidelines Network; USMSTF = US Multi-Society Task Force; USPSTF = US Preventive Services Task Force; Y = yes, recommended as an acceptable option; -- = not addressed in the guideline

## Previous USPSTF Recommendation

In 2016, the USPSTF recommended screening for CRC starting at age 50 years and continuing until age 75 years (A recommendation). The decision to screen for CRC in adults ages 76 to 85 years should be based on the individual, taking into account the patient’s overall health and prior screening history (C recommendation). Adults in this age group who have never been screened for CRC are more likely to benefit. Screening would be most appropriate among adults who (1) are healthy enough to undergo treatment if CRC is detected and (2) do not have comorbid conditions that would significantly limit their life expectancy. The A recommendation was based on high certainty that the net benefit of screening for CRC in adults ages 50 to 75 years was substantial (i.e., reduced CRC mortality and few harms of screening). The C recommendation was based on moderate certainty that the net benefit of screening for colorectal cancer in adults ages 76 to 85 years who have been previously screened is small, and adults who have never been screened for colorectal cancer are more likely to benefit.

The 2016 recommendation differed from the 2008^81^ recommendation in two important ways. First, the 2016 recommendation offered an expanded number of strategies to screen for CRC, including high sensitivity guaiac-based fecal immunochemical test (HSgFOBT) or FIT annually, sDNA-FIT annually or every 3 years, colonoscopy every 10 years, CTC or FS every 5 years, and FS every 10 years with annual FIT. The recommendation noted that the different options had varying levels of evidence supporting their effectiveness, as well as different strengths and limitations. Second, the 2016 recommendation eliminated the D recommendation for adults older than 85 years; however, the 2016 recommendation still stated in the clinical considerations section that adults older than 85 years should not receive CRC screening.