# References

1 Wells G, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed December 3, 2018. PMID.
2 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529–36. PMID: 22007046. 10.7326/0003-4819-155-8-201110180-00009 22007046
3 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. PMID: None.
4 Lee JK, Liles EG, Bent S, . Accuracy of fecal immunochemical tests for colorectal cancer: systematic review and meta-analysis. Ann Intern Med. 2014;160(3):171. PMID: 24658694. 10.7326/M13-1484 24658694
5 Levy BT, Bay C, Xu Y, . Test characteristics of faecal immunochemical tests (FIT) compared with optical colonoscopy. J Med Screen. 2014;21(3):133–43. PMID: 24958730. 10.1177/0969141314541109 24958730
6 Grobbee EJ, van der Vlugt M, van Vuuren AJ, . Diagnostic yield of one-time colonoscopy vs one-time flexible sigmoidoscopy vs multiple rounds of mailed fecal immunohistochemical tests in colorectal cancer screening. Clin Gastroenterol Hepatol. 2019;13:13. PMID: 31419575. 10.1016/j.cgh.2019.08.015 31419575
7 Regge D, Iussich G, Segnan N, . Comparing CT colonography and flexible sigmoidoscopy: a randomised trial within a population-based screening programme. Gut. 2017;66(8):1434–40. PMID: 27196588. 10.1136/gutjnl-2015-311278 27196588
8 Sali L, Mascalchi M, Falchini M, . Reduced and full-preparation CT colonography, fecal immunochemical test, and colonoscopy for population screening of colorectal cancer: a randomized trial. J Natl Cancer Inst. 2016;108(2). PMID: 26719225 10.1093/jnci/djv319 26719225
9 Stoop EM, de Haan MC, de Wijkerslooth TR, . Participation and yield of colonoscopy versus non-cathartic CT colonography in population-based screening for colorectal cancer: a randomised controlled trial. Lancet Oncol. 2012;13(1):55–64. PMID: 22088831. 10.1016/S1470-2045(11)70283-2 22088831
10 Segnan N, Senore C, Andreoni B, . Comparing attendance and detection rate of colonoscopy with sigmoidoscopy and FIT for colorectal cancer screening. Gastroenterology. 2007;132(7):2304–12. PMID: 17570205. 10.1053/j.gastro.2007.03.030 17570205
11 Quintero E, Castells A, Bujanda L, . Colonoscopy versus fecal immunochemical testing in colorectal-cancer screening. N Engl J Med. 2012;366(8):697–706. PMID: 22356323. 10.1056/NEJMoa1108895 22356323
12 Hol L, van Leerdam ME, van Balleooijen M, . Screening for colorectal cancer: randomised trial comparing guaiac-based and immunochemical faecal occult blood testing and flexible sigmoidoscopy. Gut. 2010;59(1):62–8. PMID: 19671542. 10.1136/gut.2009.177089 19671542
13 Segnan N, Senore C, Andreoni B, . Randomized trial of different screening strategies for colorectal cancer: patient response and detection rates. J Natl Cancer Inst. 2005;97(5):347–57. PMID: 15741571. 10.1093/jnci/dji050 15741571
14 Rasmussen M, Kronborg O, Fenger C, . Possible advantages and drawbacks of adding flexible sigmoidoscopy to hemoccult-II in screening for colorectal cancer. A randomized study. Scand J Gastroenterol. 1999;34(1):73–8. PMID: 10048736. 10.1080/00365529950172862 10048736
15 Verne JE, Aubrey R, Love SB, . Population based randomised study of uptake and yield of screening by flexible sigmoidoscopy compared with screening by faecal occult blood testing. BMJ. 1998;317. PMID: 9665902. 10.1136/bmj.317.7152.182 9665902
16 Berry DP, Clarke P, Hardcastle JD, . Randomized trial of the addition of flexible sigmoidoscopy to faecal occult blood testing for colorectal neoplasia population screening. Br J Surg. 1997;84(9):1274–6. PMID: 9313712.9313712
17 Brevinge H, Lindholm E, Buntzen S, . Screening for colorectal neoplasia with faecal occult blood testing compared with flexible sigmoidoscopy directly in a 55–56 years’ old population. Int J Colorectal Dis. 1997;12(5):291–5. PMID: 9401844. 10.1007/s003840050108 9401844
18 Schreuders EH, Grobbee EJ, Nieuwenburg SA, . Multiple rounds of one sample versus two sample faecal immunochemical test-based colorectal cancer screening: a population-based study. Lancet Gastroenterol Hepatol. 2019;4(8):622–631. PMID: 31196734. 10.1016/S2468-1253(19)30176-1 31196734
19 Passamonti B, Malaspina M, Fraser CG, . A comparative effectiveness trial of two faecal immunochemical tests for haemoglobin (FIT). Assessment of test performance and adherence in a single round of a population-based screening programme for colorectal cancer. Gut. 2018;67(3):485–96. PMID: 27974550. 10.1136/gutjnl-2016-312716 27974550
20 Santare D, Kojalo I, Liepniece-Karele I, . Comparison of the yield from two faecal immunochemical tests at identical cutoff concentrations - a randomized trial in Latvia. Eur J Gastroenterol Hepatol. 2016;28(8):904–10. PMID: 27120388. 10.1097/MEG.0000000000000650 27120388
21 Zubero MB, Arana-Arri E, Pijoan JI, . Population-based colorectal cancer screening: comparison of two fecal occult blood test. Front Pharmacol. 2014;4:175. PMID: 24454288. 10.3389/fphar.2013.00175 24454288
22 van Roon AH, Goede SL, van Balleooijen M, . Random comparison of repeated faecal immunochemical testing at different intervals for population-based colorectal cancer screening. Gut. 2013;62(3):409–15. PMID: 22387523. 10.1136/gutjnl-2011-301583 22387523
23 van Rossum LG, van Rijn AF, Laheij RJ, . Random comparison of guaiac and immunochemical fecal occult blood tests for colorectal cancer in a screening population. Gastroenterology. 2008;135(1):82–90. PMID: 18482589. 10.1053/j.gastro.2008.03.040 18482589
24 Faivre J, Dancourt V, Lejeune C, . Reduction in colorectal cancer mortality by fecal occult blood screening in a French controlled study. Gastroenterology. 2004;126(7):1674–80. PMID: 15188160. 10.1053/j.gastro.2004.02.018 15188160
25 Allison J, Tekawa IS, Ransom LJ, . A comparison of fecal occult-blood tests for colorectal-cancer screening. N Engl J Med. 1996;334(3):155–9. PMID: 8531970. 10.1056/NEJM199601183340304 8531970
26 Allison JE, Sakoda LC, Levin TR, . Screening for colorectal neoplasms with new fecal occult blood tests: update on performance characteristics. J Natl Cancer Inst. 2007;99(19):1462–70. PMID: 17895475. 10.1093/jnci/djm150 17895475
27 Arana-Arri E, Idigoras I, Uranga B, . Population-based colorectal cancer screening programmes using a faecal immunochemical test: should faecal haemoglobin cut-offs differ by age and sex? BMC Cancer. 2017;17(1):577. PMID: 28851318. 10.1186/s12885-017-3555-3 28851318
28 Castiglione G, Visioli CB, Ciatto S, . Sensitivity of latex agglutination faecal occult blood test in the Florence District population-based colorectal cancer screening programme. Br J Cancer. 2007;96(11):1750–4. PMID: 17453007. 10.1038/sj.bjc.6603759 17453007
29 Chen LS, Yen AM, Chiu SY, . Baseline faecal occult blood concentration as a predictor of incident colorectal neoplasia: longitudinal follow-up of a Taiwanese population-based colorectal cancer screening cohort. Lancet Oncol. 2011;12(6):551–8. PMID: 21592859. 10.1016/S1470-2045(11)70101-2 21592859
30 Chen CH, Wen CP, Tsai MK. Fecal immunochemical test for colorectal cancer from a prospective cohort with 513,283 individuals: providing detailed number needed to scope (NNS) before colonoscopy. Medicine (Baltimore). 2016;95(36):e4414. PMID: 27603337. 10.1097/MD.0000000000004414 27603337
31 Chen SL, Hsu CY, Yen AM, . Demand for colonoscopy in colorectal cancer screening using a quantitative fecal immunochemical test and age/sex-specific thresholds for test positivity. Cancer Epidemiol Biomarkers Prev. 2018;27(6):704–9. PMID: 29593012. 10.1158/1055-9965.EPI-17-0387 29593012
32 Garcia M, Domenech X, Vidal C, . Interval cancers in a population-based screening program for colorectal cancer in catalonia, Spain. Gastroenterol Res Pract. 2015;2015:672410. PMID: 25802515. 10.1155/2015/672410 25802515
33 Haug U, Grobbee EJ, Lansdorp-Vogelaar I, . Immunochemical faecal occult blood testing to screen for colorectal cancer: can the screening interval be extended? Gut. 2017;66(7):1262–7. PMID: 27006184. 10.1136/gutjnl-2015-310102 27006184
34 Itoh M, Takahashi K, Nishida H, . Estimation of the optimal cut off point in a new immunological faecal occult blood test in a corporate colorectal cancer screening programme. J Med Screen. 1996;3(2):66–71. PMID: 8849762. 10.1177/096914139600300204 8849762
35 Juul JS, Andersen B, Laurberg S, . Differences in diagnostic activity in general practice and findings for individuals invited to the danish screening programme for colorectal cancer: a population-based cohort study. Scand J Prim Health Care. 2018;36(3):281–90. PMID: 29929415. 10.1080/02813432.2018.1487378 29929415
36 Launoy GD, Bertrand HJ, Berchi C, . Evaluation of an immunochemical fecal occult blood test with automated reading in screening for colorectal cancer in a general average-risk population. Int J Cancer. 2005;115(3):493–6. PMID: 15700317. 10.1002/ijc.20921 15700317
37 Levi Z, Birkenfeld S, Vilkin A, . A higher detection rate for colorectal cancer and advanced adenomatous polyp for screening with immunochemical fecal occult blood test than guaiac fecal occult blood test, despite lower compliance rate. A prospective, controlled, feasibility study. Int J Cancer. 2011;128(10):2415–24. PMID: 20658527. 10.1002/ijc.25574 20658527
38 Mlakar DN, Bric TK, Skrjanec AL, . Interval cancers after negative immunochemical test compared to screen and non-responders’ detected cancers in Slovenian colorectal cancer screening programme. Radiol Oncol. 2018;52(4):413–21. PMID: 30511936. 10.2478/raon-2018-0025 30511936
39 Nakama H, Kamijo N, Abdul Fattah AS, . Validity of immunological faecal occult blood screening for colorectal cancer: a follow up study. J Med Screen. 1996;3(2):63–5. PMID: 8849761. 10.1177/096914139600300203 8849761
40 Selby K, Jensen CD, Lee JK, . Influence of varying quantitative fecal immunochemical test positivity thresholds on colorectal cancer detection: a community-based cohort study. Ann Intern Med. 2018;169(7):439–47. PMID: 30242328. 10.7326/M18-0244 30242328
41 Stegeman I, van Doorn SC, Mundt MW, . Participation, yield, and interval carcinomas in three rounds of biennial FIT-based colorectal cancer screening. Cancer Epidemiol. 2015;39(3):388–93. PMID: 25910865. 10.1016/j.canep.2015.03.012 25910865
42 Toes-Zoutendijk E, Kooyker AI, Dekker E, . Incidence of interval colorectal cancer after negative results from first-round fecal immunochemical screening tests, by cutoff value and participant sex and age. Clin Gastroenterol Hepatol. 2019;20:20. PMID: 31442598. 10.1016/j.cgh.2019.08.021 31442598
43 van der Vlugt M, Grobbee EJ, Bossuyt PM, . Interval colorectal cancer incidence among subjects undergoing multiple rounds of fecal immunochemical testing. Gastroenterology. 2017;153(2):439–47.e2. PMID: 28483499. 10.1053/j.gastro.2017.05.004 28483499
44 Grossberg LB, Papamichael K, Leffler DA, . Patients over age 75 are at increased risk of emergency department visit and hospitalization following colonoscopy. Dig Dis Sci. 2019;29:29. PMID: 31784850. 10.1007/s10620-019-05962-3 31784850
45 Wang P, Xu T, Ngamruengphong S, . Rates of infection after colonoscopy and osophagogastroduodenoscopy in ambulatory surgery centres in the USA. Gut. 2018;67(9):1626–36. PMID: 29777042. 10.1136/gutjnl-2017-315308 29777042
46 Zwink N, Holleczek B, Stegmaier C, . Complication rates in colonoscopy screening for cancer. Dtsch Arztebl Int. 2017;114(18):321–7. PMID: 28587708. 10.3238/arztebl.2017.0321 28587708
47 Zafar HM, Harhay MO, Yang J, . Adverse events following computed tomographic colonography compared to optical colonoscopy in the elderly. Prev Med Rep. 2014;1:3–8. PMID: 25530940.25530940
48 Pox CP, Altenhofen L, Brenner H, . Efficacy of a nationwide screening colonoscopy program for colorectal cancer. Gastroenterology. 2012;142(7):1460–7. PMID: 22446606.22446606
49 Rutter CM, Johnson E, Miglioretti DL, . Adverse events after screening and follow-up colonoscopy. Cancer Causes Control. 2012;23(2):289–96. PMID: 22105578.22105578
50 Ferlitsch M, Reinhart K, Pramhas S, . Sex-specific prevalence of adenomas, advanced adenomas, and colorectal cancer in individuals undergoing screening colonoscopy. JAMA. 2011;306(12):1352–8. PMID: 21954479.21954479
51 Crispin A, Birkner B, Munte A, . Process quality and incidence of acute complications in a series of more than 230,000 outpatient colonoscopies. Endoscopy. 2009;41(12):1018–25. PMID: 19856246. 10.1055/s-0029-1215214 19856246
52 Warren JL, Klabunde CN, Mariotto AB, . Adverse events after outpatient colonoscopy in the Medicare population. Ann Intern Med. 2009;150(12):849–57. PMID: 19528563.19528563
53 Chukmaitov A, Dahman B, Bradley CJ. Outpatient facility volume, facility type, and the risk of serious colonoscopy-related adverse events in patients with comorbid conditions: a population-based study. Int J Colorectal Dis. 2019;34(7):1203–10. PMID: 31093737. 10.1007/s00384-019-03304-3 31093737
54 Laanani M, Coste J, Blotiere PO, . Patient, procedure, and endoscopist risk factors for perforation, bleeding, and splenic injury after colonoscopies. Clin Gastroenterol Hepatol. 2019;17(4):719–727.e13. PMID: 30099110. 10.1016/j.cgh.2018.08.005 30099110
55 Thulin T, Hammar U, Ekbom A, . Perforations and bleeding in a population-based cohort of all registered colonoscopies in Sweden from 2001 to 2013. United European Gastroenterol. 2019;7(1):130–7. PMID: 30788125. 10.1177/2050640618809782 30788125
56 Forsberg A, Hammar U, Ekbom A, . A register-based study: adverse events in colonoscopies performed in Sweden 2001–2013. Scand J Gastroenterol. 2017;52(9):1042–7. PMID: 28562115. 10.1080/00365521.2017.1334812 28562115
57 Garcia-Albeniz X, Hsu J, Bretthauer M, . Effectiveness of screening colonoscopy to prevent colorectal cancer among Medicare beneficiaries aged 70 to 79 years: a prospective observational study. Ann Intern Med. 2017;166(1):18–26. PMID: 27669524. 10.7326/M16-0758 27669524
58 Johnson CD, Fletcher JG, MacCarty RL, . Effect of slice thickness and primary 2D versus 3D virtual dissection on colorectal lesion detection at CT colonography in 452 asymptomatic adults. AJR Am J Roentgenol. 2007;189(3):672–80. PMID: 17715116. 10.1148/radiol.12102177 17715116
59 Adeyemo A, Bannazadeh M, Riggs T, . Does sedation type affect colonoscopy perforation rates? Dis Colon Rectum. 2014;57(1):110–4. PMID: 24316954. 10.1097/DCR.0000000000000002 24316954
60 Bielawska B, Day AG, Lieberman DA, . Risk factors for early colonoscopic perforation include non-gastroenterologist endoscopists: a multivariable analysis. Clin Gastroenterol Hepatol. 2014;12(1):85–92. PMID: 23891916. 10.1016/j.cgh.2013.06.030 23891916
61 Blotiere PO, Weill A, Ricordeau P, . Perforations and haemorrhages after colonoscopy in 2010: a study based on comprehensive French health insurance data (SNIIRAM). Clin Res Hepatol Gastroenterol. 2014;38(1):112–7. PMID: 24268997. 10.1016/j.clinre.2013.10.005 24268997
62 Chukmaitov A, Bradley CJ, Dahman B, . Association of polypectomy techniques, endoscopist volume, and facility type with colonoscopy complications. Gastrointest Endosc. 2013;77(3):436–46. PMID: 23290773.23290773
63 Cooper GS, Kou TD, Rex DK. Complications following colonoscopy with anesthesia assistance: a population-based analysis. JAMA Intern Med. 2013;173(7):551–6. PMID: 23478904. 10.1001/jamainternmed.2013.2908 23478904
64 Hamdani U, Naeem R, Haider F, . Risk factors for colonoscopic perforation: a population-based study of 80118 cases. World J Gastroenterol. 2013;19(23):3596–601. PMID: 23801860.23801860
65 Ko CW, Riffle S, Michaels L, . Serious complications within 30 days of screening and surveillance colonoscopy are uncommon. Clin Gastroenterol Hepatol. 2010;8(2):166–73. PMID: 19850154.19850154
66 Arora G, Mannalithara A, Singh G, . Risk of perforation from a colonoscopy in adults: a large population-based study. Gastrointest Endosc. 2009;69(3 Pt 2):654–64. PMID: 19251006. 10.1016/j.gie.2008.09.008 19251006
67 Rabeneck L, Paszat LF, Hilsden RJ, . Bleeding and perforation after outpatient colonoscopy and their risk factors in usual clinical practice. Gastroenterology. 2008;135(6):1899–906. PMID: 18938166.18938166
68 Levin TR, Zhao W, Conell C, . Complications of colonoscopy in an integrated health care delivery system. Ann Intern Med. 2006;145(12):880–6. PMID: 17179057.17179057
69 Rathgaber SW, Wick TM. Colonoscopy completion and complication rates in a community gastroenterology practice. Gastrointest Endosc. 2006;64(4):556–62. PMID: 16996349.16996349
70 Brenner H, Tao S. Superior diagnostic performance of faecal immunochemical tests for haemoglobin in a head-to-head comparison with guaiac based faecal occult blood test among 2235 participants of screening colonoscopy. Eur J Cancer. 2013;49(14):3049–54. PMID: 23706981. 10.1016/j.ejca.2013.04.023 23706981
71 Chang LC, Shun CT, Hsu WF, . Fecal immunochemical test detects sessile serrated adenomas and polyps with a low level of sensitivity. Clin Gastroenterol Hepatol. 2017;15(6):872–9.e1. PMID: 27498176. 10.1016/j.cgh.2016.07.029 27498176
72 Chiu HM, Ching JY, Wu KC, . A risk-scoring system combined with a fecal immunochemical test is effective in screening high-risk subjects for early colonoscopy to detect advanced colorectal neoplasms. Gastroenterology. 2016;150(3):617–25.e3. PMID: 26627608. 10.1053/j.gastro.2015.11.042 26627608
73 Cooper GS, Markowitz SD, Chen Z, . Performance of multitarget stool DNA testing in African American patients. Cancer. 2018;124(19):3876–80. PMID: 30193399. 10.1002/cncr.31660 30193399
74 de Wijkerslooth TR, Stoop EM, Bossuyt PM, . Immunochemical fecal occult blood testing is equally sensitive for proximal and distal advanced neoplasia. Am J Gastroenterol. 2012;107(10):1570–8. PMID: 22850431. 10.1038/ajg.2012.249 22850431
75 Hernandez V, Cubiella J, Gonzalez-Mao MC, . Fecal immunochemical test accuracy in average-risk colorectal cancer screening. World J Gastroenterol. 2014;20(4):1038–47. PMID: 24574776. 10.3748/wjg.v20.i4.1038 24574776
76 Imperiale TF, Ransohoff DF, Itzkowitz SH, . Multitarget stool DNA testing for colorectal-cancer screening. N Engl J Med. 2014;370(14):1287–97. PMID: 24645800. 10.1056/NEJMoa1311194 24645800
77 Kim NH, Park JH, Park DI, . The fecal immunochemical test has high accuracy for detecting advanced colorectal neoplasia before age 50. Dig Liver Dis. 2017;49(5):557–61. PMID: 28065631. 10.1016/j.dld.2016.12.020 28065631
78 Liles EG, Perrin N, Rosales AG, . Performance of a quantitative fecal immunochemical test for detecting advanced colorectal neoplasia: a prospective cohort study. BMC Cancer. 2018;18(1):509. PMID: 29720130. 10.1186/s12885-018-4402-x 29720130
79 Park DI, Ryu S, Kim YH, . Comparison of guaiac-based and quantitative immunochemical fecal occult blood testing in a population at average risk undergoing colorectal cancer screening. Am J Gastroenterol. 2010;105(9):2017–25. PMID: 20502450. 10.1038/ajg.2010.179 20502450
80 Redwood DG, Asay ED, Blake ID, . Stool DNA testing for screening detection of colorectal neoplasia in Alaska Native people. Mayo Clin Proc. 2016;91(1):61–70. PMID: 26520415. 10.1016/j.mayocp.2015.10.008 26520415
81 Shapiro JA, Bobo JK, Church TR, . A comparison of fecal immunochemical and high-sensitivity guaiac tests for colorectal cancer screening. Am J Gastroenterol. 2017;112(11):1728–35. PMID: 29016558. 10.1038/ajg.2017.285 29016558
82 Ladabaum U, Mannalithara A, Meester RG, . Cost-effectiveness and national effects of initiating colorectal cancer screening for average-risk persons at age 45 years instead of 50 years. Gastroenterology. 2019;157(1):137–148. PMID: 30930021.30930021
83 Lew JB, St John DJ, Macrae FA, . Benefits, harms, and cost-effectiveness of potential age extensions to the National Bowel Cancer Screening Program in Australia. Cancer Epidemiol Biomarkers Prev. 2018;27(12):1450–61. PMID: 30190276. 10.1158/1055-9965.EPI-18-0128 30190276
84 D’Andrea E, Ahnen DJ, Sussman DA, . Quantifying the impact of adherence to screening strategies on colorectal cancer incidence and mortality. Cancer Med. 2020;9(2):824–36. PMID: 31777197. 10.1002/cam4.2735 31777197
85 Ran T, Cheng CY, Misselwitz B, . Cost-effectiveness of colorectal cancer screening strategies-a systematic review. Clin Gastroenterol Hepatol. 2019;17(10):1969–1981.e15. PMID: 30659991. 10.1016/j.cgh.2019.01.014 30659991
86 Lansdorp-Vogelaar I, Knudsen AB, Brenner H. Cost-effectiveness of colorectal cancer screening. Epidemiol Rev. 2011;33:88–100. PMID: 21633092. 10.1093/epirev/mxr004 21633092
87 Senore C, Correale L, Regge D, . Flexible sigmoidoscopy and CT colonography screening: patients’ experience with and factors for undergoing screening-insight from the Proteus Colon Trial. Radiology. 2018;286(3):873–83. PMID: 29040021. 10.1148/radiol.2017170228 29040021
88 Berger BM, Schroy PC, 3rd, Dinh TA. Screening for colorectal cancer using a multitarget stool DNA Test: modeling the effect of the intertest interval on clinical effectiveness. Clin Colorectal Cancer. 2016;15(3):e65–74. PMID: 26792032. 10.1016/j.clcc.2015.12.003 26792032
89 Ladabaum U, Levin Z, Mannalithara A, . Colorectal testing utilization and payments in a large cohort of commercially insured US adults. Am J Gastroenterol. 2014;109(10):1513–25. PMID: 24980877. 10.1038/ajg.2014.64 24980877
90 de Moor JS, Cohen RA, Shapiro JA, . Colorectal cancer screening in the United States: trends from 2008 to 2015 and variation by health insurance coverage. Prev Med. 2018;112:199–206. PMID: 29729288. 10.1016/j.ypmed.2018.05.001 29729288
91 Selby K, Baumgartner C, Levin TR, . Interventions to improve follow-up of positive results on fecal blood tests: a systematic review. Ann Intern Med. 2017;167(8):565–75. PMID: 29049756. 10.7326/M17-1361 29049756
92 Navarro M, Nicolas A, Ferrandez A, . Colorectal cancer population screening programs worldwide in 2016: an update. World J Gastroenterol. 2017;23(20):3632–42. PMID: 28611516. 10.3748/wjg.v23.i20.3632 28611516
93 Bretagne JF, Piette C, Cosson M, . Switching from guaiac to immunochemical faecal occult blood test increases participation and diagnostic yield of colorectal cancer screening. Dig Liver Dis. 2019;51(10):1461–9. 10.1016/j.dld.2019.05.004 31151896
94 Joseph DA, King JB, Richards TB, . Use of colorectal cancer screening tests by state. Prev Chronic Dis. 2018;15:E80. PMID: 29908051. 10.5888/pcd15.170535 29908051
95 Centers for Disease Control and Prevention. Quick Facts: Colorectal Cancer Screening in the U.S. Behavioral Risk Surveillance System - 2016. https://www.cdc.gov/cancer/colorectal/pdf/QuickFacts-BRFSS-2016-CRC-Screening-508.pdf. Accessed 28 May, 2019.
96 White A, Thompson TD, White MC, . Cancer screening test use - United States, 2015. MMWR Morb Mortal Wkly Rep. 2017;66(8):201–6. PMID: 28253225. 10.15585/mmwr.mm6608a1 28253225
97 Shaukat A, Mongin SJ, Geisser MS, . Long-term mortality after screening for colorectal cancer. N Engl J Med. 2013;369(12):1106–14. PMID: 24047060. 10.1056/NEJMoa1300720 24047060
98 Lin JS, Piper MA, Perdue LA, . Screening for Colorectal Cancer: A Systematic Review for the US Preventive Services Task Force: Evidence Synthesis No. 135. Rockville (MD): Agency for Healthcare Research and Quality; 2016. PMID: 2744132827441328.
99 Khalid-de Bakker C, Jonkers D, Smits K, . Participation in colorectal cancer screening trials after first-time invitation: a systematic review. Endoscopy. 2011;43(12):1059–86. PMID: 22135196. 10.1055/s-0031-1291430 22135196
100 Holden DJ, Jonas DE, Porterfield DS, . Systematic review: enhancing the use and quality of colorectal cancer screening. Ann Intern Med. 2010;152(10):668–76. PMID: 20388703.20388703
101 Akram A, Juang D, Bustamante R, . Replacing the guaiac fecal occult blood test with the fecal immunochemical test increases proportion of individuals screened in a large healthcare setting. Clin Gastroenterol Hepatol. 2017;15(8):1265–70.e1. PMID: 28167157. 10.1016/j.cgh.2017.01.025 28167157
102 Binefa G, Garcia M, Mila N, . Colorectal cancer screening programme in Spain: results of key performance indicators after five rounds (2000–2012). Sci Rep. 2016;6:19532. PMID: 26787510. 10.1038/srep19532 26787510
103 Idigoras I, Arrospide A, Portillo I, . Evaluation of the colorectal cancer screening programme in the Basque Country (Spain) and its effectiveness based on the Miscan-colon model. BMC Public Health. 2017;18(1):78. PMID: 28764731. 10.1186/s12889-017-4639-3 28764731
104 Weiser E, Parks PD, Swartz RK, . Cross-sectional adherence with the multi-target stool DNA test for colorectal cancer screening: real-world data from a large cohort of older adults. J Med Screen. 2020:969141320903756. PMID: 32054393. 10.1177/0969141320903756 32054393
105 Prince M, Lester L, Chiniwala R, . Multitarget stool DNA tests increases colorectal cancer screening among previously noncompliant Medicare patients. World J Gastroenterol. 2017;23(3):464–71. PMID: 28210082. 10.3748/wjg.v23.i3.464 28210082
106 Liles E, Coronado G, Perrin N, . Uptake of a colorectal cancer screening blood test is higher than of a fecal test offered in clinic: a randomized trial. Cancer treatment and research communications [serial on the Internet]. 2017 [cited Search 1 - CENTRAL; 10: Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01432189/full.
107 Symonds EL, Hughes D, Flight I, . A randomized controlled trial testing provision of fecal and blood test options on participation for colorectal cancer screening. Cancer Prev Res (Phila). 2019;12(9):631–40. 10.1158/1940-6207.CAPR-19-0089 31266825
108 Murphy CC, Sigel BM, Yang E, . Adherence to colorectal cancer screening measured as the proportion of time covered. Gastrointest Endosc. 2018;88(2):323–31.e2. PMID: 29477302. 10.1016/j.gie.2018.02.023 29477302
109 Cyhaniuk A, Coombes ME. Longitudinal adherence to colorectal cancer screening guidelines. Am J Manag Care. 2016;22(2):105–11.26885670
110 Liang PS, Wheat CL, Abhat A, . Adherence to competing strategies for colorectal cancer screening over 3 years. Am J Gastroenterol. 2016;111(1):105–14. PMID: 26526080. 10.1038/ajg.2015.367 26526080
111 Gellad ZF, Stechuchak KM, Fisher DA, . Longitudinal adherence to fecal occult blood testing impacts colorectal cancer screening quality. Am J Gastroenterol. 2011;106(6):1125–34. PMID: 21304501. 10.1038/ajg.2011.11 21304501
112 Murphy CC, Sandler RS, Grubber JM, . Underuse and overuse of colonoscopy for repeat screening and surveillance in the Veterans Health Administration. Clin Gastroenterol Hepatol. 2016;14(3):436–44.e1. PMID: 26492843. 10.1016/j.cgh.2015.10.008 26492843
113 Hol L, Sutradhar R, Gu S, . Repeat colonoscopy after a colonoscopy with a negative result in Ontario: a population-based cohort study. CMAJ Open. 2015;3(2):E244–50. PMID: 26389103. 10.9778/cmajo.20140063 26389103
114 Murphy CC, Sen A, Watson B, . A systematic review of repeat fecal occult blood tests for colorectal cancer screening. Cancer Epidemiol Biomarkers Prev. 2020;29(2):278–87. PMID: 31740521. 10.1158/1055-9965.EPI-19-0775 31740521
115 Mysliwiec PA, Jensen CD, Zhao W, . 120 Fecal immunochemical test performance over multiple rounds of annual testing in an outreach screening program. Gastroenterology. 2014;146(5):S33–4. 10.1016/S0016-5085(14)60115-3
116 Nielson CM, Vollmer WM, Petrik AF, . Factors affecting adherence in a pragmatic trial of annual fecal immunochemical testing for colorectal cancer. J Gen Intern Med. 2019;34(6):978–985. PMID: 30684199. 10.1007/s11606-018-4820-0 30684199
117 Jensen CD, Corley DA, Quinn VP, . Fecal immunochemical test program performance over 4 rounds of annual screening: a retrospective cohort study. Ann Intern Med. 2016;164(7):456–63. PMID: 26811150. 10.7326/M15-0983 26811150
118 Fenton JJ, Elmore JG, Buist DS, . Longitudinal adherence with fecal occult blood test screening in community practice. Ann Fam Med. 2010;8(5):397–401. PMID: 20843880. 10.1370/afm.1133 20843880
119 Lo SH, Halloran S, Snowball J, . Colorectal cancer screening uptake over three biennial invitation rounds in the English bowel cancer screening programme. Gut. 2015;64(2):282–91. PMID: 24812001. 10.1136/gutjnl-2013-306144 24812001
120 Knudsen MD, Berstad P, Hjartaker A, . Lifestyle predictors for non-participation and outcome in the second round of faecal immunochemical test in colorectal cancer screening. Br J Cancer. 2017;117(4):461–9. PMID: 28704841. 10.1038/bjc.2017.189 28704841
121 Denis B, Gendre I, Perrin P. Participation in four rounds of a French colorectal cancer screening programme with guaiac faecal occult blood test: a population-based open cohort study. J Med Screen. 2015;22(2):76–82. PMID: 25576338. 10.1177/0969141314567795 25576338
122 Koivogui A, Le Mab G, Benamouzig R. Detection of colorectal neoplasia in a cohort before and after the change of fecal occult blood test in a French colorectal cancer screening program. Am J Gastroenterol. 2018;113(12):1891–9. PMID: 30337703. 10.1038/s41395-018-0367-2 30337703
123 Osborne JM, Wilson C, Duncan A, . Patterns of participation over four rounds of annual fecal immunochemical test-based screening for colorectal cancer: what predicts rescreening? BMC Public Health. 2017;18(1):81. PMID: 28764667. 10.1186/s12889-017-4634-8 28764667
124 Telford J, Gentile L, Gondara L, . Performance of a quantitative fecal immunochemical test in a colorectal cancer screening pilot program: a prospective cohort study. CMAJ Open. 2016;4(4):E668–E73. PMID: 28018880. 10.9778/cmajo.20160047 28018880
125 Zorzi M, Hassan C, Capodaglio G, . Long-term performance of colorectal cancerscreening programmes based on the faecal immunochemical test. Gut. 2018;67(12):2124–30. PMID: 29101260. 10.1136/gutjnl-2017-314753 29101260
126 Singal AG, Corley DA, Kamineni A, . Patterns and predictors of repeat fecal immunochemical and occult blood test screening in four large health care systems in the United States. Am J Gastroenterol. 2018;113(5):746–54. PMID: 29487413. 10.1038/s41395-018-0023-x 29487413
127 Zauber AG, Winawer SJ, Mills GM, . 351 adherence to screening in a randomized controlled trial of a one-time screening colonoscopy versus program of annual fecal occult blood test (gFOBt): implications of lower gFOBt adherence to screening on colorectal cancer mortality reduction. Gastroenterology. 2012;142(5):S82–3. 10.1016/S0016-5085(12)60312-6
128 Zhao G, Okoro CA, Li J, . Health insurance status and clinical cancer screenings among U.S. Adults. Am J Prev Med. 2018;54(1):e11–9. PMID: 29102459. 10.1016/j.amepre.2017.08.024 29102459
129 Cooper GS, Kou TD, Schluchter MD, . Changes in receipt of cancer screening in Medicare beneficiaries following the Affordable Care Act. J Natl Cancer Inst. 2016;108(5):djv374. PMID: 26640244. 10.1093/jnci/djv374 26640244
130 Ramai D, Etienne D, Ayide G, . Individual and geospatial characteristics associated with use and nonuse of the fecal immunochemical test (FIT) for colorectal cancer screening in an urban minority population. J Clin Gastroenterol. 2019;53(10):744–749. PMID: 30222644. 10.1097/mcg.0000000000001132 30222644
131 Chatterjee S, Chattopadhyay A, Levine PH. Between-ward disparities in colorectal cancer incidence and screening in Washington DC. J Epidemiol Glob Health. 2015;5(4 Suppl 1):S1–9. PMID: 26344423. 10.1016/j.jegh.2015.08.001 26344423
132 Davis MM, Renfro S, Pham R, . Geographic and population-level disparities in colorectal cancer testing: a multilevel analysis of Medicaid and commercial claims data. Prev Med. 2017;101:44–52. PMID: 28506715. 10.1016/j.ypmed.2017.05.001 28506715
133 Bernardo BM, Gross AL, Young G, . Predictors of colorectal cancer screening in two underserved U.S. populations: a parallel analysis. Front Oncol. 2018;8:230. PMID: 29971216. 10.3389/fonc.2018.00230 29971216
134 Berkowitz Z, Zhang X, Richards TB, . Multilevel small-area estimation of colorectal cancer screening in the United States. Cancer Epidemiol Biomarkers Prev. 2018;27(3):245–53. PMID: 29500250. 10.1158/1055-9965.EPI-17-0488 29500250
135 Dolan JG, Boohaker E, Allison J, . Can streamlined multicriteria decision analysis be used to implement shared decision making for colorectal cancer screening? Med Decis Making. 2014;34(6):746–55. PMID: 24300851. 10.1177/0272989X13513338 24300851
136 Honein-AbouHaidar GN, Kastner M, Vuong V, . Systematic review and meta-study synthesis of qualitative studies evaluating facilitators and barriers to participation in colorectal cancer screening. Cancer Epidemiol Biomarkers Prev. 2016;25(6):907–17. PMID: 27197277. 10.1158/1055-9965.EPI-15-0990 27197277
137 Rogers CR, Goodson P, Foster MJ. Factors associated with colorectal cancer screening among younger African American men: a systematic review. J Health Dispar Res Pract. 2015;8(3):133–56. PMID: 26435888.26435888
138 Roh S, Burnette CE, Lee KH, . Correlates of receipt of colorectal cancer screening among American Indians in the Northern Plains. Soc Work Res. 2016;40(2):95–104. PMID: 27257363. 10.1093/swr/svw006 27257363
139 Bromley EG, May FP, Federer L, . Explaining persistent under-use of colonoscopic cancer screening in African Americans: a systematic review. Prev Med. 2015;71:40–8. PMID: 25481094. 10.1016/j.ypmed.2014.11.022 25481094
140 Lee E, Natipagon-Shah B, Sangsanoi-Terkchareon S, . Factors influencing colorectal cancer screening among Thais in the U.S. J Community Health. 2019;44(2):230–237. PMID: 30341745. 10.1007/s10900-018-0578-x 30341745
141 Halm EA, Beaber EF, McLerran D, . Association between primary care visits and colorectal cancer screening outcomes in the era of population health outreach. J Gen Intern Med. 2016;31(10):1190–7. PMID: 27279097. 10.1007/s11606-016-3760-9 27279097
142 Sy AU, Lim E, Ka’opua LS, . Colorectal cancer screening prevalence and predictors among Asian American subgroups using Medical Expenditure Panel Survey National Data. Cancer. 2018;124(Suppl 7):1543–51. PMID: 29578602. 10.1002/cncr.31098 29578602
143 Burnett-Hartman AN, Mehta SJ, Zheng Y, . Racial/ethnic disparities in colorectal cancer screening across healthcare systems. Am J Prev Med. 2016;51(4):e107–15. PMID: 27050413. 10.1016/j.amepre.2016.02.025 27050413
144 Fedewa SA, Corley DA, Jensen CD, . Colorectal cancer screening initiation after age 50 years in an organized program. Am J Prev Med. 2017;53(3):335–44. PMID: 28427954. 10.1016/j.amepre.2017.02.018 28427954
145 Burgess DJ, van Ryn M, Grill J, . Presence and correlates of racial disparities in adherence to colorectal cancer screening guidelines. J Gen Intern Med. 2011;26(3):251–8. PMID: 21088920. 10.1007/s11606-010-1575-7 21088920
146 National Cancer Institute. State Cancer Profiles. https://statecancerprofiles.cancer.gov. Accessed Juy 31, 2019.
147 American Cancer Society. Colorectal Cancer: Facts & Figures 2017–2019. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/colorectal-cancer-facts-and-figures/colorectal-cancer-facts-and-figures-2017-2019.pdf. Accessed July 30, 2019.
148 Clarke N, Sharp L, Osborne A, . Comparison of uptake of colorectal cancer screening based on fecal immunochemical testing (FIT) in males and females: a systematic review and meta-analysis. Cancer Epidemiol Biomarkers Prev. 2015;24(1):39–47. PMID: 25378366. 10.1158/1055-9965.EPI-14-0774 25378366
149 Tsai MH, Xirasagar S, Li YJ, . Colonoscopy screening among US adults aged 40 or older with a family history of colorectal cancer. Prev Chronic Dis. 2015;12:E80. PMID: 25996988. 10.5888/pcd12.140533 25996988
150 Waghray A, Jain A, Waghray N. Colorectal cancer screening in African Americans: practice patterns in the United States. Are we doing enough? Gastroenterol Rep (Oxf). 2016;4(2):136–40. PMID: 27071411. 10.1093/gastro/gow005 27071411
151 Henrikson NB, Webber EM, Goddard KA, . Family history and the natural history of colorectal cancer: systematic review. Genet Med. 2015;17(9):702. PMID: 25590981. 10.1038/gim.2014.188 25590981
152 Kerrison RS, von Wagner C, Green T, . Rapid review of factors associated with flexible sigmoidoscopy screening use. Prev Med. 2019;120:8–18. PMID: 30597228. 10.1016/j.ypmed.2018.12.018 30597228
153 Lowery JT, Ahnen DJ, Schroy PC, 3rd, . Understanding the contribution of family history to colorectal cancer risk and its clinical implications: a state-of-the-science review. Cancer. 2016;122(17):2633–45. PMID: 27258162. 10.1002/cncr.30080 27258162
154 Dougherty MK, Brenner AT, Crockett SD, . Evaluation of interventions intended to increase colorectal cancer screening rates in the united states: a systematic review and meta-analysis. JAMA Intern Med. 2018;178(12):1645–58. PMID: 30326005. 10.1001/jamainternmed.2018.4637 30326005
155 Issaka RB, Avila P, Whitaker E, . Population health interventions to improve colorectal cancer screening by fecal immunochemical tests: a systematic review. Prev Med. 2019;118:113–21. PMID: 30367972. 10.1016/j.ypmed.2018.10.021 30367972
156 Volk RJ, Linder SK, Lopez-Olivo MA, . Patient decision aids for colorectal cancer screening: a systematic review and meta-analysis. Am J Prev Med. 2016;51(5):779–91. PMID: 27593418. 10.1016/j.amepre.2016.06.022 27593418
157 Community Preventive Services Task Force. Increasing Colorectal Cancer Screening: Multicomponent Interventions. https://www.thecommunityguide.org/sites/default/files/assets/Cancer-Screening-Multicomponent-Colorectal.pdf. Accessed 1 Aug, 2019.
158 Corley DA, Jensen CD, Quinn VP, . Association between time to colonoscopy after a positive fecal test result and risk of colorectal cancer and cancer stage at diagnosis. JAMA. 2017;317(16):1631–41. PMID: 28444278. 10.1001/jama.2017.3634 28444278
159 Doubeni CA, Gabler NB, Wheeler CM, . Timely follow-up of positive cancer screening results: a systematic review and recommendations from the PROSPR Consortium. CA Cancer J Clin. 2018;68(3):199–216. PMID: 29603147. 10.3322/caac.21452 29603147
160 Chubak J, Garcia MP, Burnett-Hartman AN, . Time to colonoscopy after positive fecal blood test in four U.S. health care systems. Cancer Epidemiol Biomarkers Prev. 2016;25(2):344–50. PMID: 26843520. 10.1158/1055-9965.EPI-15-0470 26843520
161 Kapidzic A, van der Meulen MP, Hol L, . Gender differences in fecal immunochemical test performance for early detection of colorectal neoplasia. Clin Gastroenterol Hepatol. 2015;13(8):1464–71.e4. PMID: 25724706. 10.1016/j.cgh.2015.02.023 25724706
162 Partin MR, Gravely AA, Burgess JF, Jr., . Contribution of patient, physician, and environmental factors to demographic and health variation in colonoscopy follow-up for abnormal colorectal cancer screening test results. Cancer. 2017;123(18):3502–12. PMID: 28493543. 10.1002/cncr.30765 28493543
163 May FP, Yano EM, Provenzale D, . Barriers to follow-up colonoscopies for patients with positive results from fecal immunochemical tests during colorectal cancer screening. Clin Gastroenterol Hepatol. 2019;17(3):469–76. PMID: 29857147. 10.1016/j.cgh.2018.05.022 29857147
164 Liss DT, Brown T, Lee JY, . Diagnostic colonoscopy following a positive fecal occult blood test in community health center patients. Cancer Causes Control. 2016;27(7):881–7. PMID: 27228991. 10.1007/s10552-016-0763-0 27228991
165 Martin J, Halm EA, Tiro JA, . Reasons for lack of diagnostic colonoscopy after positive result on fecal immunochemical test in a safety-net health system. Am J Med. 2017;130(1):93.e1–7. PMID: 27591183. 10.1016/j.amjmed.2016.07.028 27591183
166 Alsayid M, Singh MH, Issaka R, . Yield of colonoscopy after a positive result from a fecal immunochemical test OC-Light. Clin Gastroenterol Hepatol. 2018;16(10):1593–7.e1. PMID: 29660528. 10.1016/j.cgh.2018.04.014 29660528
167 Issaka RB, Singh MH, Oshima SM, . Inadequate utilization of diagnostic colonoscopy following abnormal FIT results in an integrated safety-net system. Am J Gastroenterol. 2017;112(2):375–82. PMID: 28154400. 10.1038/ajg.2016.555 28154400
168 Gingold-Belfer R, Leibovitzh H, Boltin D, . The compliance rate for the second diagnostic evaluation after a positive fecal occult blood test: a systematic review and meta-analysis. United European Gastroenterol J. 2019;7(3):424–48. PMID: 31019712. 10.1177/2050640619828185 31019712
169 Finney Rutten LJ, Jacobson DJ, Jenkins GD, . Colorectal cancer screening completion: an examination of differences by screening modality. Prev Med Rep. 2020;20:101202. PMID: 32995145. 10.1016/j.pmedr.2020.101202 32995145
170 Eckmann JD, Ebner DW, Bering J, . Multitarget stool DNA screening in clinical practice: high positive predictive value for colorectal neoplasia regardless of exposure to previous colonoscopy. Am J Gastroenterol. 2020;115(4):608–15. PMID: 32068535. 10.14309/ajg.0000000000000546 32068535
171 Laiyemo AO, Doubeni C, Pinsky PF, . Race and colorectal cancer disparities: health-care utilization vs different cancer susceptibilities. J Natl Cancer Inst. 2010;102(8):538–46. PMID: 20357245. 10.1093/jnci/djq068 20357245
172 Nadel MR, Royalty J, Joseph D, . Variations in screening quality in a Federal colorectal cancer screening program for the uninsured. Prev Chronic Dis. 2019;16:E67. PMID: 31146803. 10.5888/pcd16.180452 31146803
173 Schoen RE, Pinsky PF, Weissfeld JL, . Colorectal-cancer incidence and mortality with screening flexible sigmoidoscopy. N Engl J Med. 2012;366(25):2345–57. PMID: 22612596. 10.1016/S2468-1253(18)30358-3 22612596
174 Scheuner MT, McNeel TS, Freedman AN. Population prevalence of familial cancer and common hereditary cancer syndromes. The 2005 California Health Interview Survey. Genet Med. 2010;12(11):726–35. PMID: 20921897. 10.1097/GIM.0b013e3181f30e9e 20921897
175 Roos VH, Mangas-Sanjuan C, Rodriguez-Girondo M, . Effects of family history on relative and absolute risks for colorectal cancer: a systematic review and meta-analysis. Clin Gastroenterol Hepatol. 2019;17(13):2657–67.e9. 10.1016/j.cgh.2019.09.007 31525516
176 Wong MC, Chan CH, Lin J, . Lower relative contribution of positive family history to colorectal cancer risk with increasing age: a systematic review and meta-analysis of 9.28 million individuals. Am J Gastroenterol. 2018;113(12):1819–27. PMID: 29867176. 10.1038/s41395-018-0075-y 29867176
177 Mitchell RJ, Brewster D, Campbell H, . Accuracy of reporting of family history of colorectal cancer. Gut. 2004;53(2):291–5. PMID: 14724166. 10.1136/gut.2003.027896 14724166
178 Qureshi N, Wilson B, Santaguida P, . Collection and use of cancer family history in primary care. Evid Rep Technol Assess (Full Rep). 2007(159):1–84. PMID: 18457477.18457477
179 Leddin D, Lieberman DA, Tse F, . Clinical practice guideline on screening for colorectal cancer in individuals with a family history of nonhereditary colorectal cancer or adenoma: the Canadian Association of Gastroenterology Banff Consensus. Gastroenterology. 2018;155(5):1325–1347.e3. PMID: 30121253. 10.1053/j.gastro.2018.08.017 30121253
180 Gupta S, Provenzale D, Llor X, . NCCN Guidelines Insights: genetic/familial high-risk assessment: colorectal, version 2.2019. J Natl Compr Canc Netw. 2019;17(9):1032–41. PMID: 31487681. 10.6004/jnccn.2019.0044 31487681
181 Rex DK, Boland CR, Dominitz JA, . Colorectal cancer screening: recommendations for physicians and patients from the U.S. Multi-Society Task Force on Colorectal Cancer. Am J Gastroenterol. 2017;112(7):1016–30. PMID: 28555630. 10.1038/ajg.2017.174 28555630
182 National Comprehensive Cancer Network (NCCN). NCCN Clinical Practice Guidelines in Oncology (NCCN Guidelines): Colorectal Cancer Screening. Version 2.2019 ed: National Comprehensive Cancer Network; 2019.
183 American Cancer Society. American Cancer Society Guideline for Colorectal Cancer Screening. http://www.cancer.org/cancer/colon-rectal-cancer/detection-diagnosis-staging/acs-recommendations.html. Accessed Dec 11, 2019.
184 Butterworth AS, Higgins JP, Pharoah P. Relative and absolute risk of colorectal cancer for individuals with a family history: a meta-analysis. Eur J Cancer. 2006;42(2):216–27. PMID: 16338133. 10.1016/j.ejca.2005.09.023 16338133
185 Tian Y, Kharazmi E, Sundquist K, . Familial colorectal cancer risk in half siblings and siblings: nationwide cohort study. BMJ. 2019;364:I803. PMID: 30872356. 10.1136/bmj.l803 30872356
186 Tian Y, Kharazmi E, Brenner H, . Calculating the starting age for screening in relatives of patients with colorectal cancer based on data from large nationwide data sets. Gastroenterology. 2020;159(1):159–68.e3. PMID: 32251666. 10.1053/j.gastro.2020.03.063 32251666
187 Schoen RE, Razzak A, Yu KJ, . Incidence and mortality of colorectal cancer in individuals with a family history of colorectal cancer. Gastroenterology. 2015;149(6):1438–45.e1. PMID: 26255045. 10.1053/j.gastro.2015.07.055 26255045
188 Miller EA, Pinsky PF, Schoen RE, . Effect of flexible sigmoidoscopy screening on colorectal cancer incidence and mortality: long-term follow-up of the randomised US PLCO cancer screening trial. Lancet Gastroenterol Hepatol. 2019;4(2):101–10. PMID: 30502933. 10.1016/S2468-1253(18)30358-3 30502933
189 Segnan N, Armaroli P, Bonelli L, . Once-only sigmoidoscopy in colorectal cancer screening: follow-up findings of the Italian Randomized Controlled Trial--SCORE. J Natl Cancer Inst. 2011;103(17):1310–22. PMID: 21852264. 10.1093/jnci/djr284 21852264
190 Kronborg O, Jorgensen OD, Fenger C, . Randomized study of biennial screening with a faecal occult blood test: results after nine screening rounds. Scand J Gastroenterol. 2004;39(9):846–51. PMID: 15513382. 10.1080/00365520410003182 15513382
191 Scholefield JH, Moss SM, Mangham CM, . Nottingham trial of faecal occult blood testing for colorectal cancer: a 20-year follow-up. Gut. 2012;61(7):1036–40. PMID: 22052062. 10.1136/gutjnl-2011-300774 22052062
192 Nishihara R, Wu K, Lochhead P, . Long-term colorectal-cancer incidence and mortality after lower endoscopy. N Engl J Med. 2013;369(12):1095–105. PMID: 24047059. 10.1056/NEJMoa1301969 24047059
193 Weigl K, Jansen L, Chang-Claude J, . Family history and the risk of colorectal cancer: the importance of patients’ history of colonoscopy. Int J Cancer. 2016;139(10):2213–20. PMID: 27459311. 10.1002/ijc.30284 27459311
194 Pickhardt PJ, Choi JR, Hwang I, . Computed tomographic virtual colonoscopy to screen for colorectal neoplasia in asymptomatic adults. N Engl J Med. 2003;349(23):2191–200. PMID: 14657426. 10.1056/NEJMoa031618 14657426
195 Kim YS, Kim N, Kim SH, . The efficacy of intravenous contrast-enhanced 16-raw multidetector CT colonography for detecting patients with colorectal polyps in an asymptomatic population in Korea. J Clin Gastroenterol. 2008;42(7):791–8. PMID: 18580500. 10.1097/MCG.0b013e31811edcb7 18580500
196 Fletcher JG, Silva AC, Fidler JL, . Noncathartic CT colonography: image quality assessment and performance and in a screening cohort. AJR Am J Roentgenol. 2013;201(4):787–94. PMID: 24059367. 10.2214/AJR.12.9225 24059367
197 Kirkoen B, Berstad P, Botteri E, . Do no harm: no psychological harm from colorectal cancer screening. Br J Cancer. 2016;114(5):497–504. PMID: 26867161. 10.1038/bjc.2016.14 26867161
198 Bretthauer M, Kaminski MF, Loberg M, . Population-based colonoscopy screening for colorectal cancer: a randomized clinical trial. JAMA Intern Med. 2016;176(7):894–902. PMID: 27214731. 10.1001/jamainternmed.2016.0960 27214731
199 Castells A, Quintero E, Alvarez C, . Rate of detection of advanced neoplasms in proximal colon by simulated sigmoidoscopy vs fecal immunochemical tests. Clin Gastroenterol Hepatol. 2014;12(10):1708–16.e4. PMID: 24681078. 10.1016/j.cgh.2014.03.022 24681078