# Appendix I Ongoing Trials

Study Reference; Trial Identifier | Study Name; Location | Recruitment age, years | Estimated N | Description | Relevant Outcomes | 2019 Status
Colonoscopy and FIT as colorectal cancer screening test in the average risk population. https://clinicaltrials.gov/ct2/show/NCT02078804. Accessed February 9, 2015.; NCT02078804 | SCREESCO; Sweden | 59–62 | 200,000 | Randomized trial comparing FIT and colonoscopy to usual care | CRC mortality and incidence | Recruiting
Pilot study of a national screening programme for bowel cancer in Norway. https://clinicaltrials.gov/ct2/show/NCT01538550. Accessed February 9, 2015.; NCT01538550 | NR; Norway | 50–74 | 140,000 | Randomized trial comparing FOBT to FS | CRC mortality and incidence; adverse events | Active, not recruiting; Psychological harms reported^197^
Kaminski MF, Bretthauer M, Zauber AG, . The NordICC Study: rationale and design of a randomized trial on colonoscopy screening for colorectal cancer. Eur J Radiol 2012 Jul;44(7):695–702.; NCT00883792 | NordICC; Nordic countries; The Netherlands; Poland | 55–64 | 66,000 | Randomized trial comparing colonoscopy to usual care | CRC mortality and incidence; all-cause mortality | Active, not recruiting; Baseline detection rates reported^198^
Colorectal Cancer Screening in Average-risk Population: Immunochemical Fecal Occult Blood Testing Versus Colonoscopy. https://clinicaltrials.gov/ct2/show/NCT00906997. Accessed September 25, 2018.; NCT00906997 | COLONPREV; Spain | 50–69 | 55,498 | Randomized trial comparing FIT to colonoscopy | CRC mortality and incidence; adverse events | Active, not recruiting; Baseline detection rates reported^199^
Colonoscopy versus fecal immunochemical test in reducing mortality from colorectal cancer (CONFIRM). https://clinicaltrials.gov/ct2/show/NCT01239082. Accessed December 15, 2014.; NCT01239082 | CONFIRM; US | 50–75 | 50,000 | Randomized trial comparing FIT to colonoscopy | CRC mortality | Active, not recruiting
Regge D, Iussich G, Senore C, . Population screening for colorectal cancer by flexible sigmoidoscopy or CT colonography: study protocol for a multicenter randomized trial. Trials 2014;15:97. PMID: 2467889624678896; NCT01739608 | NR; Italy | 58–60 | 20,000 | Randomized trial comparing CTC to FS | AN incidence; adverse events | Active, not recruiting; Baseline detection rates reported^7^
Randomized Controlled trial to evaluate the effectiveness of total colonoscopy in colorectal cancer screening. http://apps.who.int/trialsearch/Trial2.aspx?TrialID=JPRN-UMIN000001980. Accessed February 9, 2015. | NR; Japan | 40–74 | 10,000 | Randomized trial comparing FOBT to FOBT and colonoscopy | CRC mortality and incidence | Active, not recruiting