# Appendix H CRC Screening for Those With a Family History

Appendix H Table 1 Recommendations From Professional Societies for Those With a Family History

Group | Family History | Recommendation | Strength of recommendation
Canadian Association of Gastroenterology^179^ | 1+ FDR with CRC | Screening over no screening | Strong recommendation, Moderate evidence quality
Canadian Association of Gastroenterology^179^ | 2+ FDR with CRC | Colonoscopy (1^st^) | Strong recommendation, Very low evidence quality
Canadian Association of Gastroenterology^179^ | 2+ FDR with CRC | Begin at 40 years or 10 years younger than age of diagnosis of FDR | Conditional recommendation, Very low evidence quality
Canadian Association of Gastroenterology^179^ | 1 FDR with CRC | Colonoscopy (1^st^) | Conditional recommendation, Very low evidence quality
Canadian Association of Gastroenterology^179^ | 1 FDR with CRC | FIT (2^nd^) | Conditional recommendation, Very low evidence quality
Canadian Association of Gastroenterology^179^ | 1 FDR with CRC | Begin at 40 years or 10 years younger than age of diagnosis of FDR | Conditional recommendation, Very low evidence quality
Canadian Association of Gastroenterology^179^ | 1+ SDR with CRC | Screening over no screening | Strong recommendation, Very low evidence quality
Canadian Association of Gastroenterology^179^ | 1+ SDR with CRC | Begin at 50 years | Conditional recommendation, Low evidence quality
Canadian Association of Gastroenterology^179^ | 1+ SDR with CRC | Screening tests in accordance with average-risk guidelines | Conditional recommendation, Very low evidence quality
Canadian Association of Gastroenterology^179^ | 1+ FDR with AA | Screening over no screening | Strong recommendation, Very low evidence quality
Canadian Association of Gastroenterology^179^ | 1+ FDR with AA | Colonoscopy or FIT | Conditional recommendation, Very low evidence quality
Canadian Association of Gastroenterology^179^ | 1+ FDR with AA | Begin at 40 years or 10 years younger than age of diagnosis of FDR | Conditional recommendation, Very low evidence quality
Canadian Association of Gastroenterology^179^ | 1+ FDR with non-AA | Screening in accordance with average-risk guidelines | Conditional recommendation, Low evidence quality
U.S. Multi-Society Task Force on Colorectal Cancer^181^; (American College of Gastroenterology, the American Gastroenterological Association, and The American Society for Gastrointestinal Endoscopy) | 2+ FDR with CRC or AA or advanced serrated lesion (any age); or; 1+ FDR with CRC or AA or advanced serrated lesion (age <60 years) | Colonoscopy (1^st^) | Weak recommendation, Low evidence quality
U.S. Multi-Society Task Force on Colorectal Cancer^181^; (American College of Gastroenterology, the American Gastroenterological Association, and The American Society for Gastrointestinal Endoscopy) | 2+ FDR with CRC or AA or advanced serrated lesion (any age); or; 1+ FDR with CRC or AA or advanced serrated lesion (age <60 years) | FIT (2^nd^) | Strong recommendation, Moderate evidence quality
U.S. Multi-Society Task Force on Colorectal Cancer^181^; (American College of Gastroenterology, the American Gastroenterological Association, and The American Society for Gastrointestinal Endoscopy) | 2+ FDR with CRC or AA or advanced serrated lesion (any age); or; 1+ FDR with CRC or AA or advanced serrated lesion (age <60 years) | Begin at 40 years or 10 years younger than age of diagnosis of FDR | Weak recommendation, Low evidence quality
U.S. Multi-Society Task Force on Colorectal Cancer^181^; (American College of Gastroenterology, the American Gastroenterological Association, and The American Society for Gastrointestinal Endoscopy) | 1 FDR with CRC or AA or advanced serrated lesion (age ≥60 years) | Begin at 40 years; screening tests in accordance with average-risk guidelines | Weak recommendation, Very low evidence quality
U.S. Multi-Society Task Force on Colorectal Cancer^181^; (American College of Gastroenterology, the American Gastroenterological Association, and The American Society for Gastrointestinal Endoscopy) | 1+ FDR with non-AA | Screening in accordance with average-risk guidelines | NR
National Comprehensive Cancer Network^182^ | 1+ FDR with CRC (any age) | Colonoscopy at 40 years or 10 years before earliest CRC (whichever is earlier) | Based upon lower-level evidence, there is uniform NCCN consensus that the intervention is appropriate.
National Comprehensive Cancer Network^182^ | 1+ FDR with AA or advanced SSP | Colonoscopy at 40 years or at age of onset of adenoma in relative (whichever is earlier) | Based upon lower-level evidence, there is uniform NCCN consensus that the intervention is appropriate.
American Cancer Society^183^ | NA | No high-risk recommendation. Refers to the USMSTF guideline | NA

Abbreviations: AA = advanced adenoma; CRC = colorectal cancer; FDR = first-degree relative; FIT = fecal immunochemical test; SDR = second-degree relative; SSL = sessile serrated polyp