# Appendix G Adherence to Initial CRC Screening

We can estimate adherence to initial screening and subsequent testing in the United States from several types of study designs, including screening trials and observational studies of existing screening programs. Studies of European screening programs also provide estimates, though these are of limited use in estimating adherence in the United States.

Colonoscopy is the most common screening test used by commercially insured people in the United States.^89^ Among those who underwent screening in 2015, the test was used by 58.3 percent of the population, followed by FOBT (includes FIT) (7.17%) and rarely, sigmoidoscopy with FOBT (0.7%).^90^ Worldwide, FIT is the most commonly used CRC screening test, and most European CRC screening programs use it.^91–93^

## Estimates of adherence to initial colorectal cancer screening

Behavioral Risk Factor Surveillance System (BRFSS) survey data show that the overall proportion of U.S. adults ages 50–75 with “up-to-date” CRC screening increased from 65.5 percent in 2012 to 67.3 percent in 2016.^94^ However, in 2016, about 26 percent of U.S. adults ages 50–75 had never been screened.^95^ According to National Health Interview Survey data, rates of up-to-date CRC screening steadily increased between 2000 and 2015 to 62.4 percent. Adherence to CRC screening has consistently lagged behind that for breast (71.5% age adjusted in 2015) or cervical cancer screening (83.0% age adjusted in 2015).^96^

### Adherence to initial screening in included studies

One included trial, The Minnesota Colon Cancer Control Study of screening with Hemoccult II, had 90 percent adherence to at least one round of screening (not reported for individual rounds),^97^ which was higher than adherence in Hemoccult II trials conducted outside the United States (range, 60% to 70%).

Based on trials conducted in western European countries, adherence to a single round of gFOBT ranged from 32 to 59 percent, while for FIT it was 32 to 65 percent; for FS, from 28 to 47 percent; for FS plus stool testing, from 20 to 39 percent; for colonoscopy, from 17 to 27 percent; and for CTC, approximately 34 percent.^98^ One Dutch trial found greater adherence to CTC than to colonoscopy.^9^ However, estimates of adherence to colonoscopy and CTC are based on a limited number of studies, none of which was conducted in the United States. We found no studies comparing the relative adherence of FIT versus sDNA-FIT testing.

### Adherence to initial screening in other studies

A comprehensive review of adherence (Khalid-de Bakker and colleagues) included 100 prospective studies of CRC screening, only 10 of which were conducted in the United States.^99^ The review included a meta-analysis to determine a pooled estimate of adherence to a first-time invitation to screening that spanned a wide range of studies over nearly three decades. They found that overall adherence was 47 percent for gFOBT, 42 percent for FIT, 35 percent for FS, 28 percent for colonoscopy, and 22 percent for CTC. A comprehensive systematic review conducted by Holden and colleagues found a wide variation in adherence in studies whose purpose was to improve adherence to CRC screening.^100^ Adherence in usual care groups (no intervention to improve adherence to screening) ranged from 17 to 51 percent for stool tests, from 5 to 59 percent for colonoscopy, and from 23 to 55 percent for any CRC screening test. A study in the Veterans Health Administration (VA) population found significantly higher adherence rates to FIT compared with FOBT in a direct comparison over time (42.6% vs. 33.4%).^101^ This may be due in part to the relative ease of completing a FIT (fewer restrictions, fewer samples) than gFOBT.^101^ In Spain, overall adherence to guaiac or immunochemical stool-based testing increased over time and rescreening rates were high, but overall adherence rates did not go above 35.9 percent during the study period,^102^ while FIT testing adherence was higher (58.1% increasing to 70.3% over 5 years) in a population-based screening program.^103^ In a French population-based screening program, adherence to stool-based testing declined from 51.0% to 33.9% over six rounds of biennial gFOBT screening, and then increased to 53.4% with the implementation of FIT screening.^93^

A large study of adherence to sDNA-FIT in a Medicare population found that 71 percent of persons age 65 to 85 years old completed the stool test within 1 year.^104^ A small study of completion of sDNA-FIT testing in Medicare patients found that 88.3 percent of those with no colonoscopy in the previous 10 years or fecal test within the previous 1 year completed the test.^105^

A randomized trial (n=413) of blood test-based screening (Epi proColon) versus FIT testing at two integrated health systems found higher adherence to the blood test (99.5%, 95% CI 97.3%, 100% versus 88.1%, CI 83.0%, 91.8%), and considerably higher adherence to both tests than seen in observational studies.^106^ Another trial conducted in Australia (n=1800) compared adherence among those who received mailed a FIT (control group), those who received a blood test as a “rescue” strategy after 12 weeks of FIT nonparticipation (rescue group), and those offered a choice of FIT or blood testing (choice group). After 24 weeks, the trial found no significant difference in adherence among groups (control, 37.8%; rescue, 36.9%; choice, 33.8%).^107^

## Adherence to repeated screening

The effectiveness of screening over time depends on continued adherence to screening recommendations,^108,^ ^109^ particularly for stool-based tests. Adherence to repeated stool-based screening is inconsistent and remains suboptimal; however adherence to repeated stool testing may be higher than initial adherence to stool testing. Limited U.S. data suggest that adherence to one-time colonoscopy is the main driver of up-to-date screening.^90,^ ^110,^ ^111^ Limited emerging evidence suggests that repeated screening colonoscopies in people with initial negative findings may be overused, while surveillance colonoscopy remains suboptimal.

### Repeated colonoscopy screening

Limited data are available on adherence to repeated colonoscopy in people with an initial negative finding. A study in the VA population found that 16 percent of people with no adenomas received a second colonoscopy earlier than recommended guidelines, while 54 percent of people with high-risk adenomas did not receive surveillance colonoscopy at the guideline-recommended interval.^112^ A Canadian study found that 33.7 percent of people with initial negative results received early repeated colonoscopy.^113^

### Repeated stool-based test screening

Adherence to repeated stool-based testing after an initial negative test declines over time. A 2019 systematic review assessed adherence to repeated FOBT testing across 27 studies (8 U.S. based (n=753,495). Adherence to repeated FOBT testing ranged widely, from 0.8% to 3 rounds of opportunistic screening to 60.3% to 2 consecutive rounds of screening using varied outreach methods.^114^ One study in a U.S. health system using 2007–2008 data (Kaiser Permanente), showed that initial adherence to FIT was 47 percent, but only 24 percent of patients adhered to the recommended annual testing over four years.^115^ A nested observational analysis of data from the STOP CRC Trial, based in U.S. federally qualified health centers, found that rates of completed FIT kits were lower (41%) in the second round of screening invitations compared with the first round (46%), and that physician orders for eligible patients also decreased between the first and second rounds of screening.^116^ Similarly, a retrospective analysis of VA medical centers found that only 14 percent of veterans received at least four stool tests over 5 years.^111^ A cluster randomized trial of FOBT, colonoscopy, or patient choice of screening found adherence to all 3 years of FOBT was 14 percent, compared with one-time colonoscopy (38%) or choice (42%).^110^

A Kaiser Permanente study using data from 2007–2011 (sites from PROSPR consortium) found that following an initial adherence rate of 48 percent to FIT, adherence over the subsequent 3 years was 75.3 to 86.1 percent, but the analysis included only people who had been adherent in the previous round.^117^ A similar pattern was seen in a U.S. study using 2000–2003 Group Health Cooperative data,^118^ in the review by Murphy and colleagues,^114^ and in international studies. In a U.K.-based study, gFOBT increased over three biennial rounds (57.4% in the first, 60.9% in the second, and 66.2% in third), but consistent screening over all rounds was more limited (44%) and participation in the first round was strongly predictive of continued screening.^119^ In a Norwegian study, initial adherence to FIT screening was 44.7 percent; among these completers, 83.1 percent completed a second round of screening.^120^ An analysis of French data found that 14.3 percent of the invited population participated in four consecutive rounds of gFOBT screening, with participation decreasing over time.^121,^ ^122^ An Australian study of population-based screening found similar rates (43.1%) of “consistent” screening of FIT test completion over four rounds,^123^ as did a Canadian screening program that found initial adherence of 81.7 percent to FIT testing, with a 86.0% of those initial completers also completing a second round of testing.^124^ In an Italian national screening program of FIT screening, initial adherence was 69 percent and above 94 percent in each subsequent round of previous completers.^125^

A study of a 2010–2011 analysis of repeated gFOBT screening in people in four large U.S. health systems in the PROSPR consortium found wide variation in consistent repeat screening over 3 years following one negative test (mean rate 46%).^126^ In a study with older data among insured people (2000–2001) who had completed one FOBT screening, 44.4 percent completed a second screening over 2 years. Receipt of a preventive health examination was strongly associated with FOBT adherence relative to no CRC screening.^118^ Another U.S. study found that 41 percent adhered to three rounds of screening with gFOBT, much lower than the 85 percent that received a one-time colonoscopy.^127^

We found no data on adherence to multiple rounds of other screening modalities, including FS, FS plus stool testing, CTC, and sDNA-FIT.

## Predictors of adherence to CRC screening

Health insurance coverage and access to care is a major explanatory factor for screening adherence in the United States^128^ and often explains observed racial/ethnic differences in screening uptake.^90,^ ^129^ Geospatial considerations also affect access to screening and subsequent adherence, including rural/urban and neighborhood-level disparities.^130–134^

Patient selection of a screening test is multifactorial, based on the test’s ability to detect and/or prevent cancer, its side effects or adverse effects (including those from bowel preparation and the test itself), the risk of false-positives, convenience of the test, and the screening frequency (interval of testing).^135^ Several patient factors may affect uptake and adherence to screening, including age, sex, socioeconomic status/education, race/ethnicity, acculturation, health status, cancer risk, risky health behaviors, marital status, cancer experiences of friends and family, receiving a physician recommendation, and psychosocial factors (including but not limited to patient knowledge, attitudes, beliefs, and concerns about test comfort or invasiveness).^100,^ ^136–140^ People who have previously been adherent to CRC screening or other preventive care recommendations are likely to continue to adhere to CRC screening.^141^

### Differential adherence by race/ethnicity, sex, and age

In the United States, adherence to CRC screening recommendations varies by population. According to 2015 NHIS data, white adults have the highest rates of up-to-date CRC screening (63.7%), followed closely by black adults (59.3%). CRC screening rates are lower among Asian adults (52.1%) and American Indian/Alaska Native adults (48.4%), and individuals with Hispanic ethnicity have lower screening rates (47.4%) compared with non-Hispanic individuals (64.2%).^96^ CRC screening rates also vary within ethnic groups. For example, an analysis of the 2009–2014 Medical Expenditure Panel Survey identified variation in CRC screening rates across Asian-American subgroups, ranging from 48.6 percent among Asian Indians to 50.9 percent among Chinese and 55.0 percent among Filipinos.^142^

Some evidence suggests racial/ethnic disparities in CRC screening vary by health care setting. According to research from the PROSPR consortium, non-Hispanic white and black adults have similar adherence to CRC screening in health care systems with low overall screening rates, but black adults have lower adherence than white adults in systems with high overall screening rates.^143^ In a California-based integrated health system, CRC screening rates were similar among non-Hispanic white and black adults, higher among Asian adults, and marginally lower among Hispanic adults.^144^ One VA study found black adults had slightly lower adherence (72%) compared with white adults (77%), but the disparity was attenuated (compared with national averages) and was accounted for by confounders of single marital status and lower levels of education.^145^ The STOP CRC trial, which was conducted in FQHCs in Oregon and California, found that Asian race, Hispanic ethnicity, and non-English preference were associated with higher odds of screening completion.^116^

Data are mixed for differences in adherence by sex. Data from the 2016 BRFSS found rates of up-to-date CRC screening were slightly lower for males (65.9%) compared with females (69.4%),^146^ while data from the 2015 NHIS found similar screening rates for males (63.2%) and females (62.2%).^96,^ ^147^ Rates of fecal test completion (FOBT or FIT) in the previous year were slightly higher among males (7.6%) compared with females (6.8%) in the 2015 NHIS data. However, an international meta-analysis of FIT screening studies found lower uptake in men compared with women.^148^

CRC screening rates also vary by age. According to the 2015 NHIS, adherence is lower among people ages 50–64 years (57.9%) compared with people ages 65–75 years (71.8%).^96^ There are less data on screening in populations younger than age 50. A study using 2010 NHIS data found CRC screening adherence was 41.4 percent among adults ages 40–49 years who had a first-degree relative with CRC.^149^An observational study of screening adherence in African Americans ages 45–49 years found 17.4 percent had received at least one screening procedure, most commonly colonoscopy.^150^

Adherence to CRC screening also varies by other demographic characteristics. Use of CRC screening is lower among foreign-born people (52.3% [U.S. residence ≥10 years], 36.3% [U.S. residence <10 years]) than among U.S.-born people (64.6%).^96^ In addition, CRC screening is higher in groups with the highest education (70.7%) and income levels (70.0%), and lower among people without a usual source of health care (26.3%) or health insurance (25.1%).^96^ Screening rates also vary by U.S. state of residence, ranging from 58.5 percent in New Mexico to 75.9 percent in Maine.^94^

### Differential adherence by family history

A family history of CRC is associated with an increased likelihood of screening.^151,^ ^152^ According to a 2015 systematic review, adults with a family history of colorectal cancer (typically defined as at least one first-degree relative with CRC) are about 1.4–3.3 times more likely to adhere to CRC screening recommendations than individuals with no family history.^151^ A study using 2010 NHIS data found CRC screening adherence was 57.0 percent (ages 50–64) and 65.9% (age ≥65) among those with no family history of CRC, compared with 70.8 percent (age 50–64) and 72.5 percent (age ≥65) among those with a first-degree relative with CRC.^149^ Adherence was lower (41.4%) among adults ages 40–49 years with a first-degree relative with CRC,^149^ despite recommendations from several groups to initiate screening at age 40 among those who had a first-degree relative diagnosed with CRC at age <60.^153^

### Interventions to Increase CRC screening

A 2018 systematic review and meta-analysis of U.S.-based randomized clinical trials of interventions to increase colorectal cancer screening (73 included trials) found that fecal blood test outreach, patient navigation, patient education, patient reminders, and clinician-focused interventions (academic detailing or clinician reminders) were associated with increased completion of colonoscopy or initial stool-based screening.^154^ Multicomponent interventions were more effective than single-component interventions, and mailed fecal blood tests with patient navigation improved adherence to repeated stool-based testing.^154^ The Holden systematic review found strong evidence for the effectiveness of interventions including patient reminders or one-on-one interactions, eliminated structural barriers (e.g. improving access), and system-level changes (e.g., systematic screening) in improving CRC screening.^100^ A 2019 systematic review of interventions to improve FIT screening (15 of 25 studies were U.S.-based) found that mailed kit outreach improved adherence by 21.5 percentage points, while reminders only were much less effective (4.1%).^155^ Increased awareness of CRC and decision aids that help patients choose among various CRC screening options are associated with higher rates of screening uptake.^156^

The Community Preventive Services Task Force recommends multicomponent interventions to increase screening for colorectal cancers on the basis of strong evidence of effectiveness in increasing screening with colonoscopy or FOBT.^157^

## Adherence to followup colonoscopy for abnormal screening test results

Completion of followup colonoscopy is a critical step in the screening process for people with positive stool-based test results. Lack of colonoscopy within 12 months is associated with higher risk of CRC and later stage at diagnosis,^158^ based on a review of modeling following a positive stool-based test due to increasing risk of cancer and late-stage disease with increasing delays between positive stool-based test and followup colonoscopy.^159^

### Observational U.S.-based evidence of completion of colonoscopy after positive stool-based testing

Since the previous USPSTF review, several large U.S.-based observational studies on this topic have been published, as well as one meta-analysis and one systematic review of interventions. These studies together suggest that adherence to followup colonoscopy is incomplete overall, with adherence estimates between 50 percent and 87 percent. There is limited evidence of increasing adherence with time. Completion of followup colonoscopy ranges widely across institutions and may be lower in safety net settings.

Adherence appeared highest in studies of large health systems. In two observational studies from the PROSPR consortium using data from four large health systems (including Kaiser Permanente Northern California and Kaiser Permanente Southern California), estimates of adherence using 2010–2012 data were overall 79.6 percent at 3 months in people ages 50–74^141^ and 58.1 to 83.8 percent across sites at 6 months in people ages 50–89.^160^ In two studies using Kaiser Permanente data alone (southern California and northern California), adherence was 78.4 percent at 12 months according to 2006–2008 data,^117^ and 83.2 percent at 12 months in peoples ages 50–74.^158^ National screening programs in the Netherlands and Spain reported particularly high completion rates of followup colonoscopy, both above 90 percent.^103,^ ^161^

Two studies of VA populations found lower adherence. In a study of completion of followup colonoscopy in people with positive stool-based tests, completion was approximately 50 percent at 6 months at 120 clinics using 2009–2011 data. In this study, black individuals were more likely to receive colonoscopy than white individuals.^162^ In a more recent study of VA clinics in southern California using 2014–2016 data, completion was 62.1 percent at 6 months, and median time to colonoscopy was 83 days.^163^

Four studies suggest that completion rates may be even lower in these settings. In four studies of large safety net settings using data from 2010–2015, adherence ranged from 51.5 to 57.7 percent at 6 to 12 months’ followup.^164–167^ In one study, Spanish language speakers were more likely to complete colonoscopy than English speakers, and people with one to two visits were more likely to complete than those with no visits.^164^ In another, completion was less likely among those ages 61–64 compared with those ages 50–55.^165^

A recent systematic review (2019) and meta-analysis including studies published though 2017 (13 of 42 studies were U.S.-based) found that the pooled estimate of colonoscopy completion was 80.4 percent. Rates increased incrementally with each 10-year increment studied.^168^ An older systematic review found that adherence to followup colonoscopy for positive stool testing (within 1 year) in integrated health systems ranged from 44 to 86 percent.^100^ In a review of interventions to improve followup colonoscopy completion, rates in the control group ranged from 2 percent over 60 days’ followup to 80 percent within 6 months.^91^

One retrospective population based study found that the rates of follow-up colonoscopy were higher following a positive sDNA-FIT versus FIT screening test, 84.9 versus 42.6 percent respectively.^169^ Another large retrospective study of 15,469 patients at Mayo Clinic sites reported that 87 percent of persons with a positive sDNA-FIT underwent follow-up colonoscopy.^170^

### Variation by race, ethnicity, or age in completion of followup colonoscopy

Very little data exist to explain disparities in adherence to followup colonoscopy by subgroups. Based on the PLCO trial, however, it appears that blacks had lower adherence (63%) to followup colonoscopy after screening FS than whites (72%).^171^ Evidence of variation in completion by race/ethnicity or age was less consistently reported, and the available evidence was less clear, than in studies of adherence to initial screening (see CQ1).

### Interventions to increase adherence to followup colonoscopy

A systematic review of interventions to improve adherence to followup colonoscopy after stool testing found that interventions could increase the proportion of test-positive patients receiving a followup colonoscopy by up to 23 percentage points.^91^

A review of the 29 CDC-funded centers in the Colorectal Cancer Control Program (CRCCP) was published in 2019 using 2009–2015 data. Across centers, 82.9 percent of people ages 50–64 completed a colonoscopy after a positive stool test, 79.8 percent within 90 days, and 95.2 percent within 180 days.^172^ The CRCCP supports implementation of evidence-based interventions in accordance with the Guide to Community Preventive Services^157^to increase CRC screening for under- or uninsured people.

### Completion of colonoscopy after positive stool-based testing in included studies

In the Minnesota trial, 10 percent of participants on average had positive Hemoccult II tests and 83 percent of those participants underwent a followup evaluation (most often colonoscopy).^97^ In the PLCO trial, 33 percent of people with screening FS were recommended to follow up with colonoscopy; 77 percent of which actually received the followup colonoscopy.^173^

Family history of CRC represents an approximation of genetic risk and is typically characterized in terms of the number of affected relatives, the degree of relatedness to them, and their age at CRC diagnosis. Individuals at the highest risk are those from families with known genetic syndromes, multiple affected relatives, and/or relatives with early-age cancer diagnosis, particularly before age 50. At more moderate risk levels are people with one or more first-degree relatives (FDRs) or second-degree relatives (SDRs) with later onset cancer.

A systematic review of eight large population-based cohorts found that the prevalence of family history of one FDR with early-onset cancer (age 60 or younger) was approximately 0.3 percent, while the prevalence of a single FDR with history of late-onset CRC (after age 60) was more than 3 percent.^151^ Based on California Health Interview Survey data, “moderate risk” of family history (defined as either one FDR with late onset cancer, two SDRs from the same lineage with late-onset cancer, or one SDR with early onset cancer and the other SDR with an associated cancer) has a prevalence of 4.2 percent.^174^ The risk of CRC also increases with the number of affected FDRs. A systematic review of 42 case-control and 20 cohort studies found the pooled relative risk of CRC in patients with 1 affected FDR was 1.92 (95% CI, 1.53 to 2.41) in case-control and 1.37 (95% CI, 0.76 to 2.46) in cohort studies, compared to the relative risk of CRC with 2 or more affected FDRs was 2.81 in case-control studies (95% CI, 1.73 to 4.55) and 2.40 in cohort studies (95% CI, 1.76 to 3.28).^175^

A systematic review and meta-analysis of 63 studies (n=9.83 million) found further evidence that patient age is an important variable in assessing CRC risk due to family history. In this study, meta-analysis of 10 studies suggested that family history-associated CRC risk was higher in people younger than age 50 compared with people over age 50 (RR 2.81; 95% CI, 1.94 to 4.07).^176^

#### Measurement issues

Family history is a complex risk factor because it can represent genetic risk as well as aggregate behavioral risk (e.g., smoking, diet) and because it can change over time (e.g., can be altered with CRC screening and polyp removal). Furthermore, self-report of family history, while specific, may not be very sensitive. A Scottish case-control study comparing the accuracy of self-reported family history and relatives’ medical records found that cases underreported colorectal cancer in FDRs (sensitivity 0.57 [95% CI, 0.43, 0.69]; specificity 0.99 [95% CI, 0.98, 0.99]) and SDRs (sensitivity 0.27 [95% CI 0.17, 0.41]; specificity 0.99 [95% CI 0.99, 1.0]); similar patterns were reported in controls.^177^ A systematic review for the AHRQ Effective Healthcare Program found similar results, also concluding that accuracy is higher in reporting of cancer history in FDRs than in more distant relatives.^178^

#### Screening recommendations based on family history

CRC screening guidelines generally recommend early and more frequent colonoscopy for people at the highest levels of risk due to family history, typically those with a single FDR with early onset cancer (before age 60) or multiple relatives with CRC diagnoses that suggest genetic risk. In these high-risk groups, colonoscopy is typically recommended at age 40 years or 10 years before the relative’s age at diagnosis, repeated at 5–10 years.^153,^ ^179^ (Appendix H Table 1) In addition, family members of people with known genetic syndromes may be invited to receive cascade genetic testing and/or enhanced surveillance.^180^

There is less consensus on screening guidelines for people with a more moderate family history risk—those with a single FDR and/or SDR diagnosed after age 60 (Appendix H Table 1). Recommendations for this group range from a single screening with any modality at age 40 years and subsequent screening assuming average risk (U.S. Multi-Society Task Force on Colorectal Cancer) to screening in people with one or more FDR between age 40 and 50 years or 10 years before the affected relative’s age of diagnosis, and typical screening beginning at age 50 for people with affected SDRs (Canadian Association of Gastroenterology guidelines).

#### Risk of CRC in people under age 50 at moderately increased risk for CRC based on family history

A large body of observational evidence from multiple countries and populations suggests that CRC risk increases as the intensity of family history of CRC increases (more relatives, closer in relation, younger age at diagnosis), providing a plausible hypothesis for a screening benefit in these groups. Pooled risk estimates for the highest risk groups compared with people with no known family history range from 3.55 (95% CI, 1.84–6.83) for people with a single FDR diagnosed before age 50 to 3.97 (95% CI, 2.6 to 6.06) for people with two or more affected FDRs.^153^ Pooled risk estimates for a single FDR with CRC over age 60 years remain elevated compared with people who have no family history (1.83, 95% CI, 1.47–2.25).^153^ A systematic review and meta-analysis of relative risks for CRC associated with family history found a pooled risk of RR 2.24 (95% CI, 2.06–2.44), and 3.97 (95% CI, 2.60 to 6.06) for people with at least two affected FDRs.^184^ It also found that lifetime risks for CRC for a 50-year-old increased from 1.8 percent if there was no family history to 3.4 percent (95% CI, 2.8–4.0) if there was at least one affected relative and to 6.9 percent if there were two or more affected relatives.^184^ The review of reviews conducted for the CAG guidelines found similar increased levels of risk for nearly all types of studies and populations.^179^ Two studies additional studies using data from the Swedish Cancer Registry similarly add to this large body of observational evidence. One study found similar lifetime cumulative CRC risk associated with having either a half- or full-sibling with CRC (standardized incidence ratio 1.65, 95% CI, 1.58 to 1.73 for full sibling; SIR 1.55, 95% CI,1.30 to 1.83 for half sibling).^185^ The second study modeled starting ages for CRC screening based on family history, finding that people with family history reached the population level 10-year cumulative risk (0.44) 3 to 29 years (earlier according to higher intensity of family history) earlier than people without family history.^186^

In the PLCO trial, family history of CRC was a predictor of CRC incidence and mortality.^187^ Mortality risk estimates were highest for people who had two or more affected FDRs (RR 1.53; 95% CI, 0.7 to 3.3), and people who had a FDR with CRC before age 60 years (RR 1.66, 95% CI, 1.1 to 2.5).^187^ However, the PLCO trial did not include people under age 50.

#### Evidence on the effectiveness of screening for CRC in people under age 50 at moderate risk for CRC based on family history

We found no direct evidence of the effectiveness of screening people under age 50 at moderately increased CRC risk due to family history. Included studies for KQ1 generally did not include people under age 50 nor report results stratified by family history.

None of the included flex sig screening trials included participants under age 50. Two FS trials reported including about 10 percent of participants with a family history of CRC.^188,^ ^189^ Neither of these trials reported stratified results by family history. Three of the included gFOBT screening trials include participants under age 50 (starting screening age 45) but did not report results by age strata nor family risk.^24,^ ^190,^ ^191^

One included observational colonoscopy study included people under age 50, but did not report age-stratified results.^192^ This study (in health professionals) found that in people with a FDR family history of CRC, the association was no longer statistically significant after 5 years (multivariate HR 0.91; 95% CI, 0.55 to 1.52) compared with a sustained association beyond 5 years in people without a family history (multivariate HR 0.43; 95% CI, 0.32 to 0.58) (p=0.04 for interaction). Another population-based German case-control study found that previous colonoscopy was associated with decreased CRC risk in people with all levels of family history. Regardless of family history status, colonoscopy was associated with a lower CRC risk (OR: 0.25; 95% CI, 0.22 to 0.28 for people without family history and OR 0.45; 95% CI, 0.36 to 0.56 for people with family history). However, only about a fraction of the study population was under age 50 (5.4% of cases and 4.4% of controls).^193^

#### Evidence on the test accuracy of screening for CRC in people under age 50 at moderate risk for CRC based on family history

While several studies of test accuracy included people under age 50 and those with a family history of CRC, no studies reported variation of test accuracy by family history.

Four CTC and colonoscopy accuracy studies included people age 40 years and older^58,^ ^194–196^, three of which ^194–196^ required a family history for people ages 40 to 50 years. None of these studies reported age-stratified results for people under age 50 years nor by family risk. Likewise, several stool test-accuracy studies (high-sensitivity gFOBT, FIT, or sDNA) included participants under age 50 years and/or people with a family history of CRC (range 3–13% when reported), but no studies reported stratified results by family history. Five studies reported the test accuracy of OC-Sensor for a variety of age groups (i.e., 40–49 years, 50–75 years, 50–54 years, 55–59 years, 60–64 years, 65–69 years, 70–75 years). Across all studies, there were no patterns or differences in the sensitivity and specificity to detect CRC among different age groups.

#### Evidence on the harms of screening for CRC in people under age 50 at moderate risk for CRC based on family history

We found no studies that reported variation of test accuracy by family history. Harms of colonoscopy generally increase with age, and few studies included people younger than age 50 years, none of these studies reported harms by family history.