# Appendix F Decision Models

Appendix F Table 1 Study Characteristics and Reported Lesions for OC-Sensor

Author | Countries | Age, mean or range^*^ | Female, % | Total n | CRC, n (%) | AA, n (%) | Non-advanced adenoma, n (%) | No adenoma, n (%)
Brenner, 2013^70^ | DEU | 63 | 51 | 2235 | 15 (0.67) | 207 (9.3) | 398 (17.8) | 1615 (72.3)
Chang, 2017^71^ | TWN | 59 | 49 | 6198 | 0 (0) | 428^**^ (6.9) | 1254 (20.2) | 4516 (72.9)
Chiu, 2016^72^ | AUS, JPN, SGP, HKG, KOR, TWN, CHN, BRN, MYS, PAK, PHL, THA | 58 | 49 | 4434 | 28 (0.15) | 632 (3.5) | -- | --
Cooper, 2018^73^ | US | 57 | 60 | 760 | 2 (0.26) | 49 (6.4) | -- | --
de Wijkerslooth, 2012^74^ | NLD | 60^†^ | 49 | 1256 | 8 (0.64) | 111 (8.8) | -- | --
Hernandez, 2014^75^ | ESP | 58 | 50 | 779^‡^ | 5 (0.64) | 92 (11.8) | 204 (26.2) | 482 (61.9)
Imperiale, 2014^76^ | US, CAN | 64 | 54 | 9989 | 65 (0.65) | 757^**^ (7.6) | 2893 (29.0) | 6274 (62.8)
Kim, 2017^77^ | KOR | ≥40 | 30 | 14912 | 15 (0.06) | 363 (2.4) | 2972 (19.9) | 11562 (77.5)
Liles, 2018^78^ | US | NR | 51 | 2771 | 2 (0.07) | 209 (7.5) | -- | --
Park, 2010^79^ | KOR | 59 | 49 | 770 | 13 (1.7) | 59 (7.7) | 219 (28.4) | 479 (62.2)
Redwood, 2016^80^ | US | 40–85 | 60 | 661 | 10 (1.5) | 82 (12.4) | 235 (35.6) | 334 (50.5)
Shapiro, 2017^81^ | US | 50–75 | 54 | 1006 | 2 (0.2) | 53^**^ (5.3) | -- | --

* Range if mean not reported

† Median

‡ Row does not add to 779 participants; query to author could not resolve the extra participants in the non-advanced adenoma and no adenoma columns.

** Includes SSL

Note: Some data obtained through personal communication with authors.

Abbreviations: AA = advanced adenoma; AUS = Australia; BRN = Brunei Darussalam; CAN = Canada; CHN = China; CRC = colorectal cancer; DEU = Germany; ESP = Spain; HKG = Hong Kong; KOR = the Republic of Korea; JPN = Japan; MYS = Malaysia; n = number; NLD = the Netherlands; PAK = Pakistan; PHL = the Philippines; SGP = Singapore; THA = Thailand; TWN = Taiwan; US = United States of America.

Appendix F Figure 1 Pooled Sensitivity of OC-Sensor at Cutoff 20 ug Hb/g Feces to Detect CRC

Appendix F Figure 1 is a forest plot of OC-Sensor sensitivity to detect CRC at 20 μg Hb/g feces. The pooled sensitivity is 0.74 with a 95% confidence interval of 0.59 to 0.89.

Appendix F Figure 2 Pooled Sensitivity of OC-Sensor at Cutoff 20 ug Hb/g Feces to Detect AA

Appendix F Figure 2 is a forest plot of OC-Sensor sensitivity to detect advanced adenomas at 20 μg Hb/g feces. The pooled sensitivity is 0.22 with a 95% confidence interval of 0.19 to 0.25.

Appendix F Figure 3 Pooled Sensitivity and Specificity of OC-Sensor at Cutoff 20 μg Hb/g Feces to Detect Non-Advanced Adenoma

Appendix F Figure 3 is a forest plot of OC-Sensor sensitivity and specificity to detect non-advanced adenomas at 20 μg Hb/g feces. The pooled sensitivity is 0.07 with a 95% confidence interval of 0.04 to 0.09. The pooled specificity is 0.97 with a 95% confidence interval of 0.96 to 0.97.

Appendix F Figure 4 Pooled Sensitivity and Specificity of Cologuard to Detect CRC, Advanced Adenomas, and Non-Advanced Adenomas

Appendix F Figure 4 is a forest plot of pooled sensitivity and specificity of Cologuard to detect CRC, advanced adenomas, and non-advanced adenomas. For CRC, the pooled sensitivity is 0.94 with a 95% confidence interval of 0.87 to 1.00. The pooled specificity is 0.85 with a 95% confidence interval of 0.83 to 0.88. For advanced adenomas, the pooled sensitivity is 0.42 with a 95% confidence interval of 0.39 to 0.46. The pooled specificity is 0.89 with a 95% confidence interval of 0.84 to 0.93. For nonadvanced adenomas, the pooled sensitivity is 0.15 with a 95% confidence interval of 0.10 to 0.20. The pooled specificity is 0.91 with a 95% confidence interval of 0.86 to 0.95.

Appendix F Figure 5 Pooled Sensitivity and Specificity of Hemoccult Sensa to Detect CRC, Advanced Adenomas, and Non-Advanced Adenomas

Appendix F Figure 5 is a forest plot of the pooled sensitivity and specificity of Hemoccult Sensa to detect CRC, advanced adenomas, and non-advanced adenomas. For CRC, the pooled sensitivity is 0.68 with a 95% confidence interval of 0.46 to 0.90. The pooled specificity is 0.97 with a 95% confidence interval of 0.94 to 1.00. For advanced adenomas, the pooled sensitivity is 0.11 with a 95% confidence interval of 0.01 to 0.22. The pooled specificity is 0.98 with a 95% confidence interval of 0.95 to 1.00. For nonadvanced adenomas, the pooled sensitivity is 0.05 with a 95% confidence interval of 0.03 to 0.07. The pooled specificity is 0.97 with a 95% confidence interval of 0.96 to 0.98.

## Appendix F Summary of Non-CISNET Colorectal Cancer Screening Decision Models (Addressing Earlier Age to Start, Age to Stop Screening, or Comparative Effectiveness of Different Screening Tests)

There are several decision models for colorectal cancer screening in addition to the three microsimulation models in the CISNET-CRC consortium. These Markov and microsimulation models have been used to evaluate the comparative effectiveness and cost effectiveness of various CRC screening strategies. All of these models account for many parameters on the natural history of disease and the screening process; however, they vary in the sources of information and assumptions for the inputs for these parameters. There are numerous challenges to adequate representation of the disease’s natural history and screening process, as well as to evaluation of the models’ structural uncertainty. Here we briefly summarize the models’ findings as they relate to age to start/stop and the comparative effectiveness of the various screening strategies.

### Age to start/stop

Two recent decision analyses evaluated the cost-effectiveness of initiating screening before age 50.^82,^ ^83^ Both analyses found that beginning screening at age 45 years could be cost effective; however earlier initiation would increase colonoscopy demand and could have less favorable incremental benefits than screening at ages 50 to 74 or 75 years. One Markov model by Ladabaum and colleagues found that initiating screening at age 45 years instead of 50 years would prevent four CRC cases and two CRC-related deaths and require 758 additional colonoscopies.^82^ Ladabaum and colleagues modeled the impact of the additional colonoscopies (recognizing that colonoscopies are a fixed resource) on unscreened people (recognizing that many people over age 50 are not screened). They estimated that the 758 colonoscopies could instead be performed on 231 unscreened 55-year-old people or 342 unscreened 65-year-old people and avert 13 to 24 CRC cases and six to seven CRC-related deaths. Likewise, improving colonoscopy completion rates after abnormal FIT (from 60% to 90%) could avert 22 CRC cases and 10 CRC-related deaths. To estimate the population impact and resource impact of recommended earlier age to start screening in the US, the decision analyses found that shifting age specific screening to 5 years earlier could avert 29,400 CRC cases and 11,100 CRC deaths but would require an additional 10.7 million colonoscopies and cost an incremental $10.4 billion, while improving screening rates to 80% in persons age 50–75 years old would avert nearly 3-fold more CRC deaths at one third the incremental cost.

Another decision analysis by Lew and colleagues that used a microsimulation model found that initiating screening with biennial FIT at age 45 years instead of age 50 (based on the Australian National Bowel Cancer Screening Program) would result in an additional reduction of 2–3 percent in CRC cases and 2–4 percent reduction in CRC-related deaths, with an increase in colonoscopies by 3–14 percent (55 to 170 additional colonoscopies per additional CRC death prevented).^83^ Lew and colleagues’ analyses also estimated the incremental benefit of extending the age to stop screening beyond 74 years. They estimated that biennial FIT until age 79 years would result in an additional reduction of 1–2 percent in CRC cases and 3–5 percent in CRC-related deaths, with an increase in colonoscopies of 9 to 24 percent, and extending screening until age 84 years would result in a reduction of 2–3 percent in CRC cases and 5–7 percent in CRC-related deaths, with an increase in colonoscopies of 27 to 53 percent.^83^

### Comparative screening tests

One decision analysis by D’Andrea and colleagues using a microsimulation model evaluated the impact of adherence on screening effectiveness (using CRC incidence, CRC-related deaths, and incremental LYG).^84^ The analysis compares 100 percent adherence to reported adherence, using estimates to initial screening and followup colonoscopy (and assuming 100% adherence to surveillance colonoscopies) derived from the literature. Assuming 100 percent adherence, the analyses demonstrated near-equivalent benefit for annual hs-gFOBT or FIT, sDNA+FIT every 3 years, CTC every 5 years, annual mSEPT9 serum testing, and colonoscopy every 10 years. However, when using adherence reported in the literature, colonoscopy was superior to other strategies in reducing cancer incidence and mortality, and the authors concluded that adherence rates higher than 65 to 70 percent would be required for any stool- or blood-based screening to match the benefits of colonoscopy. Their model makes assumptions regarding reported adherence inputs beyond the adherence estimates to initial screening in an attempt to take into account the complexity of modeling real world adherence.

Two systematic reviews summarize the cost-effectiveness of different screening strategies, one by Landsdorp-Vogelaar and colleagues and the second an update of that review by Ran and colleagues.^85,^ ^86^ Both reviews include CISNET models. Collectively, the reviews found that a variety of strategies—annual or biennial gFOBT, annual or biennial FIT, FS every 5 years, colonoscopy every 10 years, CTC every 5 or 10 years, sDNA every 3 or 5 years, capsule endoscopy every 5 or 10 years—are all cost effective when compared to no screening, although details and estimates of cost-effectiveness vary. However, compared with common strategies (annual or biennial gFOBT or FIT, FS every 5 years, or colonoscopy every 10 years), CTC was often, but not always, less cost effective, and sDNA and capsule endoscopy were both more expensive and less effective than the majority of common strategies.^85,^ ^86^ Three additional published non-CISNET decision analyses were not included in these reviews. One additional microsimulation decision analysis by Coldman and colleagues found that screening with FIT is an effective alternative to colonoscopy, using considerably less colonoscopy resources. One additional Markov decision analysis by Senore and colleagues found that FS plus FIT was more cost effective than FS alone.^87^ Lastly, one decision analysis based on the Archimedes model, conducted by Exact Sciences, found that annual sDNA+FIT testing had similar reductions in CRC cases and CRC-related deaths compared with colonoscopy every 10 years; however, concluded that sDNA+FIT every 3 years, although less effective than annual testing, was likely more achievable in clinical practice because of greater cost-effectiveness (and patient preference).^88^