# Appendix E Figures

Appendix E Figure 1 Key Question 2: Summary ROC Curve of OC-Sensor to Detect CRC (All Colonoscopy Follow-Up), 20 μg Hb/g Feces Cutoff

Abbreviations: AUC = area under the curve; SENS = sensitivity; SPEC = specificity; ROC = receiver operating characteristic; µg Hb per g feces = microgram hemoglobin per gram feces

Appendix E Figure 1 displays a summary ROC curve of OC-Sensor to detect CRC with all colonoscopy follow-up at a cutoff of 20 μg Hb/g feces. The pooled sensitivity is 0.74 with a 95% confidence interval of 0.64 to 0.83 and a pooled specificity of 0.94 with a 95% confidence interval of 0.93 to 0.96.

Appendix E Figure 2 Key Question 2: Forest Plot of OC-Sensor Sensitivity and Specificity to Detect CRC (Registry Follow-Up), by Cutoff (μg Hb/g Feces)

Note: For 20 µg Hb/g feces cutoff, bivariate sensitivity was 0.84 (95% CI, 0.72 to 0.91) and specificity was 0.95 (95% CI, 0.94 to 0.96) .

Abbreviations: CI = Confidence interval; CRC = Colorectal cancer; FN = False negative; FP = False positive; Hb/g = hemoglobin per gram feces; TN = True negative; TP = True positive; ug = Microgram

Appendix E Figure 2 is a forest plot of OC-Sensor sensitivity and specificity to detect CRC with registry follow-up, grouped by screening test cutoff in μg Hb/g feces. For 10 μg Hb/g feces, the pooled sensitivity is 0.76 with a 95% confidence interval of 0.68 to 0.84. The pooled specificity is 0.89 with a 95% confidence interval of 0.86 to 0.92. For 15 μg Hb/g feces, the pooled sensitivity is 0.76 with a 95% confidence interval of 0.74 to 0.79. The pooled specificity is 0.91 with a 95% confidence interval of 0.91 to 0.91. For 20 μg Hb/g feces, the pooled sensitivity is 0.81 with a 95% confidence interval of 0.74 to 0.88. The pooled specificity is 0.95 with a 95% confidence interval of 0.93 to 0.96.

Appendix E Figure 3 Key Question 2: Forest Plot of Other FITs Sensitivity and Specificity to Detect CRC (Registry Follow-Up)

Abbreviations: CI = Confidence interval; CRC = Colorectal cancer; FP = False positive; FIT = Fecal immunochemical test; FN = False negative; TP = True positive; TN = true negative.

Appendix E Figure 3 is a forest plot of other FITs sensitivity and specificity to detect CRC with registry followup. Sensitivity ranges from 0.69 to 0.90 and specificity ranges from 0.84 to 0.97.