# Appendix D Tables

Appendix D Table 1 Included FIT Tests Grouped by FIT “Family”

Test Family | Test Names | Type of Test | Test Principle | Cutoff, ng Hb/mL buffer | Cutoff, μg Hb/g feces | Manufacturer
Hemosure | Hemosure | Qualitative | Immunochromatographic | 50^†^ | 50^*^ | W.H.P.M., Inc., Irwindale, CA
Hemoccult ICT | Hemoccult ICT, FlexSure OBT | Qualitative | Immunochromatographic | -- | 300^*^ | Beckman Coulter, Inc
immoCARE-C | immoCARE-C, Hemocare | Qualitative | Immunochromatographic | 50^*^ | 30^*^ | CAREdiagnostica, Voerde, Germany
MonoHaem | MonoHaem | Qualitative | Immunochromatographic | -- | 1,050*** | Silenus Laboratories Proprietary Ltd. , Wilmington, DE (distributor for Chemicon International, Inc)
QuickVue | QuickVue iFOB | Qualitative | Immunochromatographic | 50^*^ | 50^*^ | Quidel, San Diego, CA
OC-Light | OC-L FIT-CHEK (manual), OC-Light | Qualitative | Immunochromatographic | 50^*^ | 10^**^ | Eiken Chemical Co., Tokyo, Japan, distributed in the US by Polymedco, Inc., Cortlandt Manor, NY
OC-Sensor | OC FIT-CHEK (using the OC-Auto Micro 80 Analyzer); OC-Auto, OC-Micro (using OC-Auto reagents), OC-Diana, OC-Sensor (using OC-Sensor Diana reagents), OC-Auto Micro | Quantitative^‡^ | Latex agglutination, measured as optical change | 100^*^ | 20^†^ | Eiken Chemical Co., Tokyo, Japan, distributed in the US by Polymedco, Inc., Cortlandt Manor, NY
OC-Hemodia | OC-Hemodia (manual) , OC-Hemodia (automated, since 2000), OC-Sensor micro (when using OC-Hemodia reagents) | Qualitative | Visual particle agglutination | | 40^**^ | Eiken Chemical Co., Tokyo, Japan
Clearview (casette) | Clearview iFOB Complete (casette) | Qualitative | Immunochromatographic | 50^†^ | 6 ug Hb^†^ | Alere Inc., Waltham, MA
Clearview (test strip) | Clearview ULTRA iFOB (test strip) | Qualitative | Immunochromatographic | 50^1^ | 50^1^ | Inverness Medical Innovation, Inc., now Alere, Inc., Waltham, MA
FOB advanced | FOB advanced | Qualitative | Immunochromatographic | 50^†^ | -- | ulti med, Ahrensburg, Germany
PreventID CC | PreventID CC | Qualitative | Immunochromatographic | 10^**^ | -- | Preventis, Bensheim, Germany
Bionexia (Hb) | Bionexia FOBplus | Qualitative | Immunochromatographic | 40^†^ | -- | Biomerieux, Marcy l’Etoile, France [originally supplied by Dima Diagnostika]
Bionexia (Hb-Hp) | Bionexia Hb-Hp Complex | Qualitative | Immunochromatographic | 25^†^ | -- | Biomerieux, Marcy l’Etoile, France [originally supplied by Dima Diagnostika]
Magstream/Hemselect | HemeSelect, Immudia HemSp | Qualitative | Reverse passive hemagglutination | Samples diluted 1:8 showing erythrocyte agglutination | 100–200^†^ | Fujirebio, Tokyo, Japan, distributed by Beckman-Coulter, Inc., Brea, CA
Magstream/Hemselect | Magstream 1000/Hem SP | Quantitative^‡^ | Magnetic particle agglutination | 20^**^ | 67^**^ | Fujirebio, Tokyo, Japan
RIDASCREEN (Hb) | RIDASCREEN Hemoglobin | Quantitative^‡^ | Enzyme immunoassay | -- | 2^†^ | R-Biopharm AG, Darmstadt, Germany
RIDASCREEN (Hb-Hp) | RIDASCREEN Hemoglobin-Haptoglobin Complex | Quantitative^‡^ | Enzyme immunoassay | -- | 2^†^ | R-Biopharm AG, Darmstadt, Germany
FOB Gold | FOB Gold | Quantitative^‡^ | Latex agglutination, measured as optical change | 100^**^ [CE marked for user-defined cutoff] | 17^**^ | Sentinel Diagnostics, Milan, Italy
Hemo Techt | Hemo Techt NS-Plus C system | Quantitative^‡^ | Colloidal gold agglutination measured as optical change | -- | 19 | Alfresa Pharma Co., Osaka, Japan
HM-JACK | HM-JACK | Quantitative^‡^ | Latex agglutination, measured as optical change | 8 | 20 | Kyowa Medex Co., Ltd., Tokyo, Japan

1 per Levy 2014^5^

* from FDA summary

† from manufacturer website or calculated from information provided

‡ Quantitative results may be transformed into qualitative results using the manufacturer’s or a user-defined cutoff. In the US, quantitative FITs have been FDA-cleared only for qualitative use.

** from published literature

Appendix D Table 2 Key Question 1: Direct Visualization Comparative Effectiveness Studies

Author, year; (Trial name) | Round | Test | Test pos, % | Group analyzed | n CRC/n Analyzed | (%) | Interval CRC | (%)
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Total | 9/1426 | (0.63) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Distal | 4/1426 | (0.28) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Proximal | 5/1426 | (0.35) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Stage I | 7/1426 | (0.49) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Stage II | 1/1426 | (0.07) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Stage III | 1/1426 | (0.07) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Stage IV | 0/1426 | (0) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Total | 13/2435 | (0.53) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Distal | 11/2435 | (0.45) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Proximal | 2/2435 | (0.08) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Stage I | 10/2435 | (0.41) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Stage II | 0/2435 | (0) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Stage III | 3/2435 | (0.12) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Stage IV | 0/2435 | (0) | NR | NR
Regge, 2017^7^; (Proteus 2) | 1 | CTC | 10.2 | Total | 9/2673 | (0.003) | NR | NR
Regge, 2017^7^; (Proteus 2) | 1 | CTC | 10.2 | Male | 7/1375 | (0.005) | NR | NR
Regge, 2017^7^; (Proteus 2) | 1 | CTC | 10.2 | Female | 2/1298 | (0.001) | NR | NR
Regge, 2017^7^; (Proteus 2) | 1 | FS | 10.1 | Total | 10/2595 | (0.004) | NR | NR
Regge, 2017^7^; (Proteus 2) | 1 | FS | 10.1 | Male | 5/1329 | (0.004) | NR | NR
Regge, 2017^7^; (Proteus 2) | 1 | FS | 10.1 | Female | 5/1266 | (0.004) | NR | NR
Sali, 2016^8^; (SAVE) | 1 | Colonoscopy | NR | Total | 0/153 | (0.0) | NR | NR
Sali, 2016^8^; (SAVE) | 1 | Colonoscopy | NR | Proximal | 0/153 | (0.0) | NR | NR
Sali, 2016^8^; (SAVE) | 1 | CTC (Reduced cathartic preparation CTC + Full cathartic preparation CTC) | 9.8 | Total | 7/1286 | (0.005) | NR | NR
Sali, 2016^8^; (SAVE) | 1 | CTC (Reduced cathartic preparation CTC + Full cathartic preparation CTC) | 9.8 | Rectosigmoid | 4/1286 | (0.003) | NR | NR
Sali, 2016^8^; (SAVE) | 1 | CTC (Reduced cathartic preparation CTC + Full cathartic preparation CTC) | 9.8 | Proximal | 3/1286 | (0.002) | NR | NR
Stoop, 2012^9^; (COCOS) | 1 | Colonoscopy | 8.7 | Total | 7/1276 | (0.005) | NR | NR
Stoop, 2012^9^; (COCOS) | 1 | Colonoscopy | 8.7 | Rectosigmoid | 5/1276 | (0.004) | NR | NR
Stoop, 2012^9^; (COCOS) | 1 | Colonoscopy | 8.7 | Proximal | 2/1276 | (0.002) | NR | NR
Stoop, 2012^9^; (COCOS) | 1 | CTC | 8.6 | Total | 5/982 | (0.005) | NR | NR
Stoop, 2012^9^; (COCOS) | 1 | CTC | 8.6 | Rectosigmoid | 4/982 | (0.004) | NR | NR
Stoop, 2012^9^; (COCOS) | 1 | CTC | 8.6 | Proximal | 1/982 | (0.001) | NR | NR
Segnan, 2007^10^; (SCORE III) | 1 | Colonoscopy | 5.1 | Total | 13/1596 | (0.8) | NR | NR
Segnan, 2007^10^; (SCORE III) | 1 | FS | 7.2 | Total | 12/1922 | (0.6) | NR | NR

Abbreviations: COCOS = COlonoscopy or COlonography for Screening; CRC = colorectal cancer; CTC = computed tomographic colonography; FS = flexible sigmoidoscopy; n = number; NR = not reported; SCORE = Screening for COlon Rectum.

Appendix D Table 3 Key Question 1: Direct Visualization vs. Stool Tests Comparative Effectiveness

Author, year | Round | Test | Test pos | Group analyzed | n CRC/n Analyzed | (%) | N Interval CRC/n Analyzed | (%)
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Total | 9/1426 | (0.63) | 1/NR | (0.01)
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Distal | 4/1426 | (0.28) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Proximal | 5/1426 | (0.35) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Stage I | 7/1426 | (0.49) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Stage II | 1/1426 | (0.07) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Stage III | 1/1426 | (0.07) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | Colonoscopy | NR | Stage IV | 0/1426 | (0) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Total | 13/2435 | (0.53) | 6/NR | (0.09)
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Distal | 11/2435 | (0.45) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Proximal | 2/2435 | (0.08) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Stage I | 10/2435 | (0.41) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Stage II | 0/2435 | (0) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Stage III | 3/2435 | (0.12) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 1 | FS | 9.0 | Stage IV | 0/2435 | (0) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 4 | FIT | 19.1 | Total | 83/10743 | (0.77) | 19/NR | (0.13)
Grobbee, 2019; (COCOS and others)^6^ | 4 | FIT | 19.1 | Distal | 56/10743 | (0.52) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 4 | FIT | 19.1 | Proximal | 27/10743 | (0.25) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 4 | FIT | 19.1 | Stage I | 45/10743 | (0.42) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 4 | FIT | 19.1 | Stage II | 11/10743 | (0.10) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 4 | FIT | 19.1 | Stage III | 26/10743 | (0.24) | NR | NR
Grobbee, 2019; (COCOS and others)^6^ | 4 | FIT | 19.1 | Stage IV | 1/10743 | (0.009) | NR | NR
Sali, 2016^8^; SAVE | 1 | Colonoscopy | NR | Total | 0/153 | (0.0) | NR | NR
Sali, 2016^8^; SAVE | 1 | Colonoscopy | NR | Rectosigmoid | 0/153 | (0.0) | NR | NR
Sali, 2016^8^; SAVE | 1 | Colonoscopy | NR | Proximal | 0/153 | (0.0) | NR | NR
Sali, 2016^8^; SAVE | 1 | CTC (Reduced cathartic preparation CTC + Full cathartic preparation CTC) | r-CTC: 9.8%, f-CTC: 9.8% | Total | 7/1286 | (0.005) | NR | NR
Sali, 2016^8^; SAVE | 1 | CTC (Reduced cathartic preparation CTC + Full cathartic preparation CTC) | r-CTC: 9.8%, f-CTC: 9.8% | Rectosigmoid | 4/1286 | (0.003) | NR | NR
Sali, 2016^8^; SAVE | 1 | CTC (Reduced cathartic preparation CTC + Full cathartic preparation CTC) | r-CTC: 9.8%, f-CTC: 9.8% | Proximal | 3/1286 | (0.002) | NR | NR
Sali, 2016^8^; SAVE | 1 | FIT (OC-Sensor) | NR | Total | 6/4677 | (0.001) | NR | NR
Sali, 2016^8^; SAVE | 1 | FIT (OC-Sensor) | NR | Rectosigmoid | 3/4677 | (0.0006) | NR | NR
Sali, 2016^8^; SAVE | 1 | FIT (OC-Sensor) | NR | Proximal | 3/4677 | (0.0006) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | Colonoscopy | 32.3% (any finding); 10.3% (AN) | Total - Intention to screen | 30/26703 | (0.001) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | Colonoscopy | 32.3% (any finding); 10.3% (AN) | Total - As screened | 27/5059 | (0.005) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | Colonoscopy | 32.3% (any finding); 10.3% (AN) | Stage I - As Screened | 19/5059 | (0.004) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | Colonoscopy | 32.3% (any finding); 10.3% (AN) | Stage II - As Screened | 6/5059 | (0.001) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | Colonoscopy | 32.3% (any finding); 10.3% (AN) | Stage III - As Screened | 2/5059 | (0.0004) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | Colonoscopy | 32.3% (any finding); 10.3% (AN) | Proximal - Intention to screen | 6/26703 | (0.0002) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | Colonoscopy | 32.3% (any finding); 10.3% (AN) | Distal - Intention to screen | 23/26703 | (0.0009) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | FIT (OC-Sensor) | 7.2 | Total - Intention to screen | 33/26599 | (0.001) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | FIT (OC-Sensor) | 7.2 | Total - As screened | 36/10611 | (0.003) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | FIT (OC-Sensor) | 7.2 | Stage I - As Screened | 24/10611 | (0.002) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | FIT (OC-Sensor) | 7.2 | Stage II - As Screened | 6/10611 | (0.0006) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | FIT (OC-Sensor) | 7.2 | Stage IV - As Screened | 0/10611 | (0.0) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | FIT (OC-Sensor) | 7.2 | Stage III - As Screened | 6/10611 | (0.0006) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | FIT (OC-Sensor) | 7.2 | Stage IV - As Screened | 0/5059 | (0.0) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | FIT (OC-Sensor) | 7.2 | Proximal - Intention to screen | 11/26599 | (0.0004) | NR | NR
Quintero, 2012^11^; COLONPREV | 1 | FIT (OC-Sensor) | 7.2 | Distal - Intention to screen | 23/26599 | (0.0009) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | Colonoscopy | 5.1 | Total | 13/1596 | (0.008) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | Colonoscopy | 5.1 | Male | 8/811 | (0.01) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | Colonoscopy | 5.1 | Female | 5/785 | (0.006) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | Colonoscopy | 5.1 | Age 55–59 | 4/899 | (0.004) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | Colonoscopy | 5.1 | Age 60–64 | 9/697 | (0.01) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FIT (Immudia-HemSp) | 4.7 | Total | 2/1965 | (0.001) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FIT (Immudia-HemSp) | 4.7 | Male | 0/904 | (0.0) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FIT (Immudia-HemSp) | 4.7 | Female | 2/1061 | (0.002) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FIT (Immudia-HemSp) | 4.7 | Age 55–59 | 0/1090 | (0.0) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FIT (Immudia-HemSp) | 4.7 | Age 60–64 | 2/875 | (0.002) | NR | NR
Hol, 2010^*^,^12^ | 1 | gFOBT (Hemoccult II) | 2.8 | Total | 6/2351 | (0.3) | NR | NR
Hol, 2010^*^,^12^ | 1 | gFOBT (Hemoccult II) | 2.8 | Stage I | 1/2351 | NR | NR | NR
Hol, 2010^*^,^12^ | 1 | gFOBT (Hemoccult II) | 2.8 | Stage II | 2/2351 | NR | NR | NR
Hol, 2010^*^,^12^ | 1 | gFOBT (Hemoccult II) | 2.8 | Stage III | 2/2351 | NR | NR | NR
Hol, 2010^*^,^12^ | 1 | gFOBT (Hemoccult II) | 2.8 | Stage IV | 1/2351 | NR | NR | NR
Hol, 2010^*^,^12^ | 1 | FIT (OC-Sensor Micro) | 4.8 | Total | 14/2975 | (0.5) | NR | NR
Hol, 2010^*^,^12^ | 1 | FIT (OC-Sensor Micro) | 4.8 | Stage I | 5/2975 | NR | NR | NR
Hol, 2010^*^,^12^ | 1 | FIT (OC-Sensor Micro) | 4.8 | Stage II | 7/2975 | NR | NR | NR
Hol, 2010^*^,^12^ | 1 | FIT (OC-Sensor Micro) | 4.8 | Stage III | 2/2975 | NR | NR | NR
Hol, 2010^*^,^12^ | 1 | FIT (OC-Sensor Micro) | 4.8 | Stage IV | 0/2975 | (0.0) | NR | NR
Hol, 2010^*^,^12^ | 1 | FS | 10.2 | Total | 8/1386 | (0.6) | NR | NR
Hol, 2010^*^,^12^ | 1 | FS | 10.2 | Stage I | 6/1386 | NR | NR | NR
Hol, 2010^*^,^12^ | 1 | FS | 10.2 | Stage II | 0/1386 | (0.0) | NR | NR
Hol, 2010^*^,^12^ | 1 | FS | 10.2 | Stage III | 2/1386 | NR | NR | NR
Hol, 2010^*^,^12^ | 1 | FS | 10.2 | Stage IV | 0/1386 | (0.0) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FIT (Immudia-HemSp) | 4.7 | Total | 2/1965 | (0.1) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FIT (Immudia-HemSp) | 4.7 | Male | 0/904 | (0.0) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FIT (Immudia-HemSp) | 4.7 | Female | 2/1061 | (0.002) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FIT (Immudia-HemSp) | 4.7 | Age 55–59 | 0/1090 | (0.0) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FIT (Immudia-HemSp) | 4.7 | Age 60–64 | 2/875 | (0.002) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FS | 7.2 | Total | 12/1922 | (0.6)^‡^ | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FS | 7.2 | Male | 9/985 | (0.009) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FS | 7.2 | Female | 3/937 | (0.003) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FS | 7.2 | Age 55–59 | 7/1100 | (0.006) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FS | 7.2 | Age 60–64 | 5/822 | (0.006) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FS | 7.2 | Proximal | 0/1922 | (0.0) | NR | NR
Segnan, 2007^10^; SCORE III | 1 | FS | 7.2 | Distal | 12/1922 | (0.006) | NR | NR
Segnan, 2005^13^; SCORE II | 1 | FIT (Immudia-HemSp) | 4.6 | Total | 8/2336 | (0.3) | NR | NR
Segnan, 2005^13^; SCORE II | 1 | FIT (Immudia-HemSp) | 4.6 | Male | 6/1032 | (0.006) | NR | NR
Segnan, 2005^13^; SCORE II | 1 | FIT (Immudia-HemSp) | 4.6 | Female | 2/1304 | (0.002) | NR | NR
Segnan, 2005^13^; SCORE II | 1 | FIT (Immudia-HemSp) | 4.6 | Age 55–59 | 3/917 | (0.003) | NR | NR
Segnan, 2005^13^; SCORE II | 1 | FIT (Immudia-HemSp) | 4.6 | Age 60–64 | 5/1419 | (0.004) | NR | NR
Segnan, 2005^13^; SCORE II | 1 | FS +/− FIT (Immudia-HemSp) | 7.6^**^ | Total | 14/4075 | (0.3) | NR | NR
Segnan, 2005^13^; SCORE II | 1 | FS +/− FIT (Immudia-HemSp) | 7.6^**^ | Male | 9/2013 | (0.004) | NR | NR
Segnan, 2005^13^; SCORE II | 1 | FS +/− FIT (Immudia-HemSp) | 7.6^**^ | Female | 5/2012 | (0.002) | NR | NR
Segnan, 2005^13^; SCORE II | 1 | FS +/− FIT (Immudia-HemSp) | 7.6^**^ | Age 55–59 | 4/1661 | (0.002) | NR | NR
Segnan, 2005^13^; SCORE II | 1 | FS +/− FIT (Immudia-HemSp) | 7.6^**^ | Age 60–64 | 10/2364 | (0.004) | NR | NR
Rasmussen, 1999^14^ | 1 | gFOBT (Hemoccult II) | 2.4 | Total | 4/3055 | (0.1) | 18/2210^†^ | (0.8)
Rasmussen, 1999^14^ | 1 | gFOBT (Hemoccult II) + FS | 19.4 | Total | 12/2222 | (0.5)^‡^ | 8/3051^†^,^‡^ | (0.3)
Verne, 1998^15^ | 1 | gFOBT (Hemoccult II) | 8.2 | Total | 1/854 | (0.1) | NR | NR
Verne, 1998^15^ | 1 | FS | 9.9 | Total | 4/1116 | (0.4) | NR | NR
Verne, 1998^15^ | 1 | gFOBT (Hemoccult II) + FS | NR | Total | 1/401 | (0.2) | NR | NR
Berry, 1997^16^ | 1 | gFOBT (Hemoccult II) | NR | Total | 2/3128 | (0.0006) | NR | NR
Berry, 1997^16^ | 1 | gFOBT (Hemoccult II) + FS | NR | Total | 3/3243 | (0.0009) | NR | NR
Brevinge, 1997^17^ | 1 | gFOBT (Hemoccult II) | 4.4 | Total | 2/1893 | (0.1) | NR | NR
Brevinge, 1997^17^ | 1 | gFOBT (Hemoccult II) | 4.4 | Dukes’ Stage B | 1/1893 | (0.0005) | NR | NR
Brevinge, 1997^17^ | 1 | gFOBT (Hemoccult II) | 4.4 | Dukes’ Stage C | 1/1893 | (0.0005) | NR | NR
Brevinge, 1997^17^ | 1 | FS | NR | Total | 5/1371 | (0.4) | NR | NR
Brevinge, 1997^17^ | 1 | FS | NR | Dukes’ Stage A | 4/1371 | (0.003) | NR | NR
Brevinge, 1997^17^ | 1 | FS | NR | Dukes’ Stage B | 1/1371 | (0.0007) | NR | NR

* p<0.05

** Test positivity includes flexible sigmoidoscopy by patient choice.

† Followup for 24–62 months

‡ p<0.01

Abbreviations: CRC = colorectal cancer; FIT = fecal immunochemical test; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; n = number; NR = not reported; pos = positivity; SCORE = Screening for COlon Rectum.

Appendix D Table 4 Key Question 1: Stool Testing vs. Stool Testing Comparative Effectiveness

Author, year | Round | Test | Test pos | Screened group | n CRC/n Analyzed | (%) | Interval CRC | (%)
Schreuders, 2019^18^ | 1 | FIT (OC-Sensor Micro), 1 sample | 19 | Total | 29/5986 | (0.5) | NR | NR
Schreuders, 2019^18^ | 1 | FIT (OC-Sensor Micro), 2 samples | 28 | Total | 13/1875 | (0.7) | NR | NR
Schreuders, 2019^18^ | 2 | FIT (OC-Sensor Micro), 1 sample | 19 | Total | 11/5200 | (0.2) | NR | NR
Schreuders, 2019^18^ | 2 | FIT (OC-Sensor Micro), 2 samples | 28 | Total | 4/1582 | (0.3) | NR | NR
Schreuders, 2019^18^ | 3 | FIT (OC-Sensor Micro), 1 sample | 19 | Total | 8/4998 | (0.2) | NR | NR
Schreuders, 2019^18^ | 3 | FIT (OC-Sensor Micro), 2 samples | 28 | Total | 6/1474 | (0.4) | NR | NR
Schreuders, 2019^18^ | 4 | FIT (FOB Gold), 1 sample | 19 | Total | 5/4385 | (0.1) | NR | NR
Schreuders, 2019^18^ | 4 | FIT (OC-Sensor Micro), 2 samples | 28 | Total | 3/1171 | (0.3) | NR | NR
Schreuders, 2019^18^ | 1–4 | FIT (OC-Sensor Micro, FOB Gold), 1 sample | 19 | Total | 53/7310 | (0.7) | NR | NR
Schreuders, 2019^18^ | 1–4 | FIT (OC-Sensor Micro, FOB Gold), 1 sample | 19 | Male | 33/3530 | (0.9) | NR | NR
Schreuders, 2019^18^ | 1–4 | FIT (OC-Sensor Micro, FOB Gold), 1 sample | 19 | Female | 20/3780 | (0.5) | NR | NR
Schreuders, 2019^18^ | 1–4 | FIT (OC-Sensor Micro), 2 samples | 28 | Total | 26/2269 | (1.1) | NR | NR
Schreuders, 2019^18^ | 1–4 | FIT (OC-Sensor Micro), 2 samples | 28 | Male | 15/1101 | (1.4) | NR | NR
Schreuders, 2019^18^ | 1–4 | FIT (OC-Sensor Micro), 2 samples | 28 | Female | 11/1168 | (0.9) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Total | 5/2138 | (0.2) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Male | 2/960 | (0.2) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Male 50–54 | 0/560 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Male 55–59 | 0/97 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Male 60–64 | 0/101 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Male 65–69 | 1/133 | (0.8) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Male 70–74 | 1/69 | (1.4) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Female | 3/1178 | (0.3) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Female 50–54 | 0/808 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Female 55–59 | 0/99 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Female 60–64 | 1/76 | (1.3) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Female 65–69 | 1/124 | (0.8) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | Female 70–74 | 1/71 | (1.4) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | 50–54 years | 0/1368 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | 55–59 years | 0/196 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | 60–64 years | 1/177 | (0.6) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | 65–69 years | 2/257 | (0.8) | NR | NR
Passamonti, 2018^19^ | 1 | FIT (OC-Sensor) | 6.5 | 70–74 years | 2/140 | (1.4) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Total | 5/2109 | (0.2) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Male | 3/975 | (0.3 | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Male 50–54 | 2/659 | (0.3) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Male 55–59 | 0/91 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Male 60–64 | 0/75 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Male 65–69 | 0/101 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Male 70–74 | 1/49 | (2.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Female | 2/1134 | (0.2) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Female 50–54 | 2/771 | (0.3) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Female 55–59 | 0/88 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Female 60–64 | 0/114 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Female 65–69 | 0/109 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | Female 70–74 | 0/52 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | 50–54 years | 4/1430 | (0.3) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | 55–59 years | 0/179 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | 60–64 years | 0/189 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | 65–69 years | 0/210 | (0.0) | NR | NR
Passamonti, 2018^19^ | 1 | HM-JACKarc, cutoff 20 ug Hb/g feces | 6.2 | 70–74 years | 1/101 | (1.0) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Total | 14/12444 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Male | 7/5687 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Male 50–54 | 0/440 | (0.0) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Male 55–59 | 0/860 | (0.0) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Male 60–64 | 2/1844 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Male 65–69 | 3/1452 | (0.2) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Male-70–74 | 2/1091 | (0.2) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Female | 7/6757 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Female 50–54 | 1/575 | (0.2) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Female 55–59 | 0/1050 | (0.0) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Female 60–64 | 3/2198 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Female 65–69 | 2/1703 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | Female 70–74 | 1/1231 | (0.05) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | 50–54 years | 1/1015 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | 55–59 years | 0/1910 | (0.0) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | 60–64 years | 5/4042 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | 65–69 years | 5/3155 | (0.2) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (OC-Sensor) | 5.6 | 70–74 years | 3/2322 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Total | 16/12307 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Male | 3/5601 | (0.05) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Male 50–54 | 0/457 | (0.0) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Male 55–59 | 0/876 | (0.0) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Male 60–64 | 1/1692 | (0.06) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Male 65–69 | 2/1467 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Male 70–74 | 0/1109 | (0.0) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Female | 13/6706 | (0.2) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Female 50–54 | 0/565 | (0.0) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Female 55–59 | 1/1102 | (0.09) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Female 60–64 | 3/2162 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Female 65–69 | 4/1687 | (0.2) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | Female 70–74 | 5/1190 | (0.4) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | 50–54 years | 0/1022 | (0.0) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | 55–59 years | 1/1978 | (0.05) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | 60–64 years | 4/3854 | (0.1) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | 65–69 years | 6/3154 | (0.2) | NR | NR
Passamonti, 2018^19^ | 2 | FIT (HM-JACKarc) | 4.4 | 70–74 years | 5/2299 | (0.2) | NR | NR
Santare, 2016^20^ | 1 | FIT (FOB Gold) | NR | 10 ug/g cutoff | 5/2094 | (0.2) | NR | NR
Santare, 2016^20^ | 1 | FIT (FOB Gold) | NR | 15 ug/g cutoff | 5/2094 | (0.2) | NR | NR
Santare, 2016^20^ | 1 | FIT (FOB Gold) | NR | 20 ug/g cutoff | 5/2094 | (0.2) | NR | NR
Santare, 2016^20^ | 1 | FIT (OC-Sensor) | NR | 10 ug/g cutoff | 1/2303 | (0.04) | NR | NR
Santare, 2016^20^ | 1 | FIT (OC-Sensor) | NR | 15 ug/g cutoff | 1/2303 | (0.04) | NR | NR
Santare, 2016^20^ | 1 | FIT (OC-Sensor) | NR | 20 ug/g cutoff | 1/2303 | (0.04) | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Total | 35/11153 | (0.3) | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Male | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Male 50–54 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Male 55–59 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Male 60–64 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Male 65–69 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Female | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Female 50–54 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Female 55–60 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Female 60–64 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Female 65–69 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Stage I | 18/11153 | (0.2) | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Stage II | 10/11153 | (0.09) | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Stage III | 6/11153 | (0.05) | NR | NR
Zubero, 2014^21^ | 1 | FIT (OC-Sensor), 1 sample | 6.6 | Stage IV | 1/11153 | (0.009) | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Total | 44/11725 | (0.4) | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Male | 5529 | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Male 50–54 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Male 55–59 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Male 60–64 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Male 65–69 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Female | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Female 50–54 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Female 55–60 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Female 60–64 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Female 65–69 | NR | NR | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Stage I | 17/11725 | (0.1) | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Stage II | 8/11725 | (0.07) | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Stage III | 13/11725 | (0.1) | NR | NR
Zubero, 2014^21^ | 1 | FIT (FOB Gold), 1 sample | 8.5 | Stage IV | 5/11725 | (0.04) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 1 | FIT (OC-Sensor Micro), 1-year interval | 8.4 | Total – As screened | 4/1543 | (0.3) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 1 | FIT (OC-Sensor Micro), 2-year interval | 8.4 | Total – As screened | 10/1481 | (0.7) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 1 | FIT (OC-Sensor Micro), 3-year interval | 8.4 | Total – As screened | 8/1499 | (0.5) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 1 | FIT (OC-Sensor Micro), all intervals combined | 8.4 | Total – As screened | 22/4523 | (0.5) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 1 | FIT (OC-Sensor Micro), all intervals combined | 8.4 | Stage I – As screened | 14/4523 | (0.3) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 1 | FIT (OC-Sensor Micro), all intervals combined | 8.4 | Stage II – As screened | 3/4523 | (0.07) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 1 | FIT (OC-Sensor Micro), all intervals combined | 8.4 | Stage III – As screened | 5/4523 | (0.1) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 2 | FIT (OC-Sensor Micro), 1-year interval | 6.0 | Total – As screened | 1/1286 | (0.08) | NR | (0.0)
van Roon, 2013^*^,^22^; (intervals) | 2 | FIT (OC-Sensor Micro), 2-year interval | 6.0 | Total – As screened | 4/1280 | (0.3) | NR | (0.08)
van Roon, 2013^*^,^22^; (intervals) | 2 | FIT (OC-Sensor Micro), 3-year interval | 6.0 | Total – As screened | 2/1298 | (0.2) | NR | (0.2)
van Roon, 2013^*^,^22^; (intervals) | 2 | FIT (OC-Sensor Micro), all intervals combined | | Total – As screened | 7/3864 | (0.2) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 2 | FIT (OC-Sensor Micro), all intervals combined | | Stage I – As screened | 5/3864 | (0.1) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 2 | FIT (OC-Sensor Micro), all intervals combined | | Stage II – As screened | 1/3864 | (0.03) | NR | NR
van Roon, 2013^*^,^22^; (intervals) | 2 | FIT (OC-Sensor Micro), all intervals combined | | Stage III – As screened | 1/3864 | (0.03) | NR | NR
Hol, 2010^*^,^12^ | 1 | gFOBT (Hemoccult II) | 2.8 | Total | 6/2351 | (0.3) | NR | NR
Hol, 2010^*^,^12^ | 1 | gFOBT (Hemoccult II) | 2.8 | Stage I | 1/2351 | (0.04) | NR | NR
Hol, 2010^*^,^12^ | 1 | gFOBT (Hemoccult II) | 2.8 | Stage II | 2/2351 | (0.08) | NR | NR
Hol, 2010^*^,^12^ | 1 | gFOBT (Hemoccult II) | 2.8 | Stage III | 2/2351 | (0.08) | NR | NR
Hol, 2010^*^,^12^ | 1 | gFOBT (Hemoccult II) | 2.8 | Stage IV | 1/2351 | (0.04) | NR | NR
Hol, 2010^*^,^12^ | 1 | FIT (OC-Sensor Micro) | 4.8 | Total | 14/2975 | (0.5) | NR | NR
Hol, 2010^*^,^12^ | 1 | FIT (OC-Sensor Micro) | 4.8 | Stage I | 5/2975 | (0.17) | NR | NR
Hol, 2010^*^,^12^ | 1 | FIT (OC-Sensor Micro) | 4.8 | Stage II | 7/2975 | (0.24) | NR | NR
Hol, 2010^*^,^12^ | 1 | FIT (OC-Sensor Micro) | 4.8 | Stage III | 2/2975 | (0.07) | NR | NR
Hol, 2010^*^,^12^ | 1 | FIT (OC-Sensor Micro) | 4.8 | Stage IV | 0/2975 | (0.0) | NR | NR
van Rossum, 2008^23^ | 1 | gFOBT (Hemoccult II) | 2.4%, 2.8% (Amsterdam region only) | Total | 11/10301 | (0.001) | NR | NR
van Rossum, 2008^23^ | 1 | gFOBT (Hemoccult II) | 2.4%, 2.8% (Amsterdam region only) | Male | 5/4924 | (0.001) | NR | NR
van Rossum, 2008^23^ | 1 | gFOBT (Hemoccult II) | 2.4%, 2.8% (Amsterdam region only) | Female | 6/5377 | (0.001) | NR | NR
van Rossum, 2008^23^ | 1 | gFOBT (Hemoccult II) | 2.4%, 2.8% (Amsterdam region only) | Age <60 years | 8/5109 | (0.002) | NR | NR
van Rossum, 2008^23^ | 1 | gFOBT (Hemoccult II) | 2.4%, 2.8% (Amsterdam region only) | Age ≥60 years | 3/5192 | (0.0006) | NR | NR
van Rossum, 2008^23^ | 1 | FIT (OC-Sensor Micro), single sample | 5.5%, 8.1% (Amersterdam region only) | Total | 24/10322 | (0.002) | NR | NR
van Rossum, 2008^23^ | 1 | FIT (OC-Sensor Micro), single sample | 5.5%, 8.1% (Amersterdam region only) | Male | 16/5037 | (0.003) | NR | NR
van Rossum, 2008^23^ | 1 | FIT (OC-Sensor Micro), single sample | 5.5%, 8.1% (Amersterdam region only) | Female | 8/5285 | (0.002) | NR | NR
van Rossum, 2008^23^ | 1 | FIT (OC-Sensor Micro), single sample | 5.5%, 8.1% (Amersterdam region only) | Age <60 years | 18/4986 | (0.004) | NR | NR
van Rossum, 2008^23^ | 1 | FIT (OC-Sensor Micro), single sample | 5.5%, 8.1% (Amersterdam region only) | Age ≥60 years | 6/5336 | (0.001) | NR | NR
Faivre, 2012^24^ | 1 | gFOBT (Hemoccult II) | 5.2 | Total | 117/85149 | (0.1) | NR | NR
Faivre, 2012^24^ | 1 | FIT (FOB Gold), 2 samples | 5.2 | Total | 91/32215 | (0.3)^†^ | NR | NR
Faivre, 2012^24^ | 1 | FIT (Magstream), 2 samples | 4.6 | Total | 65/19244 | (0.3)^†^ | NR | NR
Faivre, 2012^24^ | 1 | FIT (OC-Sensor), 2 samples | 3.7 | Total | 92/33690 | (0.3)^†^ | NR | NR

* Overlapping study populations

† p<0.01 versus gFOBT

Abbreviations: CRC = colorectal cancer; FIT = fecal immunochemical test; gFOBT = guaiac fecal occult blood test; n = number; NR = not reported; Pos = positivity.

Appendix D Table 5 Key Question 2: Results for FIT Test Accuracy (Registry Followup)

Author, year | Test name | Cutoff, μg Hb/g | Screened group | N analyzed | CRC Sensitivity (95% CI) | CRC Specificity (95% CI)
Allison, 1996^25^ | HemeSelect | 300 | All | 7,493 | 0.688 (0.511, 0.864) | 0.944 (0.938, 0.949)
Allison, 2007^26^ | FlexSure OBT | 300 | Distal | 5,356 | 0.818 (0.478, 0.968) | 0.969 (0.964, 0.974)
Arana-Arri, 2017^27^ | OC-Sensor | 20 | All | 296,378 | 0.88 (0.86, 0.90)^*^ | 0.94 (0.94, 0.94)^*^
Arana-Arri, 2017^27^ | OC-Sensor | 20 | 50–54 years | NR | 0.86 (0.80, 0.90)^*^ | NR
Arana-Arri, 2017^27^ | OC-Sensor | 20 | 55–59 years | NR | 0.88 (0.84, 0.91)^*^ | NR
Arana-Arri, 2017^27^ | OC-Sensor | 20 | 60–64 years | NR | 0.87 (0.83, 0.90)^*^ | NR
Arana-Arri, 2017^27^ | OC-Sensor | 20 | 65–69 years | NR | 0.91 (0.88, 0.94)^*^ | NR
Arana-Arri, 2017^27^ | OC-Sensor | 20 | Female | NR | 0.88 (0.84, 0.91)^*^ | NR
Arana-Arri, 2017^27^ | OC-Sensor | 20 | Male | NR | 0.89 (0.86, 0.91)^*^ | NR
Castiglione, 2007^28^ | OC-Hemodia | 20^*^ | All | 27,503 | 0.81 (0.71, 0.88)^*^ | 0.95 (0.95, 0.95)^*^
Chen, 2011^29^ | OC-Sensor | 20 | All | 46,355 | 0.51 (0.44, 0.59)^*^ | 0.96 (0.96, 0.96)^*^
Chen, 2016^30^ | OC-Sensor | 20 | All | 512,066 | 0.933 (0.916, 0.949) | 0.960 (0.959, 0.960)
Chen, 2016^30^ | OC-Sensor | 20 | <50 years | 371,021 | 0.930 (0.891, 0.970) | 0.966 (0.965, 0.967)
Chen, 2016^30^ | OC-Sensor | 20 | ≥50 years | 141,045 | 0.933 (0.915, 0.951) | 0.944 (0.943, 0.945)
Chen, 2016^30^ | OC-Sensor | 20 | Female | 268,156 | 0.947 (0.925, 0.970) | 0.965 (0.964, 0.966)
Chen, 2016^30^ | OC-Sensor | 20 | Female <50 years | 191,345 | 0.933 (0.877, 0.990) | 0.970 (0.969, 0.970)
Chen, 2016^30^ | OC-Sensor | 20 | Female ≥50 years | 76,811 | 0.950 (0.926, 0.975) | 0.954 (0.952, 0.955)
Chen, 2016^30^ | OC-Sensor | 20 | Male | 243,910 | 0.923 (0.900, 0.945) | 0.954 (0.953, 0.955)
Chen, 2016^30^ | OC-Sensor | 20 | Male <50 years | 179,676 | 0.928 (0.872, 0.983) | 0.962 (0.961, 0.963)
Chen, 2016^30^ | OC-Sensor | 20 | Male ≥50 years | 64,234 | 0.922 (0.897, 0.946) | 0.932 (0.930, 0.934)
Chen, 2018^31^ | HM-Jack | 20 | All | 208,929 | 0.74 (0.70, 0.77)^*^ | 0.96 (0.96, 0.96)^*^
Chen, 2018^31^ | OC-Sensor | 10 | Female 60–69 years | NR | 0.80 (NR) | 0.923 (NR)
Chen, 2018^31^ | OC-Sensor | 10 | Female 60–69 years | NR | 0.804 (NR) | 0.923 (NR)
Chen, 2018^31^ | OC-Sensor | 12 | All | NR | 0.815 (NR) | 0.937 (NR)
Chen, 2018^31^ | OC-Sensor | 12 | Female 50–59 years | NR | 0.822 (NR) | 0.95 (NR)
Chen, 2018^31^ | OC-Sensor | 12 | Male 50–59 years | NR | 0.838 (NR) | 0.935 (NR)
Chen, 2018^31^ | OC-Sensor | 15 | Male 50–59 years | NR | 0.819 (NR) | 0.95 (NR)
Chen, 2018^31^ | OC-Sensor | 16 | All | NR | 0.80 (NR) | 0.946 (NR)
Chen, 2018^31^ | OC-Sensor | 16 | Female 50–59 years | NR | 0.811 (NR) | 0.964 (NR)
Chen, 2018^31^ | OC-Sensor | 16 | Female 60–69 years | NR | 0.76 (NR) | 0.95 (NR)
Chen, 2018^31^ | OC-Sensor | 16 | Male 50–59 years | NR | 0.819 (NR) | 0.950 (NR)
Chen, 2018^31^ | OC-Sensor | 16 | Male 60–69 years | NR | 0.80 (NR) | 0.938 (NR)
Chen, 2018^31^ | OC-Sensor | 18 | Female 50–59 years | NR | 0.809 (NR) | 0.968 (NR)
Chen, 2018^31^ | OC-Sensor | 18 | Female 60–69 years | NR | 0.747 (NR) | 0.958 (NR)
Chen, 2018^31^ | OC-Sensor | 18 | Male 60–69 years | NR | 0.799 (NR) | 0.938 (NR)
Chen, 2018^31^ | OC-Sensor | 20 | All | 723,113 | 0.787 (0.769, 0.804) | 0.962 (0.961, 0.963)
Chen, 2018^31^ | OC-Sensor | 20 | Female 50–59 years | 278,722 | 0.76 (0.72, 0.80)^*^ | NR
Chen, 2018^31^ | OC-Sensor | 20 | Female 60–69 years | 167,349 | 0.69 (0.65, 0.73)^*^ | NR
Chen, 2018^31^ | OC-Sensor | 20 | Male 50–59 years | 157,262 | 0.77 (0.73, 0.81)^*^ | NR
Chen, 2018^31^ | OC-Sensor | 20 | Male 60–69 years | 119,780 | 0.76 (0.72, 0.79)^*^ | NR
Chen, 2018^31^ | OC-Sensor | 24 | Male 60–69 years | NR | 0.768 (NR) | 0.95 (NR)
Garcia, 2015^32^ | OC-Auto (cutoff 100–1 sample) | 20 | All | 4,568 | 0.88 (0.69, 0.96)^*^ | 0.94 (0.93, 0.95)^*^
Haug, 2017^33^ | OC-Sensor Micro | 10 | All | 4,523 | 0.78 (0.62, 0.88)^*^ | 0.88 (0.87, 0.89)^*^
Haug, 2017^33^ | OC-Sensor Micro | 2.2 | All | 4,523 | 0.75 (0.59, 0.86)^*^ | 0.82 (0.81, 0.83)^*^
Haug, 2017^33^ | OC-Sensor Micro | 2.8 | All | 4,523 | 0.75 (0.59, 0.86)^*^ | 0.84 (0.83, 0.85)^*^
Haug, 2017^33^ | OC-Sensor Micro | 4.4 | All | 4,523 | 0.72 (0.56, 0.84)^*^ | 0.88 (0.87, 0.89)^*^
Haug, 2017^33^ | OC-Sensor Micro | 7.2 | All | 4,523 | 0.64 (0.48, 0.78)^*^ | 0.90 (0.89, 0.91)^*^
Haug, 2017^33^ | OC-Sensor Micro | 9 | All | 4,523 | 0.61 (0.45, 0.75)^*^ | 0.91 (0.90, 0.92)^*^
Itoh, 1996^34^ | OC-Hemodia | 10 | All | 27,860 | 0.865 (0.78, 0.92)^*^ | 0.95 (0.95, 0.95)^*^
Juul, 2018^35^ | OC-Sensor | 20 | All | 245,299 | 0.94 (0.92, 0.95)^*^ | 0.94 (0.94, 0.94)^*^
Launoy, 2005^36^ | Magstream 1000 | 100–200^*^ | All | 7,421 | 0.85 (0.69, 0.94)^*^ | 0.94 (0.94, 0.95)^*^
Levi, 2011^37^ | OC-Sensor | (~14^*^) | All | 1,204 | 1.0 (0.61, 1.0)^*^ | 0.88 (0.86, 0.89)^*^
Mlakar, 2018^38^ | OC-Sensor | 20 | All | 251,948 | 0.86 (0.83, 0.89)^*^ | 0.94 (0.94, 0.94)^*^
Mlakar, 2018^38^ | OC-Sensor | 20 | ≤9 years of school | NR | 0.91 (0.88, 0.93)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | ≥10 years of school | NR | 0.84 (0.80, 0.87)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | 50–54 years | NR | 0.88 (0.80, 0.93)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | 55–59 years | NR | 0.90 (0.83, 0.95)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | 60–64 years | NR | 0.88 (0.82, 0.91)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | ≥65 years | NR | 0.81 (0.74, 0.86)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | Distal | NR | 0.91 (0.88, 0.93)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | Proximal | NR | 0.74 (0.66, 0.80)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | Female | NR | 0.86 (0.81, 0.90)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | Male | NR | 0.86 (0.82, 0.89)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | Stage I | NR | 0.94 (0.90, 0.96)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | Stage II | NR | 0.85 (0.78, 0.91)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | Stage III | NR | 0.81 (0.73, 0.87)^*^ | NR
Mlakar, 2018^38^ | OC-Sensor | 20 | Stage IV | NR | 0.67 (0.54, 0.78)^*^ | NR
Nakama, 1996^39^ | Monohaem | 20 | All - 1 year followup | 3,365 | 0.909 (0.62, 0.98)^*^ | 0.96 (0.95, 0.96)^*^
Nakama, 1996^39^ | Monohaem | 20 | All - 2 year followup | 3,365 | 0.833 (0.55, 0.95)^*^ | 0.96 (0.95, 0.96)^*^
Nakama, 1996^39^ | Monohaem | 20 | All - 3 year followup | 3,365 | 0.714 (0.45, 0.88)^*^ | 0.96 (0.95, 0.96)^*^
Selby, 2018^40^ | OC FIT-CHEK | 10 | 50–59 years | 323,855 | 0.827 (0.788, 0.862) | 0.887 (0.886, 0.888)
Selby, 2018^40^ | OC FIT-CHEK | 10 | 60–69 years | 234,665 | 0.788 (0.751, 0.822) | 0.857 (0.856, 0.859)
Selby, 2018^40^ | OC FIT-CHEK | 10 | 70–75 years | 82,056 | 0.749 (0.694, 0.799) | 0.837 (0.835, 0.840)
Selby, 2018^40^ | OC FIT-CHEK | 10 | BL FIT and any FIT within 2 years | 640,859 | 0.793 (0.769, 0.815) | 0.87 (0.869, 0.871)
Selby, 2018^40^ | OC FIT-CHEK | 10 | Female | 337,588 | 0.777 (0.739, 0.811) | 0.882 (0.881, 0.883)
Selby, 2018^40^ | OC FIT-CHEK | 10 | Male | 303,271 | 0.805 (0.774, 0.833) | 0.856 (0.855, 0.857)
Selby, 2018^40^ | OC FIT-CHEK | 15 | 50–59 years | 323,855 | 0.799 (0.726, 0.810) | 0.920 (0.919, 0.921)
Selby, 2018^40^ | OC FIT-CHEK | 15 | 60–69 years | 234,665 | 0.755 (0.716, 0.791) | 0.900 (0.898, 0.901)
Selby, 2018^40^ | OC FIT-CHEK | 15 | 70–75 years | 82,056 | 0.724 (0.668, 0.776) | 0.884 (0.882, 0.886)
Selby, 2018^40^ | OC FIT-CHEK | 15 | BL FIT and any FIT within 2 years | 640,859 | 0.763 (0.738, 0.786) | 0.908 (0.907, 0.909)
Selby, 2018^40^ | OC FIT-CHEK | 15 | Female | 337,588 | 0.735 (0.695, 0.772) | 0.918 (0.917, 0.919)
Selby, 2018^40^ | OC FIT-CHEK | 15 | Male | 303,271 | 0.784 (0.752, 0.813) | 0.897 (0.896, 0.898)
Selby, 2018^40^ | OC FIT-CHEK | 20 | 50–59 years | 323,855 | 0.790 (0.748, 0.827) | 0.935 (0.934, 0.936)
Selby, 2018^40^ | OC FIT-CHEK | 20 | 60–69 years | 234,665 | 0.734 (0.694, 0.771) | 0.919 (0.918, 0.920)
Selby, 2018^40^ | OC FIT-CHEK | 20 | 70–75 years | 82,056 | 0.689 (0.632, 0.743) | 0.906 (0.904, 0.908)
Selby, 2018^40^ | OC FIT-CHEK | 20 | BL FIT and 1 additional FIT | 250,519 | 0.713 (0.66, 0.76)^*^ | 0.935 (0.93, 0.94)^*^
Selby, 2018^40^ | OC FIT-CHEK | 20 | BL FIT and 2 additional FITs | 231,298 | 0.98 (0.90, 1.0)^*^ | 0.96 (0.96, 0.96^*^)
Selby, 2018^40^ | OC FIT-CHEK | 20 | BL FIT and any FIT within 2 years | 640,859 | 0.743 (0.718, 0.767) | 0.926 (0.925, 0.926)
Selby, 2018^40^ | OC FIT-CHEK | 20 | BL FIT only | 159,042 | 0.741 (0.71, 0.77)^*^ | 0.856 (0.85, 0.86)^*^
Selby, 2018^40^ | OC FIT-CHEK | 20 | Female | 337,588 | 0.706 (0.666, 0.745) | 0.934 (0.933, 0.935)
Selby, 2018^40^ | OC FIT-CHEK | 20 | Male | 303,271 | 0.770 (0.737, 0.800) | 0.916 (0.915, 0.917)
Selby, 2018^40^ | OC FIT-CHEK | 25 | 50–59 years | 323,855 | 0.736 (0.692, 0.777) | 0.946 (0.945, 0.946)
Selby, 2018^40^ | OC FIT-CHEK | 25 | 60–69 years | 234,665 | 0.693 (0.652, 0.732) | 0.933 (0.932, 0.934)
Selby, 2018^40^ | OC FIT-CHEK | 25 | 70–75 years | 82,056 | 0.643 (0.584, 0.699) | 0.922 (0.920, 0.924)
Selby, 2018^40^ | OC FIT-CHEK | 25 | BL FIT and any FIT within 2 years | 640,859 | 0.696 (0.67, 0.722) | 0.938 (0.938, 0.939)
Selby, 2018^40^ | OC FIT-CHEK | 25 | Female | 337,588 | 0.663 (0.621, 0.703) | 0.945 (0.945, 0.946)
Selby, 2018^40^ | OC FIT-CHEK | 25 | Male | 303,271 | 0.721 (0.687, 0.754) | 0.930 (0.929, 0.931)
Selby, 2018^40^ | OC FIT-CHEK | 30 | 50–59 years | 323,855 | 0.696 (0.650, 0.740) | 0.953 (0.952, 0.953)
Selby, 2018^40^ | OC FIT-CHEK | 30 | 60–69 years | 234,665 | 0.661 (0.619, 0.701) | 0.943 (0.942, 0.944)
Selby, 2018^40^ | OC FIT-CHEK | 30 | 70–75 years | 82,056 | 0.604 (0.545, 0.662) | 0.933 (0.931, 0.935)
Selby, 2018^40^ | OC FIT-CHEK | 30 | BL FIT and any FIT within 2 years | 640,859 | 0.66 (0.633, 0.687) | 0.947 (0.946, 0.947)
Selby, 2018^40^ | OC FIT-CHEK | 30 | Female | 337,588 | 0.631 (0.588, 0.672) | 0.953 (0.952, 0.954)
Selby, 2018^40^ | OC FIT-CHEK | 30 | Male | 303,271 | 0.682 (0.647, 0.716) | 0.939 (0.938, 0.940)
Stegeman, 2015^41^ | OC-Sensor | 10 | All | 2,871 | 0.60 (0.68, 0.84)^*^ | 0.92 (0.87, 0.93)
Stegeman, 2015^41^ | OC-Sensor | 10 | Distal | NR | 0.55 (0.28, 0.79)^*^ | (, )
Stegeman, 2015^41^ | OC-Sensor | 10 | Proximal | NR | 0.67 (0.35, 0.88)^*^ | (, )
Stegeman, 2015^41^ | OC-Sensor | 10 | Stage I | NR | 0.67 (0.35, 0.88)^*^ | (, )
Stegeman, 2015^41^ | OC-Sensor | 10 | Stage II | NR | 0.67 (0.21, 0.94)^*^ | (, )
Stegeman, 2015^41^ | OC-Sensor | 10 | Stage III | NR | 0.67 (0.30, 0.90)^*^ | (, )
Stegeman, 2015^41^ | OC-Sensor | 10 | Stage IV | NR | 0 (0, 0.66)^*^ | (, )
Toes-Zoutendijk, 2019^42^ | FOB Gold | 15 | All | 127,411 | 0.90 (0.88, 0.91) | 0.89 (0.88, 0.89)
Toes-Zoutendijk, 2019^42^ | FOB Gold | 15 | Female | 66,475 | 0.89 (0.86,0.92) | 0.91 (0.90, 0.91)
Toes-Zoutendijk, 2019^42^ | FOB Gold | 15 | Male | 60,936 | 0.90 (0.88, 0.92) | 0.86 (0.86, 0.87)
Toes-Zoutendijk, 2019^42^ | FOB Gold | 47 | All | 398,505 | 0.83 (0.82, 0.85) | 0.94 (0.94, 0.94)
Toes-Zoutendijk, 2019^42^ | FOB Gold | 47 | Female | 203,968 | 0.79 (0.77, 0.82) | 0.96 (0.95, 0.96)
Toes-Zoutendijk, 2019^42^ | FOB Gold | 47 | Male | 194,537 | 0.86 (0.84, 0.88) | 0.93 (0.93, 0.93)
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | All | 18,716 | 0.82 (0.75, 0.87)^*^ | 0.84 (0.84, 0.85)^*^
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | >70 years | NR | 0.80 (0.67, 0.89)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | 50–59 years | NR | 0.83 (0.67, 0.92)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | 60–69 years | NR | 0.84 (0.73, 0.91)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | Average SES | NR | 0.81 (0.72, 0.87)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | Distal | NR | 0.83 (0.75, 0.89)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | Female | NR | 0.81 (0.70, 0.89)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | High SES | NR | 0.85 (0.66, 0.94)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | Low SES | NR | 0.88 (0.66, 0.97)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | Male | NR | 0.83 (0.74, 0.89)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | Proximal | NR | 0.80 (0.68, 0.89)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | Stage I | NR | 0.89 (0.79, 0.94)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | Stage II | NR | 0.73 (0.52, 0.87)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | Stage III | NR | 0.81 (0.67, 0.90)^*^ | NR
van der Vlugt, 2017^43^ | OC-Sensor/FOB Gold | 10 | Stage IV | NR | 0.69 (0.42, 0.87)^*^ | NR

* Calculated sensitivity, specificity, or CI

Abbreviations: BL = baseline; CI = confidence interval; CRC = colorectal cancer; FIT = fecal immunochemical test; n = number; NR = not reported; µg Hb/g = micrograms hemoglobin per gram feces

Appendix D Table 6 Key Question 3: Harms of Screening Colonoscopy for Subgroups

Author, year | Country | Age, mean | F/U | Group | n | Serious bleeding events | | Perforation events | | Other SAEs
Author, year | Country | Age, mean | F/U | Group | n | n | OR or RR (95% CI) | n | OR or RR (95% CI | n | OR or RR (95% CI)
Grossberg, 2019^44^ | US | 60 (median) | 7 days | 50–75 years | 27799^‡^ | NR | NR | NR | NR | Hospitalization: 35^‡^; ED visit: 157^‡^ | NR
Grossberg, 2019^44^ | US | 60 (median) | 7 days | 76–85 years | 2422^‡^ | NR | NR | NR | NR | Hospitalization: 16^‡^; ED visit: 28^‡^ | NR
Grossberg, 2019^44^ | US | 60 (median) | 7 days | >85 years | 188^‡^ | NR | NR | NR | NR | Hospitalization: 3^‡^; ED visit: 3^‡^ | NR
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | Female | 265227 | NR | NR | NR | NR | Hospitalization - due to infection: 292 | OR: 0.94 (0.79, 1.11)
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | Male | 196841 | NR | NR | NR | NR | Hospitalization - due to infection: 217 | Ref
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | 40–49 yrs | 35117 | NR | NR | NR | NR | Hospitalization - due to infection: 49 | OR: 1.28 (0.93, 1.76)
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | 50–59 yrs | 183903 | NR | NR | NR | NR | Hospitalization - due to infection: 166 | Ref
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | 60–69 yrs | 148324 | NR | NR | NR | NR | Hospitalization - due to infection: 148 | OR: 1.09 (0.88, 1.37)
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | 70–79 yrs | 77627 | NR | NR | NR | NR | Hospitalization - due to infection: 109 | OR: 1.40 (1.09, 1.78)
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | 80–100 yrs | 17559 | NR | NR | NR | NR | Hospitalization - due to infection: 44 | OR: 1.96 (1.39, 2.76)
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | White | 306351 | NR | NR | NR | NR | Hospitalization - due to infection: 337 | Ref
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | Black | 46669 | NR | NR | NR | NR | Hospitalization - due to infection: 84 | OR: 1.57 (1.22, 2.01)
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | Hispanic | 69310 | NR | NR | NR | NR | Hospitalization - due to infection: 90 | OR: 1.11 (0.87, 1.42)
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | Asian or Pacific Islander | 18483 | NR | NR | NR | NR | Hospitalization - due to infection: 9 | OR: 0.50 (0.27, 0.96)
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | Native American | 1386 | NR | NR | NR | NR | Hospitalization - due to infection: 6 | OR: 3.68 (1.51, 8.89)
Wang, 2018^45^; (Newly identified) | US | NR | 7 days | Other race | 19869 | NR | NR | NR | NR | Hospitalization - due to infection: 12 | OR: 0.70 (0.39, 1.25)
Zwink, 2017^46^ 5065; (Newly identified) | DEU | 61^*^ | 4 wks | Female | 2731 | NR | NR | NR | NR | Physician-confirmed complication: 8^†^ | NR
Zwink, 2017^46^ 5065; (Newly identified) | DEU | 61^*^ | 4 wks | Male | 2521 | NR | NR | NR | NR | Physician-confirmed complication: 12^†^ | NR
Zafar, 2014^47^ | US | 74 | 30 days | 66–74 years | NR | NR^§^ | Ref | NR^‡^ | Ref | NR^‡^,^§^ | Ref
Zafar, 2014^47^ | US | 74 | 30 days | 75–84 years | NR | NR^§^ | OR: 1.14 (0.87, 1.48) | NR^‡^ | OR: 1.02 (0.49, 2.14) | NR^‡^,^§^ | OR: 0.92 (0.70, 1.22)
Zafar, 2014^47^ | US | 74 | 30 days | ≥85 years | NR | NR^§^ | OR: 1.49 (0.81, 2.75) | NR^‡^ | OR: 1.99 (0.45, 8.69) | NR^‡^,^§^ | OR: 1.22 (0.68, 2.2)
Pox, 2012^48^ | DEU | 65 | NR | Female 55–59 | NR | NR | NR | NR | NR | SAE: NR (Total major and minor complications) | OR reported as reference
Pox, 2012^48^ | DEU | 65 | NR | Female 60–64 | NR | NR | NR | NR | NR | SAE: NR | OR: 1.5 (1.3, 1.7)
Pox, 2012^48^ | DEU | 65 | NR | Female 65–69 | NR | NR | NR | NR | NR | SAE: NR | OR: 1.8 (1.6, 2.0)
Pox, 2012^48^ | DEU | 65 | NR | Female 70–74 | NR | NR | NR | NR | NR | SAE: NR | OR: 2.1 (1.8, 2.4)
Pox, 2012^48^ | DEU | 65 | NR | Female 75–79 | NR | NR | NR | NR | NR | SAE: NR | OR: 2.8 (2.4, 3.2)
Pox, 2012^48^ | DEU | 65 | NR | Female ≥79 | NR | NR | NR | NR | NR | SAE: NR | OR: 3.4 (2.8, 4.1)
Pox, 2012^48^ | DEU | 65 | NR | Male 55–59 | NR | NR | NR | NR | NR | SAE: NR | Ref
Pox, 2012^48^ | DEU | 65 | NR | Male 60–64 | NR | NR | NR | NR | NR | SAE: NR | OR: 1.2 (1.0, 1.3)
Pox, 2012^48^ | DEU | 65 | NR | Male 65–69 | NR | NR | NR | NR | NR | SAE: NR | OR: 1.3 (1.2, 1.5)
Pox, 2012^48^ | DEU | 65 | NR | Male 70–74 | NR | NR | NR | NR | NR | SAE: NR | OR: 1.5 (1.3, 1.7)
Pox, 2012^48^ | DEU | 65 | NR | Male 75–79 | NR | NR | NR | NR | NR | SAE: NR | OR: 1.7 (1.5, 2.0)
Pox, 2012^48^ | DEU | 65 | NR | Male ≥79 | NR | NR | NR | NR | NR | SAE: NR | OR: 1.6 (1.3, 2.0)
Rutter, 2012^49^ | US | NR | 30 days | 40–49 years | 2450 | 6^ǁ¶^ | NR | 0^¶^ | NR | Hospitalization: 28 | NR
Rutter, 2012^49^ | US | NR | 30 days | 40–49 years | 2450 | 6^ǁ¶^ | NR | 0^¶^ | NR | ED visit: 77 | NR
Rutter, 2012^49^ | US | NR | 30 days | 50–64 years | 28565 | 66^ǁ¶^ | NR | 10^¶^ | NR | Hospitalization: 277 | NR
Rutter, 2012^49^ | US | NR | 30 days | 50–64 years | 28565 | 66^ǁ¶^ | NR | 10^¶^ | NR | ED visit: 684 | NR
Rutter, 2012^49^ | US | NR | 30 days | 65–74 years | 5804 | 31^ǁ¶^ | NR | 7^¶^ | NR | Hospitalization: 141 | NR
Rutter, 2012^49^ | US | NR | 30 days | 65–74 years | 5804 | 31^ǁ¶^ | NR | 7^¶^ | NR | ED visit: 177 | NR
Rutter, 2012^49^ | US | NR | 30 days | 75–85 years | 1653 | 19^ǁ¶^ | NR | 4^¶^ | NR | Hospitalization: 62 | NR
Rutter, 2012^49^ | US | NR | 30 days | 75–85 years | 1653 | 19^ǁ¶^ | NR | 4^¶^ | NR | ED visit: 81^¶^ | NR
Ferlitsch, 2011^50^ | AUT | 61 | NR | Male | 21752 | 39^ǁ^ | NR | 2 | NR | Cardiopulmonary event: 16 | NR
Ferlitsch, 2011^50^ | AUT | 61 | NR | Male | 21752 | 39^ǁ^ | NR | 2 | NR | Other SAE: 6 | NR
Ferlitsch, 2011^50^ | AUT | 61 | NR | Female | 22598 | 15^ǁ^ | NR | 1 | NR | Cardiopulmonary event: 30 | NR
Ferlitsch, 2011^50^ | AUT | 61 | NR | Female | 22598 | 15^ǁ^ | NR | 1 | NR | Other SAE: 2 | NR
Ferlitsch, 2011^50^ | AUT | 61 | NR | 50–60 yrs | 19326 | NR^#^ | NR | NR | NR | Cardiopulmonary event: 10^**^ | NR
Ferlitsch, 2011^50^ | AUT | 61 | NR | 70–80 yrs | 6279 | NR^#^ | NR | NR | NR | Cardiopulmonary event: 16^**^ | NR
Crispin, 2009^51^ | DEU | 64^*^ | NR | Female | 31216 | NR | OR: 1.0001 (1.0001, 1.0002) | NR | NR | Cardiopulmonary event: NR | NR
Crispin, 2009^51^ | DEU | 64^*^ | NR | Age squared, per year | NR | NR | OR: 0.822 (0.686, 0.984) | NR | OR: 1.0003 (1.0002, 1.0005) | Cardiopulmonary event: NR | OR: 1.0003 (1.0002, 1.0004)
Warren, 2009^52^ | US | NR | 30 days | 66–69 yrs | 12942 (IG); 12986 (CG) | NR | NR | NR | NR | - Cardiovascular event: NR (12.6/1000 persons [IG]; 10.7/1000 persons [CG])^†^; - Serious GI events: NR (5.0/1000 persons [IG]; 1.3/1000 persons [CG])^†^ | NR
Warren, 2009^52^ | US | NR | 30 days | 70–74 yrs | 16606 (IG); 16548 (CG) | NR | NR | NR | NR | - Cardiovascular event: NR (16.0/1000 persons [IG]; 13.6/1000 persons [CG])^†^; - Serious GI events: NR (5.8/1000 persons [IG]; 1.5/1000 persons [CG])^†^ | NR
Warren, 2009^52^ | US | NR | 30 days | 75–79 yrs | 13289 (IG); 13295 (CG) | NR | NR | NR | NR | - Cardiovascular event: NR (20.6/1000 persons [IG]; 17.5/1000 persons [CG])^†^; - Serious GI events: NR (7.2/1000 persons [IG]; 1.9/1000 persons [CG])^†^ | NR
Warren, 2009^52^ | US | NR | 30 days | 80–84 yrs | 7453 (IG); 7441 (CG) | NR | NR | NR | NR | - Cardiovascular event: NR (25.7/1000 persons [IG]; 21.9/1000 persons [CG])^†^; - Serious GI events: NR (8.8/1000 persons [IG]; 2.3/1000 persons [CG])^†^ | NR
Warren, 2009^52^ | US | NR | 30 days | ≥85 yrs | 2930 (IG); 2950 (CG) | NR | NR | NR | NR | - Cardiovascular event: NR (31.8/1000 persons [IG]; 27.1/1000 persons [CG])^†^; - Serious GI events: NR (12.1/1000 persons [IG]; 3.2/1000 persons [CG])^†^ | NR

* Median age

† Physician confirmed hospitalizations due to bleeding and/or perforation

‡ Increasing risk of bleeding, perforation, and other GI events with older ages (only odds ratios presented; not statistically significant; also includes 1384 people total who received CT colonography)

§ Increasing risk of cardiovascular events with older ages (only odds ratios presented; statistically significant; also includes 1384 people total who received CT colonography)

ǁ Unspecified bleeding

¶ Number of events (rather than number of people)

# Bleeding events were unchanged by age (p=0.23)

** Cardiopulmonary adverse events increased with age, from 0.05% in patients age 50–60 yrs to 0.25% in patients age 70–80 yrs (p<0.001)

Abbreviations: AUT = Austria; CI = confidence interval; DEU = Germany; F/U = followup;IG = intervention (screening) group; CG = control (no screening) group; n = number; NR = not reported; MI = myocardial infarction; perf = perforation; SAE = serious adverse events; GI = gastrointestinal; OR = odds ratio; RR = rate ratio; SAE = serious adverse events; US = United States; wks = weeks; yrs = yrs

Appendix D Table 7 Key Question 3: Harms of Mixed Colonoscopies - Subgroups

Author, year | Country | Age, mean | F/U | Group | n | Serious bleeding events | | Perforation events | | Other SAEs
Author, year | Country | Age, mean | F/U | Group | n | n | OR or RR (95% CI) | n | OR or RR (95% CI) | n | OR or RR (95% CI)
Chukmaitov, 2019^53^ | US | NR | 30 days | 19–49 yrs | NR | NR | NR | NR | NR | Hospitalization due to perforations and GI bleeding: NR | OR reported as reference
Chukmaitov, 2019^53^ | US | NR | 30 days | 50–64 yrs | NR | NR | NR | NR | NR | Hospitalization due to perforations and GI bleeding: NR | OR: 1.60 (1.10, 2.34)
Chukmaitov, 2019^53^ | US | NR | 30 days | 65–74 yrs | NR | NR | NR | NR | NR | Hospitalization due to perforations and GI bleeding: NR | OR: 2.26 (1.51, 3.38)
Chukmaitov, 2019^53^ | US | NR | 30 days | 75–84 yrs | NR | NR | NR | NR | NR | Hospitalization due to perforations and GI bleeding: NR | OR: 3.06 (2.02, 4.62)
Chukmaitov, 2019^53^ | US | NR | 30 days | 85 yrs and older | NR | NR | NR | NR | NR | Hospitalization due to perforations and GI bleeding: NR | OR: 4.22 (2.56, 6.97)
Laanani, 2019^54^ | FRA | NR | 5 days | 30–39 yrs | 319498 | NR | aOR: 1.00 | NR | aOR: 1.00 | NR | NR
Laanani, 2019^54^ | FRA | NR | 5 days | 40–49 yrs | 737285 | NR | aOR: 0.83 (0.62, 1.12) | NR | aOR: 1.24 (0.75, 2.07) | NR | NR
Laanani, 2019^54^ | FRA | NR | 5 days | 50–59 yrs | 1134487 | NR | aOR: 0.99 (0.75, 1.31) | NR | aOR: 1.85 (1.15, 2.95) | NR | NR
Laanani, 2019^54^ | FRA | NR | 5 days | 60–69 yrs | 1123714 | NR | aOR: 1.13 (0.86, 1.49) | NR | aOR: 2.90 (1.83, 4.59) | NR | NR
Laanani, 2019^54^ | FRA | NR | 5 days | 70–79 yrs | 605787 | NR | aOR: 1.18 (0.89, 1.56) | NR | aOR: 4.91 (3.09, 7.80) | NR | NR
Laanani, 2019^54^ | FRA | NR | 5 days | 80 yrs and older | 168028 | NR | aOR: 1.95 (1.44, 2.63) | NR | aOR: 8.20 (5.04, 13.3) | NR | NR
Thulin, 2019^55^ | SWE | 63 | 30 days | Female | 320386 | NR^†^ | RR reported as reference | NR | RR reported as reference | NR | NR
Thulin, 2019^55^ | SWE | 63 | 30 days | Male | 272922 | NR^†^ | RR: 0.62 (0.54, 0.72) | NR | RR: 1.16 (0.98, 1.37) | NR | NR
Thulin, 2019^55^ | SWE | 63 | 30 days | 18–30 yrs | NR | NR^†^ | RR reported as reference | NR | RR reported as reference | NR | NR
Thulin, 2019^55^ | SWE | 63 | 30 days | 30–40 yrs | NR | NR^†^ | RR: 1.11 (0.62, 1.98) | NR | RR: 1.06 (0.54, 2.06) | NR | NR
Thulin, 2019^55^ | SWE | 63 | 30 days | 40–50 yrs | NR | NR^†^ | RR: 1.84 (1.10, 3.08) | NR | RR: 1.34 (0.75, 2.43) | NR | NR
Thulin, 2019^55^ | SWE | 63 | 30 days | 50–60 yrs | NR | NR^†^ | RR: 2.01 (1.24, 3.25) | NR | RR: 1.62 (0.94, 2.78) | NR | NR
Thulin, 2019^55^ | SWE | 63 | 30 days | 60–70 yrs | NR | NR^†^ | RR: 2.39 (1.51, 3.80) | NR | RR: 2.65 (1.60, 4.40) | NR | NR
Thulin, 2019^55^ | SWE | 63 | 30 days | 70–80 yrs | NR | NR^†^ | RR: 3.12 (1.96, 4.96) | NR | RR: 3.46 (2.08, 5.75) | NR | NR
Thulin, 2019^55^ | SWE | 63 | 30 days | 80 yrs and older | NR | NR^†^ | RR: 3.88 (2.42, 6.22) | NR | RR: 5.24 (3.12, 8.80) | NR | NR
Forsberg, 2017^56^; (Newly identified) | SWE | 63 | 30 days | Female | 238874 | NR^*^ | RR: 0.62 (0.54, 0.72) | NR^*^ | RR: 1.15 (0.98, 1.36) | NR | NR
Forsberg, 2017^56^; (Newly identified) | SWE | 63 | 30 days | Male | 187686 | NR^*^ | NR | NR^*^ | NR | NR | NR
Forsberg, 2017^56^; (Newly identified) | SWE | 63 | 30 days | 18–30 yrs | 43755 | 23^†^ | NR | 19 | NR | NR | NR
Forsberg, 2017^56^; (Newly identified) | SWE | 63 | 30 days | 30–40 yrs | 48373 | 29^†^ | NR | 23 | NR | NR | NR
Forsberg, 2017^56^; (Newly identified) | SWE | 63 | 30 days | 40–50 yrs | 68462 | 68^†^ | NR | 41 | NR | NR | NR
Forsberg, 2017^56^; (Newly identified) | SWE | 63 | 30 days | 50–60 yrs | 97891 | 123^†^ | NR | 71 | NR | NR | NR
Forsberg, 2017^56^; (Newly identified) | SWE | 63 | 30 days | 60–70 yrs | 153703 | 250^†^ | NR | 169 | NR | NR | NR
Forsberg, 2017^56^; (Newly identified) | SWE | 63 | 30 days | 70–80 yrs | 124450 | 296^†^ | NR | 194 | NR | NR | NR
Garcia-Albeniz, 2017^57^; (Newly identified) | US | NR | 30 days | 70–74 yrs | 46872 (IG); 1762816 (CG) | 20 (IG); 130 (CG) | NR | 20 (IG); 51 (CG) | NR | Other GI events: 257 (IG); 4331 (CG) | NR
Garcia-Albeniz, 2017^57^; (Newly identified) | US | NR | 30 days | 70–74 yrs | 46872 (IG); 1762816 (CG) | 20 (IG); 130 (CG) | NR | 20 (IG); 51 (CG) | NR | Cardiovascular event: 473 (IG); 14026 (CG) | NR
Garcia-Albeniz, 2017^57^; (Newly identified) | US | NR | 30 days | 75–79 yrs | 31193 (IG); 1628020 (CG) | 14 (IG); 180 (CG) | NR | 11 (IG); 71 (CG) | NR | Other GI events: 206 (IG); 5003 (CG) | NR
Garcia-Albeniz, 2017^57^; (Newly identified) | US | NR | 30 days | 75–79 yrs | 31193 (IG); 1628020 (CG) | 14 (IG); 180 (CG) | NR | 11 (IG); 71 (CG) | NR | Cardiovascular event: 538 (IG); 17638 (CG) | NR
Johnson, 2017^58^; (Newly identified) | US | NR | 30 days | Female | 262689 | NR | NR | NR | NR | Non GI SAE^‡^: 3030 | NR
Johnson, 2017^58^; (Newly identified) | US | NR | 30 days | Male | 225817 | NR | NR | NR | NR | Non GI SAE^‡^: 3532 | NR
Johnson, 2017^58^; (Newly identified) | US | NR | 30 days | <50 yrs old | 87437 | NR | NR | NR | NR | Non GI SAE^‡^: 595 | NR
Johnson, 2017^58^; (Newly identified) | US | NR | 30 days | ≥50 yrs | 401069 | NR | NR | NR | NR | Non GI SAE^‡^: 5967 | NR
Adeyemo, 2014^59^ | US | 61 | NR | Female | 63337 | NR | NR | 22 | NR | NR | NR
Adeyemo, 2014^59^ | US | 61 | NR | Male | 54667 | NR | NR | 26 | NR | NR | NR
Bielawska, 2014^60^ | US | NR | NR | Female | 548587 | NR | NR | 103 | OR: 1.26 (0.95, 1.67) | NR | NR
Bielawska, 2014^60^ | US | NR | NR | Male | 596309 | NR | NR | 89 | OR reported as reference | NR | NR
Bielawska, 2014^60^ | US | NR | NR | <60 yrs | 566952 | NR | NR | 39 | OR reported as reference | NR | NR
Bielawska, 2014^60^ | US | NR | NR | 60–74 yrs | 426305 | NR | NR | 83 | OR: 2.83 (1.94, 4.14) | NR | NR
Bielawska, 2014^60^ | US | NR | NR | ≥75 yrs | 151210 | NR | | 70 | OR: 6.73 (4.55, 9.96) | NR | NR
Blotiere, 2014^61^ | FRA | NR | 3 days | Male | 420852 | NR^§^ | NR | NR^§^ | OR: 0.99 (0.81, 1.20) | NR | NR
Blotiere, 2014^61^ | FRA | NR | 3 days | 0–39 yrs | 92188 | NR^§^ | OR: 1.00 | NR^§^ | OR reported as reference | NR | NR
Blotiere, 2014^61^ | FRA | NR | 3 days | 40–49 yrs | 143604 | NR^§^ | OR: 1.06 (0.70, 1.62) | NR^§^ | OR: 0.78 (0.38, 1.58) | NR | NR
Blotiere, 2014^61^ | FRA | NR | 3 days | 50–59 yrs | 249746 | NR^§^ | OR: 1.75 (1.22, 2.52) | NR^§^ | OR: 1.56 (0.87, 2.79) | NR | NR
Blotiere, 2014^61^ | FRA | NR | 3 days | 60–69 yrs | 252689 | NR^§^ | OR: 2.51 (1.76, 3.58) | NR^§^ | OR: 2.89 (1.66, 5.05) | NR | NR
Blotiere, 2014^61^ | FRA | NR | 3 days | 70–79 yrs | 155861 | NR^§^ | OR: 4.54 (3.19, 6.45) | NR^§^ | OR: 5.75 (3.32, 9.97) | NR | NR
Blotiere, 2014^61^ | FRA | NR | 3 days | ≥80 yrs | 52973 | NR^§^ | NR | NR^§^ | OR: 10.83 (6.16, 19.05) | NR | NR
Chukmaitov, 2013^62^ | US | NR | 30 days | Female | NR | NR^ǁ^ | OR: 0.65 (0.61, 0.70) | NR^ǁ^ | OR: 1.33 (1.15, 1.55) | NR | NR
Chukmaitov, 2013^62^ | US | NR | 30 days | 55–64 yrs | NR | NR^ǁ^ | OR: 1.08 (0.94, 1.25) | NR^ǁ^ | OR: 1.38 (1.01, 1.87) | NR | NR
Chukmaitov, 2013^62^ | US | NR | 30 days | 65–74 yrs | NR | NR^ǁ^ | OR: 1.22 (1.03, 1.45) | NR^ǁ^ | OR: 1.80 (1.24, 2.62) | NR | NR
Chukmaitov, 2013^62^ | US | NR | 30 days | 75–84 yrs | NR | NR^ǁ^ | OR: 1.71 (1.43, 2.05) | NR^ǁ^ | OR: 2.36 (1.61, 3.48) | NR | NR
Chukmaitov, 2013^62^ | US | NR | 30 days | ≥85 yrs | NR | NR^ǁ^ | OR: 2.88 (1.75, 4.72) | NR^ǁ^ | OR: 2.88 (1.75, 4.72) | NR | NR
Chukmaitov, 2013^62^ | US | NR | 30 days | Black | NR | NR^ǁ^ | OR: 1.32 (1.13, 1.53) | NR^ǁ^ | OR: 0.86 (0.60, 1.25) | NR | NR
Chukmaitov, 2013^62^ | US | NR | 30 days | Hispanic | NR | NR^ǁ^ | OR: 1.23 (1.08, 1.39) | NR^ǁ^ | OR: 0.99 (0.75, 1.31) | NR | NR
Chukmaitov, 2013^62^ | US | NR | 30 days | Other race | NR | NR^ǁ^ | OR: 1.00 (0.87, 1.14) | NR^ǁ^ | OR: 0.90 (0.68, 1.20) | NR | NR
Cooper, 2013^63^ | US | 76 | 30 days | 66–69 yrs | 38391 | NR | NR | NR | OR reported as reference | Perforation, splenic injury, or aspiration pneumonia: NR^¶^ | OR reported as reference
Cooper, 2013^63^ | US | 76 | 30 days | 70–74 yrs | 44690 | NR | NR | NR | OR: 3.36 (2.03, 5.56) | Perforation, splenic injury, or aspiration pneumonia: NR^¶^ | OR: 3.36 (2.03, 5.56)
Cooper, 2013^63^ | US | 76 | 30 days | 75–79 yrs | 35061 | NR | NR | NR | OR: 3.63 (2.18, 6.05) | Perforation, splenic injury, or aspiration pneumonia: NR^¶^ | OR: 3.63 (2.18, 6.05)
Cooper, 2013^63^ | US | 76 | 30 days | 80–84 yrs | 19839 | NR | NR | NR | OR: 5.97 (3.58, 9.97) | Perforation, splenic injury, or aspiration pneumonia: NR^¶^ | OR: 5.97 (3.58, 9.97)
Cooper, 2013^63^ | US | 76 | 30 days | ≥85 yrs | 8723 | NR | NR | NR | OR: 10.41 (6.18, 17.54) | Perforation, splenic injury, or aspiration pneumonia: NR^¶^ | OR: 10.41 (6.18, 17.54)
Hamdani, 2013^64^ | US | NR | 7 days | Female | 41121 | NR | NR | 34 | NR | NR | NR
Hamdani, 2013^64^ | US | NR | 7 days | Male | 38988 | NR | NR | 16 | NR | NR | NR
Hamdani, 2013^64^ | US | NR | 7 days | 18–49 yrs | 13703 | NR | NR | 5 | NR | NR | NR
Hamdani, 2013^64^ | US | NR | 7 days | 50–64 yrs | 38705 | NR | NR | 10 | NR | NR | NR
Hamdani, 2013^64^ | US | NR | 7 days | 65–79 yrs | 22974 | NR | NR | 20 | NR | NR | NR
Hamdani, 2013^64^ | US | NR | 7 days | ≥80 yrs | 4736 | NR | NR | 15 | NR | NR | NR
Ko, 2010^65^ | US | NR | 30 days | Female | 9612 | NR | NR | NR | NR | Hospitalization - directly or potentially related to colonoscopy^#^: 25 | NR
Ko, 2010^65^ | US | NR | 30 days | Female | 9612 | NR | NR | NR | NR | Hospitalization - directly related to colonoscopy^**^: 16 | NR
Ko, 2010^65^ | US | NR | 30 days | Male | 11763 | NR | NR | NR | NR | Hospitalization - directly or potentially related to colonoscopy^#^: 43 | NR
Ko, 2010^65^ | US | NR | 30 days | Male | 11763 | NR | NR | NR | NR | Hospitalization - directly related to colonoscopy^**^: 27 | NR
Ko, 2010^65^ | US | NR | 30 days | 40–59 yrs | 9234 | NR | NR | NR | NR | Hospitalization - directly or potentially related to colonoscopy^#^: 18 | NR
Ko, 2010^65^ | US | NR | 30 days | 40–59 yrs | 9234 | NR | NR | NR | NR | Hospitalization - directly related to colonoscopy^**^: 11 | NR
Ko, 2010^65^ | US | NR | 30 days | 60–69 yrs | 6676 | NR | NR | NR | NR | Hospitalization - directly or potentially related to colonoscopy^#^: 21 | NR
Ko, 2010^65^ | US | NR | 30 days | 60–69 yrs | 6676 | NR | NR | NR | NR | Hospitalization - directly related to colonoscopy^**^: 12 | NR
Ko, 2010^65^ | US | NR | 30 days | 70–79 yrs | 4318 | NR | NR | NR | NR | Hospitalization - directly or potentially related to colonoscopy^#^: 23 | NR
Ko, 2010^65^ | US | NR | 30 days | 70–79 yrs | 4318 | NR | NR | NR | NR | Hospitalization - directly related to colonoscopy^**^: 15 | NR
Ko, 2010^65^ | US | NR | 30 days | ≥80 yrs | 1147 | NR | NR | NR | NR | Hospitalization - directly or potentially related to colonoscopy^#^: 6 | NR
Ko, 2010^65^ | US | NR | 30 days | ≥80 yrs | 1147 | NR | NR | NR | NR | Hospitalization - directly related to colonoscopy^**^: 5 | NR
Ko, 2010^65^ | US | NR | 30 days | White | 19301 | NR | NR | NR | NR | Hospitalization - directly or potentially related to colonoscopy^#^: 60 | NR
Ko, 2010^65^ | US | NR | 30 days | White | 19301 | NR | NR | NR | NR | Hospitalization - directly related to colonoscopy^**^: 38 | NR
Ko, 2010^65^ | US | NR | 30 days | Black | 1617 | NR | NR | NR | NR | Hospitalization - directly or potentially related to colonoscopy^#^: 7 | NR
Ko, 2010^65^ | US | NR | 30 days | Black | 1617 | NR | NR | NR | NR | Hospitalization - directly related to colonoscopy^**^: 5 | NR
Ko, 2010^65^ | US | NR | 30 days | Hispanic | 269 | NR | NR | NR | NR | Hospitalization - directly or potentially related to colonoscopy^#^: 2 | NR
Ko, 2010^65^ | US | NR | 30 days | Hispanic | 269 | NR | NR | NR | NR | Hospitalization - directly related to colonoscopy^**^: 1 | NR
Ko, 2010^65^ | US | NR | 30 days | Not Hispanic | 21080 | NR | NR | NR | NR | Hospitalization - directly or potentially related to colonoscopy^#^: 66 | NR
Ko, 2010^65^ | US | NR | 30 days | Not Hispanic | 21080 | NR | NR | NR | NR | Hospitalization - directly related to colonoscopy^**^: 42 | NR
Arora, 2009^66^ | US | NR | 7 days | Female | 175816 | NR | NR | 138 | OR: 21.09 (13.77, 32.29) | NR | NR
Arora, 2009^66^ | US | NR | 7 days | Male | 101618 | NR | NR | 90 | OR: 50.85 (23.57, 109.73) | NR | NR
Arora, 2009^66^ | US | NR | 7 days | 18–50 yrs | 49678 | NR | NR | 33 | OR: 26.42 (10.31, 67.67) | NR | NR
Arora, 2009^66^ | US | NR | 7 days | 50–65 yrs | 74235 | NR | NR | 53 | OR: 20.99 (10.68, 41.26) | NR | NR
Arora, 2009^66^ | US | NR | 7 days | 65–80 yrs | 118294 | NR | NR | 100 | OR: 24.80 (14.41, 42.68) | NR | NR
Arora, 2009^66^ | US | NR | 7 days | ≥80 yrs | 35227 | NR | NR | 42 | OR: 83.86 (20.30, 346.43) | NR | NR
Arora, 2009^66^ | US | NR | 7 days | White | 108946 | NR | NR | 105 | OR: 34.44 (18.51, 64.10) | NR | NR
Arora, 2009^66^ | US | NR | 7 days | Hispanic | 48365 | NR | NR | 34 | OR: 28.54 (6.53, 124.79) | NR | NR
Arora, 2009^66^ | US | NR | 7 days | Black | 26824 | NR | NR | 15 | OR: 33.07 (12.93, 84.57) | NR | NR
Arora, 2009^66^ | US | NR | 7 days | Other race | 93299 | NR | NR | 74 | OR: 19.44 (10.98, 34.42) | NR | NR
Rabeneck, 2008^67^ | CAN | 61 | 30 days | Female | 52641 | NR^††^ | OR: 0.52 (0.36, 0.74) | NR^††^ | OR: 1.21 (0.97, 1.50) | NR | NR
Rabeneck, 2008^67^ | CAN | 61 | 30 days | Male | 44450 | NR^††^ | OR: 1.00 | NR^††^ | OR: 1.00 | NR | NR
Rabeneck, 2008^67^ | CAN | 61 | 30 days | 50–59 yrs | 46967 | NR^††^ | OR: 1.00 | NR^††^ | OR: 1.00 | NR | NR
Rabeneck, 2008^67^ | CAN | 61 | 30 days | 60–75 yrs | 50124 | NR^††^ | OR: 1.60 (1.20, 2.16) | NR^††^ | OR: 2.06 (1.79, 2.37) | NR | NR
Levin, 2006^68^ | US | 62 | 30 days | Female | 6575 | NR | NR | NR | RR: 2.3 (0.9, 6.0) | Perforation, bleeding with transfusion, and diverticulitis requiring surgery: NR^‡‡^ | RR reported as reference
Levin, 2006^68^ | US | 62 | 30 days | Male | 9743 | NR | NR | NR | RR: 1.0 | Perforation, bleeding with transfusion, and diverticulitis requiring surgery: NR^‡‡^ | RR: 1.1 (0.6, 2.3)
Levin, 2006^68^ | US | 62 | 30 days | 40–59 yrs | 6962 | NR | NR | NR | RR: 1.0 | Perforation, bleeding with transfusion, and diverticulitis requiring surgery: NR^‡‡^ | RR reported as reference
Levin, 2006^68^ | US | 62 | 30 days | ≥60 yrs | 9356 | NR | NR | NR | RR: 5.2 (1.4, 19.2) | Perforation, bleeding with transfusion, and diverticulitis requiring surgery: NR^‡‡^ | RR: 2.7 (1.4, 1.5)
Rathgaber, 2006^69^ | US | 60 | 30 days | Female | 6482 | 6^§§^ | NR | 1 | NR | NR | NR
Rathgaber, 2006^69^ | US | 60 | 30 days | Male | 5925 | 17^§§^ | NR | 1 | NR | NR | NR

* Study presents risk ratios for risk of bleeding and perforation by sex. Male sex was associated with a higher risk of bleeding compared with female sex; no significant differences by sex were found for perforations

† Unspecified bleeding

‡ Includes cardiac events, pulmonary events, and neurovascular events

§ Study reports odds ratios for risk of bleeding and perforation by age subgroups with 0–39 as reference group. Older age groups (e.g., age >=70) were associated with higher risks of bleeding and perforation

ǁ Study reports odds ratios for risk of bleeding and perforation by age, sex, and race/ethnicity subgroups. Older age groups (e.g., age >=65) were associated with higher risks of bleeding and perforation compared with age 19–49, and Hispanic ethnicity and black or African American race were associated with higher risks of bleeding compared with white race. No significant differences were found for perforation by race/ethnicity, and no significant differences were found for bleeding or perforation by sex

¶ Study reports odds ratios for risk of complications (defined as perforation, splenic injury, or aspiration pneumonia) by age subgroups. Older age groups (e.g., age >=70 yrs) were associated with higher risks of complications compared with age 66–69 yrs

# Includes serious bleeding, diverticulitis, perforation, post-polypectomy syndrome, cardiovascular events, neurologic events, abdominal pain, biliary colic, perirectal abscess, pneumonia, splenic hematoma, prolonged recovery from sedation, nausea and vomiting from bowel prep, and ileus

** Includes serious bleeding, diverticulitis, perforation, post-polypectomy syndrome

†† Study reports odds ratios for risk of bleeding and perforation by age and sex groups. Older age groups (e.g., age 60–75) were associated with higher risk of bleeding and perforation compared with age 50–59 yrs. Male sex was associated with a higher risk of bleeding compared with female sex; the study found no significant differences in perforations by sex.

‡‡ Study reports rate ratios for risk of perforation, bleeding with transfusion, and diverticulitis requiring surgery by age and sex groups. Older age groups (e.g., age >= 60 yrs) were associated with higher risk of these complications compared with age 50–59 yrs. No significant differences were found by sex

§§ Serious bleeding occurring post-polypectomy

Abbreviations: CAN = Canada; CI = confidence interval; FRA = France; F/U = followup; IG = intervention (screening) group; CG = control (no screening) group; n = number; NR = not reported; MI = myocardial infarction; SAE = serious adverse events; GI = gastrointestinal; ED = emergency department; OR = odds ratio; RR = rate ratio; SAE = serious adverse events; SWE = Sweden; US = United States; wks = weeks; yrs = years