# Appendix C Excluded Studies

Code | Exclusion Criteria
E1 | Study relevance
E1a | Study relevance: Primary aim technology improvements
E2 | Study design: Not an included study design (e.g., non-nested case-control)
E2a | Study design: No reference standard
E2b | Study design: Case report
E3 | Setting (e.g., not a very high HDI country)
E4 | Population
E4a | Population: High-risk or symptomatic
E5 | Outcomes: No relevant outcomes or incomplete outcomes
E5a | Outcomes: No additional relevant data (primary article included)
E6 | Screening Test: Not one of the specified screening tests (including outdated technology)
E7 | Study quality (including a reference standard not applied to any screen negatives or a random subset of screen negatives)
E8 | Key existing SER with out of date MA
E9 | Abstract only
KQ | Key Question

Bibliography | Code
Adler, A, Wegscheider, K, . Factors determining the quality of screening colonoscopy: a prospective study on adenoma detection rates, from 12,134 examinations (Berlin colonoscopy project 3, BECOP-3). Gut. 62(2):236–241. 2013. PMID: 22442161.22442161 22442161 | KQ3E5
Adrian-de-Ganzo, Z, Alarcon-Fernandez, O, . Uptake of colon capsule endoscopy vs colonoscopy for screening relatives of patients with colorectal cancer. Clin Gastroenterol Hepatol. 13(13):2293–301.e1. 2015. PMID: 26133904. 10.1016/j.cgh.2015.06.032 26133904 | KQ2E4a
Akram, A, Juang, D, . Replacing the guaiac fecal occult blood test with the fecal immunochemical test increases proportion of individuals screened in a large healthcare setting. Clin Gastroenterol Hepatol. 15(8):1265–1270.e1. 2017. PMID: 28167157. 10.1016/j.cgh.2017.01.025 28167157 | KQ1E2a; KQ2E2a
Akyuz, U, Yilmaz, Y, . Diagnostic role of colon capsule endoscopy in patients with optimal colon cleaning. Gastroenterol Res Pract. 2016:2738208. 2016. PMID: 27066070. 10.1155/2016/2738208 27066070 | KQ2E4
Alsayid, M, Singh, MH, . Yield of colonoscopy after a positive result from a fecal immunochemical test OC-Light. Clin Gastroenterol Hepatol. 16(10):1593–1597.e1. 2018. PMID: 29660528. 10.1016/j.cgh.2018.04.014 29660528 | KQ2E2b
Amin, MF, Hassanin, AM. Diagnostic performance of CT colonography with limited cathartic preparation in colorectal cancer screening; comparison with conventional colonoscopy. Egypt J Radiol Nuclear Med. 46(3):591–598. 2015. PMID: None. 10.1016/j.ejrnm.2015.05.012 | KQ2E3
Amitay, EL, Cuk, K, . Factors associated with false-positive fecal immunochemical tests in a large German colorectal cancer screening study. Int J Cancer. 144:2419–242. 2018. PMID: 30411799. 10.1002/ijc.31972 30411799 | KQ1E1
Amitay, EL, Gies, A, . Fecal immunochemical tests for colorectal cancer screening: is fecal sampling from multiple sites necessary? Cancers (Basel). 11(3):21. 2019. PMID: 30901946. 10.3390/cancers11030400 30901946 | KQ2E7
Aniwan, S, Ratanachu-Ek, T, . Impact of fecal Hb levels on advanced neoplasia detection and the diagnostic miss rate for colorectal cancer screening in high-risk vs. average-risk subjects: a multi-center study. Clin Transl Gastroenterol. 8(8):e113. 2017. PMID: 28796231. 10.1038/ctg.2017.40 28796231 | KQ2E3
Aniwan, S, Rerknimitr, R, . A combination of clinical risk stratification and fecal immunochemical test results to prioritize colonoscopy screening in asymptomatic participants. Gastrointest Endosc. 81(3):719–27. 2015. PMID: 25708760. 10.1016/j.gie.2014.11.035 25708760 | KQ2E3
Arana-Arri, E, Imaz-Ayo, N, . Screening colonoscopy and risk of adverse events among individuals undergoing fecal immunochemical testing in a population-based program: a nested case-control study. United Eur Gastroenterol J. 6(5):755–764. 2018. PMID: 30083338. 10.1177/2050640618756105 30083338 | KQ3E2a
Atkin, W, Cross, AJ, . Faecal immunochemical tests versus colonoscopy for post-polypectomy surveillance: an accuracy, acceptability and economic study. Health Technol Assess. 23(1):1–84. 2019. PMID: 30618357. 10.3310/hta23010 30618357 | KQ2E4a
Australian Institute of Health Welfare, Australian Government Department of Health. Analysis of colorectal cancer outcomes for the Australian National Bowel Cancer Screening Program. Asia Pac J Clin Oncol. 12(1):22–32. 2016 PMID: 26803949. 10.1111/ajco.12452 26803949 | KQ2E9
Azimafousse Assogba, GF, Jezewski-Serra, D, . Impact of subsequent screening episodes on the positive predictive value for advanced neoplasia and on the distribution of anatomic subsites of colorectal cancer: a population-based study on behalf of the French colorectal cancer screening program. Cancer Epidemiol. 39(6):964–71. 2015. PMID: 26546750. 10.1016/j.canep.2015.09.008 26546750 | KQ1E2a
Baiocchi, GL, Mazzarri, G, . CT colonography for the detection of nonpolypoid colorectal lesions: a prospective series. Ann Ital Chir. 86:532–8. 2015. PMID: 26899231.26899231 | KQ2E1a
Banaszkiewicz, Z, Budzynski, J, . The fecal occult blood test as a tool for improved outpatient qualification for colonoscopy. A single-center experience and 10-year follow-up survey. Adv Med Sci. 62(1):171–176. 2017. PMID: 28282604. 10.1016/j.advms.2016.08.003 28282604 | KQ2E4a
Barzi, A, Siegel, R, . Comparative effectiveness of initiating colorectal cancer (CRC) screening (scr) at age 45. Eur J Cancer. 72:S157. 2017. PMID: None. https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01569964/full | KQ1E9
Berger, BM, Kisiel, JB, . Low incidence of aerodigestive cancers in patients with negative results from colonoscopies, regardless of findings from multi-target stool DNA tests. Clin Gastroenterol Hepatol. 18(4):864–871. 2019. PMID: 31394289. 10.1016/j.cgh.2019.07.057 31394289 | KQ1E1
Berry, E, Miller, S, . Lower abnormal fecal immunochemical test cut-off values improve detection of colorectal cancer in system-level screens. Clin Gastroenterol Hepatol. 11:11. 2019. PMID: 31085338. 10.1016/j.cgh.2019.04.077 31085338 | KQ2E2b
Bevan, R, Rubin, G, . Implementing a national flexible sigmoidoscopy screening program: results of the English early pilot. Endoscopy. 47(3):225–31. 2015. PMID: 25268309. 10.1055/s-0034-1378119 25268309 | KQ1E2a
Bjerrum, A, Andersen, O, . Long-term risk of colorectal cancer after negative colonoscopy in a Danish gFOBT screening cohort. Int J Cancer. 141(3):503–511. 2017. PMID: 28463410. 10.1002/ijc.30756 28463410 | KQ1E2a
Bjerrum, A, Andersen, O, . Colorectal cancer mortality 10 years after a single round of guaiac faecal occult blood test (gFOBT) screening: experiences from a Danish screening cohort. BMJ Open Gastroenterol. 3(1):e000120. 2016. PMID: 28074150. 10.1136/bmjgast-2016-000120 28074150 | KQ1E1
Bjerrum, A, Milter, MC, . Risk stratification and detection of new colorectal neoplasms after colorectal cancer screening with faecal occult blood test: experiences from a Danish screening cohort. Eur J Gastroenterol Hepatol. 27(12):1433–7. 2015. PMID: 26352132. 10.1097/MEG.0000000000000451 26352132 | KQ2E4a
Blom, J, Lowbeer, C, . Gender-specific cut-offs in colorectal cancer screening with FIT: increased compliance and equal positivity rate. J Med Screen. 26(2):92–7. 2019. PMID: 30336730. 10.1177/0969141318804843 30336730 | KQ1E2a
Blom, J, Tornberg, S. Interval cancers in a guaiac-based colorectal cancer screening programme: consequences on sensitivity. J Med Screen. 24(3):146–152. 2017. PMID: 28142309. 10.1177/0969141316682983 28142309 | KQ2E6
Brenner, H, Altenhofen, L, . Trends in adenoma detection rates during the first 10 years of the German screening colonoscopy program. Gastroenterology. 149(2):356–66.e1. 2015. PMID: 25911510. 10.1053/j.gastro.2015.04.012 25911510 | KQ1E2a
Brenner, H, Hoffmeister, M, . Which adenomas are detected by fecal occult blood testing? A state-wide analysis from Bavaria, Germany. Int J Cancer. 136(7):1672–9. 2015. PMID: 25142576. 10.1002/ijc.29148 25142576 | KQ2E2b
Brenner, H, Schrotz-King, P, . Declining bowel cancer incidence and mortality in Germany. Dtsch Arztebl Int. 113(7):101–6. 2016. PMID: 26940777. 10.3238/arztebl.2016.0101 26940777 | KQ1E2a
Bretagne, JF, Piette, C, . Switching from guaiac to immunochemical faecal occult blood test increases participation and diagnostic yield of colorectal cancer screening. Dig Liver Dis. 51(10):1461–1469. 2019. PMID: 31151896. 10.1016/j.dld.2019.05.004 31151896 | KQ2E2b
Brown, JP, Wooldrage, K, . Effect of once-only flexible sigmoidoscopy screening on the outcomes of subsequent faecal occult blood test screening. J Med Screen. 26(1):11–18. 2018. PMID: 30282520. 10.1177/0969141318785654 30282520 | KQ2E6
Brown, JP, Wooldrage, K, . High test positivity and low positive predictive value for colorectal cancer of continued faecal occult blood test screening after negative colonoscopy. J Med Screen. 25(2):70–75. 2018. PMID: 30282520. 10.1177/0969141317698501 28467146 | KQ2E1
Bugajski, M, Wieszczy, P, . Effectiveness of digital feedback on patient experience and 30-day complications after screening colonoscopy: a randomized health services study. Endosc Int Open. 7(4):e537–44. 2019. PMID: None. 10.1055/a-0830-4648 31041371 | KQ3E1
Bujanda, L, Sarasqueta, C, . Colorectal cancer in a second round after a negative faecal immunochemical test. Eur J Gastroenterol Hepatol. 27(7):813–8. 2015. PMID: 25856688. 10.1097/MEG.0000000000000366 25856688 | KQ2E2b
Campos S, Amaro P, Portela F, . Iatrogenic perforations during colonoscopy in a Portuguese population: a study including in and out-of-hospital procedures. GE Port J Gastroenterol. 2016;23(4):183–90. PMID: 28868458. 10.1016/j.jpge.2016.02.007 28868458 | KQ3E9
Caron, M, Lamarre, G, . The fecal immunochemical test (fit): Selected aspects regarding its effectiveness for colorectal cancer screening in Quebec City. Prev Med Rep. 12:6–11. 2018. PMID: 30116704. 10.1016/j.pmedr.2018.08.003 30116704 | KQ2E4a
Carot, L, Castells, A, . Rate of detection of serrated lesions in proximal colon by simulated sigmoidoscopy: comparison with colonoscopy and faecal immunochemical testing in a multicentre pragmatic, randomised controlled trial. Gastroenterology. 150(4):S750–s751. 2016. PMID: None. 10.1002/central/CN-01160717/full | KQ2E2b
Castro, I, Estevez, P, . Diagnostic performance of fecal immunochemical test and sigmoidoscopy for advanced right-sided colorectal neoplasms. Dig Dis Sci. 60(5):1424–32. 2015. PMID: 25407805. 10.1007/s10620-014-3434-6 25407805 | KQ2E4
Caviglia, GP, Cabianca, L, . Colorectal cancer detection in an asymptomatic population: fecal immunochemical test for hemoglobin vs. fecal M2-type pyruvate kinase. Biochem Med (Zagreb). 26(1):114–20. 2016. PMID: 26981025. 10.11613/BM.2016.012 26981025 | KQ2E2b
Chen, CH, Tsai, MK, . Extending colorectal cancer screening to persons aged 40 to 49 years with immunochemical fecal occult blood test: a prospective cohort study of 513,283 individuals. J Clin Gastroenterol. 50(9):761–8. 2016. PMID: 26905605. 10.1097/MCG.0000000000000495 26905605 | KQ2E5
Chen, CH, Yan, SL, . The relationship between the methylated septin-9 DNA blood test and stool occult blood test for diagnosing colorectal cancer in Taiwanese people. J Clin Lab Anal. 31(1):e22013. 2017. PMID: 27390118. 10.1002/jcla.22013 27390118 | KQ2E4a
Chen, H, Werner, S, . Prospective evaluation of 64 serum autoantibodies as biomarkers for early detection of colorectal cancer in a true screening setting. Oncotarget. 7(13):16420–32. 2016. PMID: 26909861. 10.18632/oncotarget.7500 26909861 | KQ2E6
Chiu, HM, Lee, YC, . Comparison of one-day and two-day sampling on detection of significant colorectal neoplasm by fecal immunochemical test-preliminary results from a population-based randomized controlled trial. Gastroenterology. 148(4):S742. 2015. PMID: None. https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01076124/full | KQ2E9
Clark, BT, Parikh, ND, . Yield of repeat forward-view examination of the right side of the colon in screening and surveillance colonoscopy. Gastrointest Endosc. 84(1):126–32. 2016. PMID: 26769408. 10.1016/j.gie.2015.12.030 26769408 | KQ2E1a
Click, B, Pinsky, PF, . Association of colonoscopy adenoma findings with long-term colorectal cancer incidence. JAMA. 319(19):2021–2031. 2018. PMID: 29800214. 10.1001/jama.2018.5809 29800214 | KQ1E1
Cock, C, Anwar, S, . Low sensitivity of fecal immunochemical tests and blood-based markers of DNA hypermethylation for detection of sessile serrated adenomas/polyps. Dig Dis Sci. 64(9):2555–2562. 2019. PMID: 30835026. 10.1007/s10620-019-05569-8 30835026 | KQ2E4a
Cole SR, Tucker GR, Osborne JM, . Shift to earlier stage at diagnosis as a consequence of the National Bowel Cancer Screening Program. Med J Australia. 2013;198(6):327–30. PMID: 23545032. 10.5694/mja12.11357 23545032 | KQ1E9
Cotter, TG, Burger, KN, . Long-term follow-up of patients having false-positive multitarget stool DNA tests after negative screening colonoscopy: the LONG-HAUL cohort study. Cancer Epidemiol Biomarkers Prevent. 26(4):614–621. 2017. PMID: 27999144. 10.1158/1055-9965.EPI-16-0800 27999144 | KQ2E1
Crouse, AL, De Koning, L, . Sensitivity and specificity of community fecal immunotesting screening for colorectal carcinoma in a high-risk Canadian population. Arch Pathol Lab Med. 139(11):1441–5. 2015. PMID: 26516941. 10.5858/arpa.2014-0454-OA 26516941 | KQ2E4a
Cubiella, J, Castro, I, . Diagnostic accuracy of fecal immunochemical test in average- and familial-risk colorectal cancer screening. United European Gastroenterol J. 2(6):522–9. 2014. PMID: 25452848. 10.1177/2050640614553285 25452848 | KQ2E4
de Klerk, CM, Wieten, E, . Performance of two faecal immunochemical tests for the detection of advanced neoplasia at different positivity thresholds: a cross-sectional study of the Dutch national colorectal cancer screening programme. Lancet Gastroenterol Hepatol. 4(2):111–118. 2019. PMID: 30497962. 10.1016/S2468-1253(18)30319-4 30497962 | KQ2E2b
de Klerk, CM, Wieten, E, . Participation and ease of use in colorectal cancer screening: a comparison of 2 fecal immunochemical tests. Am J Gastroenterol. 114(3):511–518. 2019. PMID: 30789417. 10.14309/ajg.0000000000000148 30789417 | KQ2E2b
Decker, KM, Nugent, Z, . Interval colorectal cancer rates after Hemoccult Sensa and survival by detection mode for individuals diagnosed with colorectal cancer in Winnipeg, Manitoba. PLoS One. 13(9):e0203321. 2018. PMID: 30180176. 10.1371/journal.pone.0203321 30180176 | KQ1E2a
Deng, B, Zhi, J, . The impact of colonoscopy quality control table on adenoma detection rates. Gastroenterol Res Pract. 2016:2548109. 2016. PMID: 27340398. 10.1155/2016/2548109 27340398 | KQ1E1a
Deng, L, Ismond, K, . Urinary metabolomics to identify a unique biomarker panel for detecting colorectal cancer: a multicenter study. Cancer Epidemiol Biomarkers Prevent. 28(8):1283–1291. 2019. PMID: 31151939. 10.1158/1055-9965.EPI-18-1291 31151939 | KQ2E2a
Denis, B, Gendre, I, . Participation in four rounds of a French colorectal cancer screening programme with guaiac faecal occult blood test: a population-based open cohort study. J Med Screen. 22(2):76–82. 2015. PMID: 25576338. 10.1177/0969141314567795 25576338 | KQ1E2a
Denters, MJ, Deutekom, M, . Lower risk of advanced neoplasia among patients with a previous negative result from a fecal test for colorectal cancer. Gastroenterology. 142(3):497–504. 2012. PMID: 22108194. 10.1053/j.gastro.2011.11.024 22108194 | KQ1E2a
Desai, R, Patel, U, . Does “July effect” exist in colonoscopies performed at teaching hospitals?. Transl Gastroenterol Hepatol. 3:28. 2018. PMID: 29971259. 10.21037/tgh.2018.05.04 29971259 | KQ3E1a
Devir, C, Kebapci, M, . Comparison of 64-detector CT colonography and conventional colonoscopy in the detection of colorectal lesions. Iran J Radiol. 13(1):e19518. 2016. PMID: 27110333. 10.5812/iranjradiol.19518 27110333 | KQ2E3
Digby, J, Fraser, CG, . Interval cancers using a quantitative faecal immunochemical test (FIT) for haemoglobin when colonoscopy capacity is limited. J Med Screen. 23(3):130–4. 2016. PMID: 26589788. 10.1177/0969141315609634 26589788 | KQ2E5
Dollinger, MM, Behl, S, . Early detection of colorectal cancer: a multi-center pre-clinical case cohort study for validation of a combined DNA stool test. Clin Lab. 64(10):1719–1730. 2018. PMID: 30336540. 10.7754/Clin.Lab.2018.180521 30336540 | KQ2E2a
Doubeni, CA, Corley, DA, . Effectiveness of screening colonoscopy in reducing the risk of death from right and left colon cancer: a large community-based study. Gut. 67(2):291–298. 2018. PMID: 27733426. 10.1136/gutjnl-2016-312712 27733426 | KQ1E2a
Ee, H, St John, J. The National Bowel Cancer Screening Program: time to achieve its potential to save lives. Public Health Res Pract. 29(2):31. 2019. PMID: 31384889. 10.17061/phrp2921915 31384889 | KQ1E2a
Eliakim, R, Fireman, Z, . Evaluation of the PillCam Colon capsule in the detection of colonic pathology: results of the first multicenter, prospective, comparative study. Endoscopy. 38(10):963–70. 2006. PMID: 17058158. 10.1055/s-2006-944832 17058158 | KQ2E4a
Elmunzer, BJ, Singal, AG, . Comparing the effectiveness of competing tests for reducing colorectal cancer mortality: a network meta-analysis. Gastrointest Endosc. 81(3):700–709.e3. 2015. PMID: 25708757. 10.1016/j.gie.2014.10.033 25708757 | KQ1E2a
Fernandez-Urien, I, Carretero, C, . Incidence, clinical outcomes, and therapeutic approaches of capsule endoscopy-related adverse events in a large study population. Rev Esp Enferm Dig. 107(12):745–52. 2015. PMID: 26671587. 10.17235/reed.2015.3820/2015 26671587 | KQ3E4a
Fletcher, RH. Aspirin before fecal immunochemical testing did not increase sensitivity for detecting advanced colorectal neoplasms. Ann Intern Med. 171(4):JC20. 2019. PMID: 31426063. 10.7326/ACPJ201908200-020 31426063 | KQ2E2a
Friedland, Shai, Watson, Drew, . 575: a highly sensitive and quantitative multimodal blood test for the detection of colorectal adenomas and cancer. Gastroenterology. 158(6):S121. 2020. PMID: None. | KQ2E9
Garcia, M, Mila, N, . Fecal hemoglobin concentration as a measure of risk to tailor colorectal cancer screening: are we there yet?. Eur J Cancer Prev. 24(4):321–7. 2015. PMID: 25370684. 10.1097/CEJ.0000000000000090 25370684 | KQ2E1
George, AT, Field, A. Patients with ‘interval’ colorectal cancers have worse outcomes compared with cancers in patients who decline the National Bowel Cancer Screening Programme - results from a multicentre study. Colorect Dis. 19(6):590–591. 2017. PMID: 28494513. 10.1111/codi.13719 28494513 | KQ1E9
Geraghty, J, Shawihdi, M, . Reduced risk of emergency admission for colorectal cancer associated with the introduction of bowel cancer screening across England: a retrospective national cohort study. Colorectal Disease. 20(2):94–104. 2018. PMID: 28736972. 10.1111/codi.13822 28736972 | KQ2E5
Gies, A, Cuk, K, . Head-to-head comparison of diagnostic performance of nine quantitative faecal immunochemical tests for colorectal cancer screening. United European Gastroenterol J. 5(5):a11–a12. 2017. PMID: None. 10.1177/2050640617725668 | KQ2E9
Gies, A, Cuk, K, . Direct comparison of ten quantitative fecal immunochemical tests for hemoglobin stability in colorectal cancer screening. Clin Transl Gastroenterol. 9(7):168. 2018. PMID: 29976921. 10.1038/s41424-018-0035-2 29976921 | KQ2E1
Gies, A, Niedermaier, T, . Effect of long-term frozen storage and thawing of stool samples on faecal haemoglobin concentration and diagnostic performance of faecal immunochemical tests. Clin Chem Lab Med. 28:28. 2019. PMID: 31655793. 10.1515/cclm-2019-0878 31655793 | KQ2E1
Giorgi Rossi, P, Carretta, E, . Incidence of interval cancers in faecal immunochemical test colorectal screening programmes in Italy. J Med Screen. 25(1):32–39. 2018. PMID: 28195508. 10.1177/0969141316686391 28195508 | KQ2E5
Giorgi Rossi, P, Vicentini, M, . Impact of screening program on incidence of colorectal cancer: a cohort study in Italy. Am J Gastroenterol. 110(9):1359–66. 2015. PMID: 26303133. 10.1038/ajg.2015.240 26303133 | KQ1E2a
Gluck, N, Half, EE, . Novel prep-less X-ray imaging capsule for colon cancer screening: a feasibility study. Gut. 68:774–775. 2019. PMID: 29785966. 10.1136/gutjnl-2018-316127 29785966 | KQ2E4a; KQ3E4a
Goodman, M, Fletcher, RH, . Observational methods to assess the effectiveness of screening colonoscopy in reducing right colon cancer mortality risk: SCOLAR. J Comp Eff Res. 4(6):541–51. 2015. PMID: 26201973. 10.2217/cer.15.39 26201973 | KQ1E2a
Govindarajan, A, Rabeneck, L, . Population-based assessment of the outcomes in patients with postcolonoscopy colorectal cancers. Gut. 65(6):971–6. 2016. PMID: 25748649. 10.1136/gutjnl-2014-308578 25748649 | KQ1E1
Grobbee, Ej, Van, Der Vlugt M, . Comparison of OC-sensor and fob-gold in population-based colorectal cancer screening based on FIT. Gastroenterology. 148(4 suppl 1):S160. 2015. PMID: None. https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01102682/full | KQ2E9
Guittet, L, Bouvier, V, . Colorectal cancer screening: why immunochemical faecal occult blood test performs as well with either one or two samples. Dig Liver Dis. 44(8):694–699. 2012. PMID: 22525156. 10.1016/j.dld.2012.03.005 22525156 | KQ1E2a
Guittet, L, Bouvier, V, . Performance of immunochemical faecal occult blood test in colorectal cancer screening in average-risk population according to positivity threshold and number of samples. Int J Cancer. 125(5):1127–1133. 2009. PMID: 19431212. 10.1002/ijc.24407 19431212 | KQ1E2a
Guittet, L, Bouvier, V, . Comparison of a guaiac and an immunochemical faecal occult blood test for the detection of colonic lesions according to lesion type and location. Br J Cancer. 100(8):1230–1235. 2009. PMID: 19337253. 10.1038/sj.bjc.6604996 19337253 | KQ1E2a
Halligan, S, Wooldrage, K, . Identification of extracolonic pathologies by computed tomographic colonography in colorectal cancer symptomatic patients. Gastroenterology. 149(1):89–101.e5. 2015. PMID: 25796362. 10.1053/j.gastro.2015.03.011 25796362 | KQ3E4a
Hamza, S, Dancourt, V, . Diagnostic yield of a one sample immunochemical test at different cut-off values in an organised screening programme for colorectal cancer. Eur J Cancer. 49(12):2727–2733. 2013. PMID: 23601670. 10.1016/j.ejca.2013.03.023 23601670 | KQ1E2a
Haug, U, Hillebrand, T, . Mutant-enriched PCR and allele-specific hybridization reaction to detect K-ras mutations in stool DNA: high prevalence in a large sample of older adults. Clin Chem. 53(4):787–790. 2007. PMID: 17317884. 10.1373/clinchem.2006.078188 17317884 | KQ2E8
He, N, Song, L, . The pathological features of colorectal cancer determine the detection performance on blood ctDNA. Technol Cancer Res Treat. 17:1533033818791794. 2018. PMID: 30223720. 10.1177/1533033818791794 30223720 | KQ2E3
Hilsden, RJ, Heitman, SJ, . Prediction of findings at screening colonoscopy using a machine learning algorithm based on complete blood counts (ColonFlag). PLoS One. 13(11):e0207848. 2018. PMID: 30481208. 10.1371/journal.pone.0207848 30481208 | KQ2E6
Hirata, I. Evaluation of the usefulness of the simultaneous assay of fecal hemoglobin (Hb) and transferrin (Tf) in colorectal cancer screening - for the establishment of the Hb and Tf two-step cutoff assay (HTTC assay). Diagnosis. 7(2):133–139. 2020. PMID: 31472060. 10.1515/dx-2019-0049 31472060 | KQ2E4a
Hoeck, S, Pringels, S, . First results of the Flemish colorectal cancer screening program: start-up-period late 2013. Acta Gastroenterol Belg. 79(3):421–428. 2016. PMID: 28209100.28209100 | KQ1E2a
Holleran, Grainne, Leen, Ronan, . Colon capsule endoscopy as possible filter test for colonoscopy selection in a screening population with positive fecal immunology. 46(06):473–478. 2014. PMID: 24824091. 10.1055/s-0034-1365402 24824091 | KQ2E4a
Holme, O, Schoen, RE, . Effectiveness of flexible sigmoidoscopy screening in men and women and different age groups: pooled analysis of randomised trials. BMJ. 356:i6673. 2018. PMID: 28087510. 10.1136/bmj.i6673 28087510 | KQ1E2a; KQ3E2a
Howard, R, Machado-Aranda, D. Frailty as a predictor of colonoscopic procedural risk: robust associations from fragile patients. Dig Dis Sci. 63(12):3159–60. 2018. PMID: 29934724. 10.1007/s10620-018-5172-7 29934724 | KQ3E2a
Hussey, M, Holleran, G, . Same-day colon capsule endoscopy is a viable means to assess unexplored colonic segments after incomplete colonoscopy in selected patients. United European Gastroenterol J. 6(10):1556–1562. 2018. PMID: 30574326. 10.1177/2050640618800629 30574326 | KQ2E4a
Hwang, JP, Woo, SK, . The potential usefulness of (18)F-FDG PET/CT for detecting colorectal carcinoma and adenoma in asymptomatic adults. Ann Nucl Med. 29(2):157–63. 2015. PMID: 25358843. 10.1007/s12149-014-0922-x 25358843 | KQ2E6
Jspeert JE I, Tutein Nolthenius, CJ, Kuipers, . CT-colonography vs. colonoscopy for detection of high-risk sessile serrated polyps. Am J Gastroenterol. 111(4):516–22. 2016. PMID: 27021193. 10.1038/ajg.2016.58 27021193 | KQ1E5; KQ2E5
Ibanez-Sanz, G, Garcia, M, . False-positive results in a population-based colorectal screening program: cumulative risk from 2000 to 2017 with biennial screening. Cancer Epidemiol Biomarkers Prevent. 28(11):1909–1916. 2019. PMID: 31488415. 10.1158/1055-9965.EPI-18-1368 31488415 | KQ2E5
Idigoras Rubio, I, Arana-Arri, E, . Participation in a population-based screening for colorectal cancer using the faecal immunochemical test decreases mortality in 5 years. Eur J Gastroenterol Hepatol. 31(2):197–204. 2019. PMID: 30543575. 10.1097/MEG.0000000000001338 30543575 | KQ1E2a
Idigoras, I, Arrospide, A, . Evaluation of the colorectal cancer screening programme in the Basque Country (Spain) and its effectiveness based on the Miscan-colon model. BMC Public Health. 18(1):78. 2017. PMID: 28764731. 10.1186/s12889-017-4639-3 28764731 | KQ1E2a
Igarashi, K, Hotta, K, . Can positron emission tomography detect colorectal adenomas and cancers? J Gastroenterol Hepatol. 32(3):602–608. 2017. PMID: 27548332. 10.1111/jgh.13543 27548332 | KQ2E6
Imperiale, TF, Ransohoff, DF, . Fecal DNA versus fecal occult blood for colorectal-cancer screening in an average-risk population. N Engl J Med. 351(26):2704–2714. 2004. PMID: 15616205. 10.1056/NEJMoa033403 15616205 | KQ2E8
Isohata, N, Yamada, R, . Validity and safety of colonoscopy in the very elderly: multicenter study in Japan. J Gastroenterol Hepatol (Australia). 31:216. 2016. PMID: None. 10.1111/jgh.13540 | KQ1E9; KQ3E9
Isohata, N, Shimojima, R, . Colonoscopy in patients aged 85 years or older: an observational study. J Anus Rectum Colon. 2(4):155–161. 2018. PMID: 31559358. 10.23922/jarc.2018-014 31559358 | KQ3E4a
Iuliano, D, Miranda, A, . Colorectal cancer screening in early age: preliminary data from the caserta area. Dig Liver Dis. 48:e172. 2016. PMID: None. https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01172373/full | KQ1E2a
Jensen, CD, Corley, DA, . Fecal immunochemical test program performance over 4 rounds of annual screening: a retrospective cohort study. Ann Intern Med. 164(7):456–63. 2016. PMID: 26811150. 10.7326/M15-0983 26811150 | KQ1E2a; KQ2E2a; KQ3E2a
Jin, P, Kang, Q, . Performance of a second-generation methylated SEPT9 test in detecting colorectal neoplasm. J Gastroenterol Hepatol. 30(5):830–3. 2015. PMID: 25471329. 10.1111/jgh.12855 25471329 | KQ2E3
Johnson, DH, Kisiel, JB, . Multitarget stool DNA test: clinical performance and impact on yield and quality of colonoscopy for colorectal cancer screening. Gastrointest Endosc. 85(3):657–665.e1. 2017. PMID: 27884518. 10.1016/j.gie.2016.11.012 27884518 | KQ2E1
Kallenberg, FG, Vleugels, JL, . Adding family history to faecal immunochemical testing increases the detection of advanced neoplasia in a colorectal cancer screening programme. Aliment Pharmacol Ther. 44(1):88–96. 2016. PMID: 27170502. 10.1111/apt.13660 27170502 | KQ2E5a
Kamali, M, Brake, A, . The yield and patient factors associated with CT colonography C-RADS results in a non-screening patient population. Abdom Radiol (NY). 44(9):2971–2977. 2019. PMID: 31197463. 10.1007/s00261-019-02099-9 31197463 | KQ3E4a
Kaminski, MF, Kraszewska, E, . Design of the Polish Colonoscopy Screening Program: a randomized health services study. Endoscopy. 47(12):1144–50. 2015. PMID: 26517847. 10.1055/s-0034-1392769 26517847 | KQ1E5
Kang, HJ, Kim, SH, . Sub-millisievert CT colonography: effect of knowledge-based iterative reconstruction on the detection of colonic polyps. Eur Radiol. 28(12):5258–5266. 2018. PMID: 29948063. 10.1007/s00330-018-5545-5 29948063 | KQ2E4a
Kapidzic, A, van der Meulen, MP, . Gender differences in fecal immunochemical test performance for early detection of colorectal neoplasia. Clin Gastroenterol Hepatol. 13(8):1464–71.e4. 2015. PMID: 25724706. 10.1016/j.cgh.2015.02.023 25724706 | KQ2E2b
Kastenberg, D, Burch, Wc, . Multicenter, randomized study to optimize bowel for colon capsule endoscopy. World J Gastroenterol. 23(48):8615–8625. 2017. PMID: 29358870. 10.3748/wjg.v23.i48.8615 29358870 | KQ2E1a
Kawamura, T, Nakamura, S, . Risk of colorectal cancer for fecal immunochemistry test-positive, average-risk patients after a colonoscopy. J Gastroenterol Hepatol. 34(3):532–536. 2018. PMID: 30357912. 10.1111/jgh.14517 30357912 | KQ1E4a
Keating, NL, James O’Malley, A, . Assessing the impact of colonoscopy complications on use of colonoscopy among primary care physicians and other connected physicians: an observational study of older Americans. BMJ Open. 7(6):e014239. 2017. PMID: 28645954. 10.1136/bmjopen-2016-014239 28645954 | KQ3E1
Kim, DH, Matkowskyj, KA, . Serrated polyps at CT colonography: prevalence and characteristics of the serrated polyp spectrum. Radiology. 280(2):455–63. 2016. PMID: 26878227. 10.1148/radiol.2016151608 26878227 | KQ2E4
Kim, DH, Matkowskyj, KA, . Serrated polyps are detected at CT colonography: clinical observations over the past decade and results from CTC-based screening of average risk adults. Abdom Radiol (NY). 41(8):1445–7. 2016. PMID: 27405644. 10.1007/s00261-016-0828-2 27405644 | KQ2E2a
Kim, HS, Kim, HM, . A randomized controlled trial of combined fecal immunochemical test plus sigmoidoscopy based colonoscopy vs. colonoscopy for the detection of advanced neoplasia in the average risk population. Gastrointest Endosc. 87(6):ab101–ab102. 2018. PMID: None. https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01619582/full | KQ2E2b
Kim, H, Lee, JK, . Detection of methylated SEPT9 in Korean colorectal cancer patients: comparison with previous studies. Clin Lab. 64(9):1573–1579. 2018. PMID: 30273999. 10.7754/Clin.Lab.2018.180551 30273999 | KQ2E4a
Kim, KO, Huh, KC, . Frequency and characteristics of interval colorectal cancer in actual clinical practice: a KASID multicenter study. Gut Liver. 12(5):537–543. 2018. PMID: 29938454. 10.5009/gnl17485 29938454 | KQ1E1
Kim, NH, Yang, HJ, . Does low threshold value use improve proximal neoplasia detection by fecal immunochemical test? Dig Dis Sci. 61(9):2685–93. 2016. PMID: 27107865. 10.1007/s10620-016-4169-3 27107865 | KQ2E4
Kirkoen, B, Berstad, P, . Do no harm: no psychological harm from colorectal cancer screening. Br J Cancer. 114(5):497–504. 2016. PMID: 26867161. 10.1038/bjc.2016.14 26867161 | KQ3E5
Ko, CW, Doria-Rose, VP, . Screening flexible sigmoidoscopy versus colonoscopy for reduction of colorectal cancer mortality. Int J Colorectal Dis. 34(7):1273–1281. 2019. PMID: 31152198. 10.1007/s00384-019-03300-7 31152198 | KQ1E2a
Kobaek-Larsen, M, Kroijer, R, . Back-to-back colon capsule endoscopy and optical colonoscopy in colorectal cancer screening individuals. Colorect Dis. 20(6):479–485. 2018. PMID: 29166546. 10.1111/codi.13965 29166546 | KQ2E4a
Koivogui, A, Balamou, C, . Colorectal cancer fecal screening test completion after age 74, sources and outcomes in French program. World J Gastrointest Oncol. 11(9):729–740. 2019. PMID: 31558977. 10.4251/wjgo.v11.i9.729 31558977 | KQ2E2b
Koivogui, A, Le Mab, G, . Detection of colorectal neoplasia in a cohort before and after the change of fecal occult blood test in a French colorectal cancer screening program. Am J Gastroenterol. 113(12):1891–1899. 2018. PMID: 30337703. 10.1038/s41395-018-0367-2 30337703 | KQ1E2a
Kumar, R, Choudhary, N. Colonoscopy in rural general surgery practice: challenges, outcomes, and quality measures. Am Surg. 84(1):e1–e3. 2018. PMID: 30454283.30454283 | KQ3E2a
Kwak, MS, Cha, JM, . Age-adapted variation in screening interval of fecal immunochemical test may improve its participation and colonoscopy acceptance. J Clin Gastroenterol. 51(9):825–830. 2017. PMID: 27824639. 10.1097/MCG.0000000000000743 27824639 | KQ1E2a
Lambert, L, Ourednicek, P, . Sub-milliSievert ultralow-dose CT colonography with iterative model reconstruction technique. PeerJ. 4:e1883. 2016. PMID: 27069813. 10.7717/peerj.1883 27069813 | KQ2E1a
Larsen MB, Njor S, Ingeholm P, . Effectiveness of colorectal cancer screening in detecting earlier-stage disease-a nationwide cohort study in Denmark. Gastroenterology. 2018;155(1):99–106. PMID: 29626451. 10.1053/j.gastro.2018.03.062 29626451 | KQ1E9
Lee, BJ, Balasingam, A, . Retrospective analysis of computed tomographic colonography in a rural hospital. J Med Imaging Radiat Oncol. 61(4):476–480. 2017. PMID: 28105788. 10.1111/1754-9485.12586 28105788 | KQ2E4a
Lee, CK, Choi, KS, . Risk and characteristics of postcolonoscopy interval colorectal cancer after a positive fecal test: a nationwide population-based study in Korea. Cancer Res Treat. 50(1):50–59. 2018. PMID: 28231692. 10.4143/crt.2017.027 28231692 | KQ1E2a
Lee, JK, Jensen, CD, . Long-term risk of colorectal cancer and related deaths after a colonoscopy with normal findings. JAMA Intern Med. 179(2):153–160. 2019. PMID: 30556824. 10.1001/jamainternmed.2018.5565 30556824 | KQ1E2a
Lee, YC, Hsu, CY, . Effects of screening and universal healthcare on long-term colorectal cancer mortality. Int J Epidemiol. 48(2):538–548. 2018. PMID: 30184208. 10.1093/ije/dyy182 30184208 | KQ1E2a
Levin, TR, Corley, DA, . Effects of organized colorectal cancer screening on cancer incidence and mortality in a large community-based population. Gastroenterology. 155(5):1383–1391.e5. 2018. PMID: 30031768. 10.1053/j.gastro.2018.07.017 30031768 | KQ1E2a
Lewis, Blair, Rex, Douglas, . Capsule colonoscopy—an interim report of a pilot 3 arm, blinded trial of capsule colonoscopy, virtual colonoscopy and colonoscopy: 1470(101):S559. 2006. PMID: None. | KQ1E9
Libby, G, Brewster, DH, . The impact of population-based faecal occult blood test screening on colorectal cancer mortality: a matched cohort study. Br J Cancer. 107(2):255–259. 2012. PMID: 22735907. 10.1038/bjc.2012.277 22735907 | KQ1E2a
Libby, G, Fraser, CG, . Occult blood in faeces is associated with all-cause and non-colorectal cancer mortality. Gut. 67(12):2116–2123. 2018. PMID: 30012724. 10.1136/gutjnl-2018-316483 30012724 | KQ1E2a
Lieberman, D, Sullivan, BA, . Baseline colonoscopy findings associated with 10-year outcomes in a screening cohort undergoing colonoscopy surveillance. Gastroenterology. 158(4):862–874.e8. 2020. PMID: 31376388. 10.1053/j.gastro.2019.07.052 31376388 | KQ1E2a
Lin, JS, Webber, EM, . Fecal DNA Testing in Screening for Colorectal Cancer in Average-Risk Adults. [Internet]. Rockville (MD): Agency for Healthcare Research and Quality (US); Report No.: 12-EHC022-EF. 2012. PMID: 2245788322457883. | KQ2E8
Lindholm, E, Berglund, B, . Worry associated with screening for colorectal carcinomas. Scand J Gastroenterol. 32(3):238–245. 1997. PMID: 9085461. 10.3109/00365529709000201 9085461 | KQ3E5
Lippert, E, Herfarth, HH, . Gastrointestinal endoscopy in patients aged 75 years and older: risks, complications, and findings--a retrospective study. Int J Colorectal Dis. 30(3):363–6. 2015. PMID: 25503802. 10.1007/s00384-014-2088-3 25503802 | KQ3E4a
Lynn, W, Vadhwana, B, . Computed tomography colonography: a retrospective analysis of outcomes of 2 years experience in a district general hospital. ANZ J Surg. 89(5):541–545. 2019. PMID: 30884097. 10.1111/ans.15063 30884097 | KQ3E4a
McGill, SK, Soetikno, R, . Patients with nonpolypoid (flat and depressed) colorectal neoplasms at increased risk for advanced neoplasias, compared with patients with polypoid neoplasms. Clin Gastroenterol Hepatol. 15(2):249–256.e1. 2017. PMID: 27639328. 10.1016/j.cgh.2016.08.045 27639328 | KQ1E1
Meiklejohn, DJ, Ridley, LJ, . Utility of minimal preparation computed tomography colonography in detecting colorectal cancer in elderly and frail patients. Intern Med J. 48(12):1492–1498. 2018. PMID: 29893053. 10.1111/imj.13999 29893053 | KQ2E4a
Miyanaga, R, Hosoe, N, . Complications and outcomes of routine endoscopy in the very elderly. Endosc Int Open. 6(2):E224–E229. 2018. PMID: 29423432. 10.1055/s-0043-120569 29423432 | KQ3E5
Mizukami, T, Yokoyama, A, . Screening by total colonoscopy following fecal immunochemical tests and determinants of colorectal neoplasia in Japanese men with alcohol dependence. Alcohol Alcohol. 52(2):131–137. 2017. PMID: 28182201. 10.1093/alcalc/agw071 28182201 | KQ2E4a
Mooers, HM, Holub, JL, . Screening women aged 50–59 for CRC using fecal occult blood test produces outcomes similar to men undergoing screening colonoscopy. Dig Dis Sci. 63(10):2780–2785. 2018. PMID: 29948570. 10.1007/s10620-018-5156-7 29948570 | KQ2E4a
Moosavi, S, Enns, R, . Comparison of one versus two fecal immunochemical tests in the detection of colorectal neoplasia in a population-based colorectal cancer screening program. Can J Gastroenterol Hepatol. 2016:5914048. 2016. PMID: 28044123. 10.1155/2016/5914048 28044123 | KQ1E2a
Morgan, DR, Malik, PR, . Initial US evaluation of second-generation capsule colonoscopy for detecting colon polyps. BMJ Open Gastroenterol. 3(1):e000089. 2016. PMID: 27195129. 10.1136/bmjgast-2016-000089 27195129 | KQ2E4a
Moss, S, Mathews, C, . Increased uptake and improved outcomes of bowel cancer screening with a faecal immunochemical test: results from a pilot study within the national screening programme in England. Gut. 66(9):1631–1644. 2017. PMID: 27267903. 10.1136/gutjnl-2015-310691 27267903 | KQ1E2a
Mowat, C, Digby, J, . Low sensitivity of fecal immunochemical tests (FIT) for detection of sessile serrated adenomas/polyps confirmed over clinical setting, geography, and FIT system. Dig Dis Sci. 64(10):3024–3026. 2019. PMID: 31104198. 10.1007/s10620-019-05661-z 31104198 | KQ2E4a
Murthy, SK, Benchimol, EI, . Temporal trends in postcolonoscopy colorectal cancer rates in 50- to 74-year-old persons: a population-based study. Gastrointest Endosc. 87(5):1324–1334.e4. 2018. PMID: 29317271. 10.1016/j.gie.2017.12.027 29317271 | KQ1E2a
Na, SY, Kim, KJ, . Who should undergo a colonoscopy among patients with incidental colon uptake on PET-CT? Scand J Gastroenterol. 50(8):1045–53. 2015. PMID: 25761495. 10.3109/00365521.2014.992363 25761495 | KQ2E6
Nagata, K, Endo, S, . Accuracy of CT colonography for detection of polypoid and nonpolypoid neoplasia by gastroenterologists and radiologists: a nationwide multicenter study in Japan. Am J Gastroenterol. 112(1):163–171. 2017. PMID: 27779195. 10.1038/ajg.2016.478 27779195 | KQ2E4a; KQ3E4a
Nagata, K, Fujiwara, M, . Evaluation of dose reduction and image quality in CT colonography: comparison of low-dose CT with iterative reconstruction and routine-dose CT with filtered back projection. Eur Radiol. 25(1):221–9. 2015. PMID: 25097128. 10.1007/s00330-014-3350-3 25097128 | KQ2E1a
Nagata K, Takabayashi K, Yasuda T, . Adverse events during CT colonography for screening, diagnosis and preoperative staging of colorectal cancer: a Japanese national survey. Eur Radiol. 27(12):4970–8. 2017. PMID: 28674967. 10.1007/s00330-017-4920-y 28674967 | KQ3E9
Negreanu, L, Babiuc, R, . PillCam Colon 2 capsule in patients unable or unwilling to undergo colonoscopy. World J Gastrointest Endosc. 5(11):559–67. 2013. PMID: 24255748. 10.4253/wjge.v5.i11.559 24255748 | KQ2E4a
Neri, E, Mantarro, A, . CT colonography with rectal iodine tagging: Feasibility and comparison with oral tagging in a colorectal cancer screening population. Eur J Radiol. 84(9):1701–7. 2015. PMID: 26032131. 10.1016/j.ejrad.2015.05.025 26032131 | KQ2E1a
Netz, FRS, Pickhardt, PJ, . Detection of potentially relevant extracolonic and colorectal findings at CT colonography in a low-risk symptomatic patient population. Abdom Radiol (NY). 42(12):2799–2806. 2017. PMID: 28647771. 10.1007/s00261-017-1221-5 28647771 | KQ3E4a
Nicholson, BD, James, T, . Experience of adopting faecal immunochemical testing to meet the NICE colorectal cancer referral criteria for low-risk symptomatic primary care patients in Oxfordshire, UK. Frontline Gastroenterol. 10(4):347–355. 2019. PMID: 31656559. 10.1136/flgastro-2018-101052 31656559 | KQ2E4a
O’Donoghue, D, Sheahan, K, . A national bowel cancer screening programme using FIT: achievements and challenges. Cancer Prev Res. 12(2):89–94. 2019. PMID: 30514807. 10.1158/1940-6207.CAPR-18-0182 30514807 | KQ1E2a
O’Shea, A, Murray, T, . Incidence of clinically significant perforation at low dose non-contrast CT and its value prior to same day CT colonography following incomplete colonoscopy. Abdom Radiol (NY). 45:1044–1048. 2019. PMID: 31123769. 10.1007/s00261-019-02062-8 31123769 | KQ3E4a
Okada, T, Tanaka, K, . International collaboration between Japan and Chile to improve detection rates in colorectal cancer screening. Cancer. 122(1):71–7. 2016. PMID: 26445309. 10.1002/cncr.29715 26445309 | KQ1E2a
Olaiya B, Adler DG. Adverse events after inpatient colonoscopy in octogenarians: results from the National Inpatient Sample (1998–2013). J Clin Gastroenterol. 54(9):813–818. 2020. PMID: 31764488. 10.1097/mcg.0000000000001288 31764488 | KQ3E9
Orntoft, MB, Nielsen, HJ, . Performance of the colorectal cancer screening marker Sept9 is influenced by age, diabetes and arthritis: a nested case-control study. BMC Cancer. 15:819. 2015. PMID: 26514170. 10.1186/s12885-015-1832-6 26514170 | KQ2E4a
Parente, F, Vailati, C, . Improved 5-year survival of patients with immunochemical faecal blood test-screen-detected colorectal cancer versus non-screening cancers in northern Italy. Dig Liver Dis. 47(1):68–72. 2015. PMID: 25306524. 10.1016/j.dld.2014.09.015 25306524 | KQ1E2a
Park, CH, Jung, YS, . Impact of temperature and humidity on performance of the fecal immunochemical test for advanced colorectal neoplasia. Sci Rep. 9(1):9824. 2019. PMID: 31285459. 10.1038/s41598-019-44490-y 31285459 | KQ2E4
Parker, MA, Robinson, MH, . Psychiatric morbidity and screening for colorectal cancer. J Med Screen. 9(1):7–10. 2002. PMID: 11943790. 10.1136/jms.9.1.7 11943790 | KQ3E5
Parodi, A, Vanbiervliet, G, . Colon capsule endoscopy to screen for colorectal neoplasia in those with family histories of colorectal cancer. Gastrointest Endosc. 87(3):695–704. 2018. PMID: 28554656. 10.1016/j.gie.2017.05.023 28554656 | KQ2E4a
Paszat, L, Sutradhar, R, . Interval colorectal cancers following guaiac fecal occult blood testing in the Ontario ColonCancerCheck Program. Can J Gastroenterol Hepatol. 2016:4768728. 2016. PMID: 27446842. 10.1155/2016/4768728 27446842 | KQ2E6
Pellat, A, Deyra, J, . Results of the national organised colorectal cancer screening program with FIT in Paris. Sci Rep. 8(1):4162. 2018. PMID: 29515157. 10.1038/s41598-018-22481-9 29515157 | KQ2E2b
Philipp, M, Rossmann, A, . Sudden swelling of face and neck following colonoscopy. J Dtsch Dermatol Ges. 16(5):609–610. 2018. PMID: 29578278. 10.1111/ddg.13490 29578278 | KQ3E2a
Pickhardt, PJ, Correale, L, . Positive predictive value for colorectal lesions at CT colonography: analysis of factors impacting results in a large screening cohort. AJR Am J Roentgenol. 213:W1–W8. 2019. PMID: 30973775. 10.2214/AJR.18.20686 30973775 | KQ2E4
Pickhardt, PJ, Mbah, I, . CT colonographic screening of patients with a family history of colorectal cancer: comparison with adults at average risk and implications for guidelines. AJR Am J Roentgenol. 208(4):794–800. 2017. PMID: 28125785. 10.2214/AJR.16.16724 28125785 | KQ2E2b
Pilz, JB, Portmann, S, . Colon capsule endoscopy compared to conventional colonoscopy under routine screening conditions. BMC Gastroenterol. 10:66. 2010. PMID: 20565828. 10.1186/1471-230X-10-66 20565828 | KQ2E4a
Pioche, M, Ganne, C, . Colon capsule versus computed tomography colonography for colorectal cancer screening in patients with positive fecal occult blood test who refuse colonoscopy: a randomized trial. Endoscopy. 50(8):761–769. 2018. PMID: 29486502. 10.1055/s-0044-100721 29486502 | KQ2E4a
Plumb, AA, Taylor, SA, . Effect of faecal occult blood positivity on detection rates and positive predictive value of CT colonography when screening for colorectal neoplasia. Clin Radiol. 70(10):1104–9. 2015. PMID: 26145187. 10.1016/j.crad.2015.05.013 26145187 | KQ2E4a
Pontarolo, N, Merlo, F, . Kaplan-meier cumulative survival curves: a six year experience of a large volume colonoscopy colorectal cancer screening center. Dig Liver Dis. 48:e192–e193. 2016. PMID: None. | KQ1E9
Ponugoti, PL, Rex, DK. Yield of a second screening colonoscopy 10 years after an initial negative examination in average-risk individuals. Gastrointest Endosc. 85(1):221–224. 2017. PMID: 27222282. 10.1016/j.gie.2016.05.024 27222282 | KQ1E1
Pooler, BD, Kim, DH, . Extracolonic findings at screening ct colonography: prevalence, benefits, challenges, and opportunities. AJR Am J Roentgenol. 209(1):94–102. 2017. PMID: 28333541. 10.2214/AJR.17.17864 28333541 | KQ3E1
Pooler, BD, Kim, DH, . Colorectal polyps missed with optical colonoscopy despite previous detection and localization with CT colonography. Radiology. 278(2):422–9. 2016. PMID: 26280354. 10.1148/radiol.2015150294 26280354 | KQ2E5
Prince, M, Lester, L, . Multitarget stool DNA tests increases colorectal cancer screening among previously noncompliant Medicare patients. World J Gastroenterol. 23(3):464–471. 2017. PMID: 28210082. 10.3748/wjg.v23.i3.464 28210082 | KQ2E2b
Prorok, PC, Wright, P, . Overall and multiphasic findings of the Prostate, Lung, Colorectal and Ovarian (PLCO) randomized cancer screening trial. Rev Recent Clin Trials. 13(4):257–273. 2018. PMID: 29629665. 10.2174/1574887113666180409153059 29629665 | KQ1E5; KQ3E5
Randel, KR, Botteri, E, . Effects of oral anticoagulants and aspirin on performance of fecal immunochemical tests in colorectal cancer screening. Gastroenterology. 156(6):1642–1649.e1. 2019. PMID: 30689972. 10.1053/j.gastro.2019.01.040 30689972 | KQ2E4a
Randel, Kr, Schult, Al, . Bowel cancer screening in Norway (BCSN)-a randomized pilot study comparing flexible sigmoidoscopy (FS) to fecal immunochemical test (FIT). Gastroenterology. 148(4 suppl 1):S747. 2015. PMID: None. https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01102642/full | KQ1E9
Ribbing Wilen, H, Blom, J, . Fecal immunochemical test in colorectal cancer screening: colonoscopy findings by different cut-off levels. J Gastroenterol Hepatol. 34(1):103–112. 2019. PMID: 29968937. 10.1111/jgh.14373 29968937 | KQ2E2b
Rivero-Sanchez, L, Grau, J, . Colorectal cancer after negative colonoscopy in fecal immunochemical test-positive participants from a colorectal cancer screening program. Endosc Int Open. 6(9):E1140–E1148. 2018. PMID: 30211305. 10.1055/a-0650-4296 30211305 | KQ2E4
Ruby, JA, Pusceddu, L, . Traditional serrated adenomas on ct colonography: international multicenter experience with this rare colorectal neoplasm. AJR Am J Roentgenol. 214:355–361. 2019. PMID: 31714847. 10.2214/ajr.19.21882 31714847 | KQ2E2b
Sacher-Huvelin, S, Coron, E, . Colon capsule endoscopy vs. colonoscopy in patients at average or increased risk of colorectal cancer. Aliment Pharmacol Ther. 32(9):1145–1153. 2010. PMID: 21039676. 10.1111/j.1365-2036.2010.04458.x 21039676 | KQ2E4a
Sacher-Huvelin, Sylvie, Le Rhun, Marc, . 276 wireless capsule colonoscopy compared to conventional colonoscopy in patients at moderate or increased risk for colorectal cancer. Interim Analysis of a Prospective Multicenter Study. 136(5):A53. 2009. PMID: None. | KQ2E4a
Sadeghei, A, Malekzadeh, R. Complications of colonoscopy and its management: a single gastroenterologist experience. Middle East J Dig Dis. 10(4):254–257. 2018. PMID: 31049174. 10.15171/mejdd.2018.119 31049174 | KQ3E3
Saito, Y, Saito, S, . Evaluation of the clinical efficacy of colon capsule endoscopy in the detection of lesions of the colon: prospective, multicenter, open study. Gastrointest Endosc. 82(5):861–9. 2015. PMID: 25936450. 10.1016/j.gie.2015.02.004 25936450 | KQ2E4a; KQ3E4a
Salas Trejo, D, Portillo Villares, I, . Implementation of colorectal cancer screening in Spain: main results 2006–2011. Eur J Cancer Prev. 26(1):17–26. 2017. PMID: 27167150. 10.1097/CEJ.0000000000000232 27167150 | KQ1E2a
Sali, L, Ventura, L, . Faecal immunochemical test in subjects not attending screening computed tomography colonography and colonoscopy in a randomized trial. Eur J Cancer Prev. 27(2):105–109. 2018. PMID: 27428397. 10.1097/CEJ.0000000000000284 27428397 | KQ1E2a
Sarakarn, P, Promthet, S, . Preliminary results: colorectal cancer screening using fecal immunochemical test (FIT) in a Thai population aged 45–74 years: a population-based randomized controlled trial. Asian Pac J Cancer Prev. 18(10):2883–2889. 2017. PMID: 29072830. 10.22034/APJCP.2017.18.10.2883 29072830 | KQ1E3
Schoofs, N, Deviere, J, . PillCam colon capsule endoscopy compared with colonoscopy for colorectal tumor diagnosis: a prospective pilot study. Endoscopy. 38(10):971–7. 2006. PMID: 17058159. 10.1055/s-2006-944835 17058159 | KQ2E4a
Segnan, N, Senore, C, . Proteus trial: comparing neoplasia yield and attendance of sigmoidoscopy and ct colonography in a colorectal cancer screening setting. Gastroenterology.148(4 suppl 1):S112. 2015. PMID: None. https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01089163/full | KQ1E9
Sekiguchi, M, Kakugawa, Y, . Feasibility of observational screening colonoscopy followed by deferred polypectomy. J Gastroenterol Hepatol. 35(2):263–270. 2019. PMID: 31497895. 10.1111/jgh.14851 31497895 | KQ2E4
Sekiguchi, M, Kakugawa, Y, . Sensitivity of 2-fluoro-2-deoxyglucose positron emission tomography for advanced colorectal neoplasms: a large-scale analysis of 7505 asymptomatic screening individuals. J Gastroenterol. 51(12):1122–1132. 2016. PMID: 27021493. 10.1007/s00535-016-1201-5 27021493 | KQ2E6
Shahidi, N, Gentile, L, . Correlating quantitative fecal immunochemical test results with neoplastic findings on colonoscopy in a population-based colorectal cancer screening program: a prospective study. Can J Gastroenterol Hepatol. 2016:4650471. 2016. PMID: 28116286. 10.1155/2016/4650471 28116286 | KQ2E2b
Shaukat, A, Dostal, A, . BMI is a risk factor for colorectal cancer mortality. Dig Dis Sci. 62(9):2511–2517. 2017. PMID: 28733869. 10.1007/s10620-017-4682-z 28733869 | KQ1E5
Shaukat, A, Gravely, AA, . Rates of detection of adenoma, sessile serrated adenoma, and advanced adenoma are stable over time and modifiable. Gastroenterology. 156(3):816–817. 2019. PMID: 30404025. 10.1053/j.gastro.2018.10.052 30404025 | KQ2E1
Shergill, AK, Conners, EE, . Protective association of colonoscopy against proximal and distal colon cancer and patterns in interval cancer. Gastrointest Endosc. 82(3):529–37.e1. 2015. PMID: 25936449. 10.1016/j.gie.2015.01.053 25936449 | KQ1E2a
Shin, HY, Suh, M, . Performance of the fecal immunochemical test for colorectal cancer screening using different stool-collection devices: preliminary results from a randomized controlled trial. Gut Liver. 10(6):925–931. 2016. PMID: 27282262. 10.5009/gnl15479 27282262 | KQ2E1a
Short, Matthew W, Layton, Miles C, . Colorectal cancer screening and surveillance. Am Fam Physician. 91(2):93–100. 2015. PMID: 25591210.25591210 | KQ1E2a
Sieg, Andreas, Friedrich, Kilian, . Is PillCam COLON capsule endoscopy ready for colorectal cancer screening? A prospective feasibility study in a community gastroenterology practice. 104(4):848. 2009. PMID: 19240710. 10.1038/ajg.2008.163 19240710 | KQ2E4a
Siripongpreeda, B, Mahidol, C, . High prevalence of advanced colorectal neoplasia in the Thai population: a prospective screening colonoscopy of 1,404 cases. BMC Gastroenterol. 16:101. 2016. PMID: 27553627. 10.1186/s12876-016-0526-0 27553627 | KQ2E3
Song, L, Jia, J, . The performance of the mSEPT9 assay is influenced by algorithm, cancer stage and age, but not sex and cancer location. J Cancer Res Clin Oncol. 143(6):1093–1101. 2017. PMID: 28224298. 10.1007/s00432-017-2363-0 28224298 | KQ2E3
Song, L, Peng, X, . The SEPT9 gene methylation assay is capable of detecting colorectal adenoma in opportunistic screening. Epigenomics. 9(5):599–610. 2017. PMID: 28470092. 10.2217/epi-2016-0146 28470092 | KQ2E3
Spada, C, Hassan, C, . Colon capsule versus CT colonography in patients with incomplete colonoscopy: a prospective, comparative trial. Gut. 64(2):272–81. 2015. PMID: 24964317. 10.1136/gutjnl-2013-306550 24964317 | KQ2E4a
Spada, C, Hassan, C, . Second-generation colon capsule endoscopy compared with colonoscopy. Gastrointest Endosc. 74(3):581–589 e1. 2011. PMID: 21601200. 10.1016/j.gie.2011.03.1125 21601200 | KQ2E4a
Steele, RJ, Stanners, G, . Interval cancers in a national colorectal cancer screening programme. United European Gastroenterolo J. 4(4):587–94. 2016. PMID: 27536369. 10.1177/2050640615624294 27536369 | KQ1E2a
Steffenssen, MW, Al-Najami, I, . Patient-reported complications related to colonoscopy: a prospective feasibility study of an email-based survey. Acta Oncol. 58(suppl 1):S65–S70. 2018. PMID: 30523730. 10.1080/0284186x.2018.1535188 30523730 | KQ3E4a
Stewart, R, Carter-Templeton, H. A study comparing colorectal cancer screening techniques. Gastroenterol Nurs. 40(2):121–127. 2017. PMID: 620172551. 10.1097/SGA.0000000000000207 28362661 | KQ1E5
Stock, D, Paszat, LF, . Colorectal cancer mortality reduction is associated with having at least 1 colonoscopy within the previous 10 years among a population-wide cohort of screening age. Gastrointest Endosc. 84(1):133–41. 2016. PMID: 26769406. 10.1016/j.gie.2015.12.035 26769406 | KQ1E2a
Su, SY, Huang, JY. Effect of nationwide screening program on colorectal cancer mortality in Taiwan: a controlled interrupted time series analysis. Int J Colorectal Dis. 13:13. 2019. PMID: 31834474. 10.1007/s00384-019-03468-y 31834474 | KQ1E2a
Sutton, ER, Walling, S, . Cost analysis of free colonoscopies in an uninsured population at increased risk for colorectal cancer. J Am Coll Surg. 223(1):129–32. 2016. PMID: 27238000. 10.1016/j.jamcollsurg.2016.04.035 27238000 | KQ1E4a
Swanson, SA, Holme, O, . Bounding the per-protocol effect in randomized trials: an application to colorectal cancer screening. Trials. 16:541. 2015. PMID: 26620120. 10.1186/s13063-015-1056-8 26620120 | KQ1E5
Telford, J, Gentile, L, . Performance of a quantitative fecal immunochemical test in a colorectal cancer screening pilot program: a prospective cohort study. CMAJ Open. 4(4):E668–E673. 2016. PMID: 28018880. 10.9778/cmajo.20160047 28018880 | KQ1E2a
Tepes, B, Bracko, M, . Results of the FIT-based national colorectal cancer screening program in Slovenia. J Clin Gastroenterol. 51(6):e52–e59. 2017. PMID: 27552327. 10.1097/MCG.0000000000000662 27552327 | KQ2E2b
Tikk, K, Czock, D, . Clinical trial protocol of the ASTER trial: a double-blind, randomized, placebo-controlled phase III trial evaluating the use of acetylsalicylic acid (ASA) for enhanced early detection of colorectal neoplasms. BMC Cancer. 18(1):914. 2018. PMID: 30249195. 10.1186/s12885-018-4826-3 30249195 | KQ2E5
Toes-Zoutendijk, E, van Leerdam, ME, . Real-time monitoring of results during first year of Dutch colorectal cancer screening program and optimization by altering fecal immunochemical test cut-off levels. Gastroenterology. 152(4):767–775.e2. 2017. PMID: 27890769. 10.1053/j.gastro.2016.11.022 27890769 | KQ2E2b
Ulla-Rocha, JL, Salgado, A, . Iatrogenic colonic perforations: changing the paradigm. Surg Laparosc Endosc Percutan Tech. 29(3):173–177. 2019. PMID: 30608917. 10.1097/SLE.0000000000000610 30608917 | KQ3E4a
Utano, K, Nagata, K, . Diagnostic performance and patient acceptance of reduced-laxative CT colonography for the detection of polypoid and non-polypoid neoplasms: a multicenter prospective trial. Radiology. 282(2):399–407. 2017. PMID: 27580426. 10.1148/radiol.2016160320 27580426 | KQ2E4a
van der Meulen, MP, Lansdorp-Vogelaar, I, . Colorectal cancer: cost-effectiveness of colonoscopy versus CT colonography screening with participation rates and costs. Radiology. 287(3):901–911. 2018. PMID: 29485322. 10.1148/radiol.2017162359 29485322 | KQ1E2a
Vicentini M, Zorzi M, Bovo E, . Impact of screening programme using the faecal immunochemical test on stage of colorectal cancer: results from the IMPATTO study. Int J Cancer. 2019. PMID: 30585621. 10.1002/ijc.32089 30585621 | KQ1E9
Vitellius, C, Laly, M, . Contribution of the OC Sensor((R)) immunoassay in comparison to the Hemoccult II((R)) guaiac-test in organized colorectal cancer screening. Eur J Epidemiol. 34(2):163–172. 2018. PMID: 30536183. 10.1007/s10654-018-0471-z 30536183 | KQ1E4a
Vleugels, JLA, Koens, L, . Suboptimal endoscopic cancer recognition in colorectal lesions in a national bowel screening programme. Gut. 69(6):977–980. 2020. PMID: 31822579. 10.1136/gutjnl-2018-316882 31822579 | KQ2E4a
Wang, YR, Cangemi, JR, . Decreased risk of colorectal cancer after colonoscopy in patients 76-85 years old in the united states. Digestion. 93(2):132–8. 2016. PMID: 26636320. 10.1159/000442571 26636320 | KQ1E2a
Wardle, J, Williamson, S, . Psychological impact of colorectal cancer screening. Health Psychol. 22(1):54–59. 2003. PMID: 12558202. 10.1037//0278-6133.22.1.54 12558202 | KQ3E5
Wieszczy, P, Kaminski, MF, . Colorectal cancer incidence and mortality after removal of adenomas during screening colonoscopies. Gastroenterology. 158(4):875–883.e5. 2020. PMID: 31563625. 10.1053/j.gastro.2019.09.011 31563625 | KQ1E2a
Wieten, E, de, Klerk Cm, . Equivalent accuracy of 2 quantitative fecal immunochemical tests in detecting advanced neoplasia in an organized colorectal cancer screening program. Gastroenterology. 155(5):1392–1399. 2018. PMID: 30055170. 10.1053/j.gastro.2018.07.021 30055170 | KQ2E2b
Wieten, E, de Klerk, CM, . A quarter of participants with advanced neoplasia have discordant results from 2-sample fecal immunochemical tests for colorectal cancer screening. Clin Gastroenterol Hepatol. 18(8):1805–1811.e1. 2020. PMID: 31563557. 10.1016/j.cgh.2019.09.024 31563557 | KQ2E2b
Wieten, E, Schreuders, EH, . Effects of increasing screening age and fecal hemoglobin cutoff concentrations in a colorectal cancer screening program. Clin Gastroenterol Hepatol. 14(12):1771–1777. 2016. PMID: 27567693. 10.1016/j.cgh.2016.08.016 27567693 | KQ2E2b
Wu, D, Zhou, G, . Detection of colorectal cancer using a simplified SEPT9 gene methylation assay is a reliable method for opportunistic screening. J Mol Diagn. 18(4):535–45. 2016. PMID: 27133379. 10.1016/j.jmoldx.2016.02.005 27133379 | KQ2E3
Yamada, K, Nakamura, M, . Clinical factors associated with missing colorectal polyp on colon capsule endoscopy. Digestion. 101(3):316–322. 2019. PMID: 30889601. 10.1159/000498942 30889601 | KQ2E4a
You JJ, Liu Y, Kirby J, . Virtual colonoscopy, optical colonoscopy, or fecal occult blood testing for colorectal cancer screening: results of a pilot randomized controlled trial. Trials. 2015;16:296. PMID: 26156248. 10.1186/s13063-015-0826-7 26156248 | KQ1E9
Yuan, SY, Wu, W, . Quantitative immunochemical fecal occult blood test for neoplasia in colon cancer screening. J Dig Dis. 20(2):78–82. 2019. PMID: 30714346. 10.1111/1751-2980.12711 30714346 | KQ1E3
Ziemlewicz, TJ, Kim, DH, . Computer-aided detection of colorectal polyps at CT colonography: prospective clinical performance and third-party reimbursement. AJR Am J Roentgenol. 208(6):1244–1248. 2017. PMID: 28753031. 10.2214/AJR.16.17499 28753031 | KQ2E1a
Zimmermann-Fraedrich, K, Sehner, S, . Right-sided location not associated with missed colorectal adenomas in an individual-level reanalysis of tandem colonoscopy studies. Gastroenterology. 157(3):660–671.e2. 2019. PMID: 31103625. 10.1053/j.gastro.2019.05.011 31103625 | KQ2E5
Zorzi, M, Da Re, F, . Screening for colorectal cancer in Italy: 2011–2012 survey. Epidemiol Prev. 39(3 Suppl 1):93–107. 2015. PMID: 26405781.26405781 | KQ2E2b
Zorzi, M, Fedeli, U. Early effect of screening programmes on incidence and mortality rates of colorectal cancer. Gut. 64(6):1007. 2015. PMID: 25539674. 10.1136/gutjnl-2014-308970 25539674 | KQ1E2a
Zorzi, M, Fedeli, U, . Impact on colorectal cancer mortality of screening programmes based on the faecal immunochemical test. Gut. 64(5):784–90. 2015. PMID: 25179811. 10.1136/gutjnl-2014-307508 25179811 | KQ1E2a
Zorzi, M, Hassan, C, . Long-term performance of colorectal cancerscreening programmes based on the faecal immunochemical test. Gut. 67(12):2124–2130. 2018. PMID: 29101260. 10.1136/gutjnl-2017-314753 29101260 | KQ2E2b
Zorzi, M, Hassan, C, . Divergent long-term detection rates of proximal and distal advanced neoplasia in fecal immunochemical test screening programs: a retrospective cohort study. Ann Intern Med. 169(9):602–609. 2018. PMID: 30285055. 10.7326/M18-0855 30285055 | KQ1E2a