# Appendix B Included Studies

## Below is a list of included studies and their ancillary publications (indented below main results publication)

### Key Question 1

1. Atkin WS, Wooldrage K, Parkin DM, . Long term effects of once-only flexible sigmoidoscopy screening after 17 years of follow-up: the UK Flexible Sigmoidoscopy Screening randomised controlled trial. Lancet. 2017;389(10076):1624–33. PMID: 28236467. 10.1016/S0140-6736(17)30396-3 28236467
  a. Atkin WS. Single flexible sigmoidoscopy screening to prevent colorectal cancer: baseline findings of a UK multicentre randomised trial. Lancet. 2002;359(9314):1291–300. PMID: 11965274. 10.1016/S0140-6736(02)08268-5 11965274
  b. Atkin WS, Edwards R, Kralj-Hans I, . Once-only flexible sigmoidoscopy screening in prevention of colorectal cancer: a multicentre randomised controlled trial. Lancet. 2010;375(9726):1624–33. 10.1016/S0140-6736(10)60551-X 20430429
  c. Miles A, Wardle J, McCaffery K, . The effects of colorectal cancer screening on health attitudes and practices. Cancer Epidemiol Biomarkers Prev. 2003;12(7):651–5. PMID: 12869406.12869406
2. Berry DP, Clarke P, Hardcastle JD, . Randomized trial of the addition of flexible sigmoidoscopy to faecal occult blood testing for colorectal neoplasia population screening. Br J Surg. 1997;84(9):1274–6. PMID: 9313712.9313712
3. Brevinge H, Lindholm E, Buntzen S, . Screening for colorectal neoplasia with faecal occult blood testing compared with flexible sigmoidoscopy directly in a 55–56 years’ old population. Int J Colorectal Dis. 1997;12(5):291–5. PMID: 9401844. 10.1007/s003840050108 9401844
4. Chiu HM, Chen SL, Yen AM, . Effectiveness of fecal immunochemical testing in reducing colorectal cancer mortality from the One Million Taiwanese Screening Program. Cancer. 2015;121(18):3221–9. PMID: 25995082. 10.1002/cncr.29462 25995082
5. Faivre J, Dancourt V, Denis B, . Comparison between a guaiac and three immunochemical faecal occult blood tests in screening for colorectal cancer. Eur J Cancer. 2012;48(16):2969–76. PMID: 22572481. 10.1016/j.ejca.2012.04.007 22572481
  a. Faivre J, Dancourt V, Manfredi S, . Positivity rates and performances of immunochemical faecal occult blood tests at different cut-off levels within a colorectal cancer screening programme. Dig Liver Dis. 2012;44(8):700–4. PMID: 22542582. 10.1016/j.dld.2012.03.015 22542582
6. Faivre J, Dancourt V, Lejeune C, . Reduction in colorectal cancer mortality by fecal occult blood screening in a French controlled study. Gastroenterology. 2004;126(7):1674–80. PMID: 15188160. 10.1053/j.gastro.2004.02.018 15188160
7. Garcia-Albeniz X, Hsu J, Bretthauer M, . Effectiveness of screening colonoscopy to prevent colorectal cancer among Medicare beneficiaries aged 70 to 79 years: a prospective observational study. Ann Intern Med. 2017;166(1):18–26. PMID: 27669524. 10.7326/M16-0758 27669524
8. Grobbee EJ, van der Vlugt M, van Vuuren AJ, . Diagnostic yield of one-time colonoscopy vs one-time flexible sigmoidoscopy vs multiple rounds of mailed fecal immunohistochemical tests in colorectal cancer screening. Clin Gastroenterol Hepatol. 2019;13:13. 10.1016/j.cgh.2019.08.015
9. Hol L, van Leerdam ME, van Ballegooijen M, . Screening for colorectal cancer: randomised trial comparing guaiac-based and immunochemical faecal occult blood testing and flexible sigmoidoscopy. Gut. 2010;59(1):62–8. PMID: 19671542. 10.1136/gut.2009.177089 19671542
10. Holme O, Loberg M, Kalager M, . Long-term effectiveness of sigmoidoscopy screening on colorectal cancer incidence and mortality in women and men: a randomized trial. JAMA. 2018;168(11):775–782. PMID: 29710125. 10.7326/M17-1441 29710125
  a. Hoff G, Grotmol T, Skovlund E, . Risk of colorectal cancer seven years after flexible sigmoidoscopy screening: randomised controlled trial. BMJ. 2009;338:b1846. PMID: 19483252. 10.1136/bmj.b1846 19483252
  b. Holme O, Bretthauer M, Eide TJ, . Long-term risk of colorectal cancer in individuals with serrated polyps. Gut. 2015;64(6):929–36. PMID: 25399542. 10.1136/gutjnl-2014-307793 25399542
  c. Holme O, Loberg M, Kalager M, . Effect of flexible sigmoidoscopy screening on colorectal cancer incidence and mortality: a randomized clinical trial. Ann Intern Med. 2014;312(6):606–15. PMID: 2971012529710125
  d. Gondal G, Grotmol T, Hofstad B, . The Norwegian Colorectal Cancer Prevention (NORCCAP) screening study: baseline findings and implementations for clinical work-up in age groups 50–64 years. Scand J Gastroenterol. 2003;38(6):635–42. PMID: 12825872. 10.1080/00365520310003002 12825872
  e. Jodal HC, Loberg M, Holme O, . Mortality from postscreening (interval) colorectal cancers is comparable to that from cancer in unscreened patients-a randomized sigmoidoscopy trial. Gastroenterology. 2018;155(6):1787–94.e3. PMID: 30165051. 10.1053/j.gastro.2018.08.035 30165051
11. Kronborg O, Jorgensen OD, Fenger C, . Randomized study of biennial screening with a faecal occult blood test: results after nine screening rounds. Scand J Gastroenterol. 2004;39(9):846–51. PMID: 15513382. 10.1080/00365520410003182 15513382
12. Lindholm E, Brevinge H, Haglind E. Survival benefit in a randomized clinical trial of faecal occult blood screening for colorectal cancer. Br J Surg. 2008;95(8):1029–36. PMID: 18563785. 10.1002/bjs.6136 18563785
  a. Kewenter J, Brevinge H. Endoscopic and surgical complications of work-up in screening for colorectal cancer. Dis Colon Rectum. 1996;39(6):676–80. PMID: 8646956. 10.1007/bf02056949 8646956
  b. Kewenter J, Brevinge H, Engaras B, . Results of screening, rescreening, and follow-up in a prospective randomized study for detection of colorectal cancer by fecal occult blood testing. Results for 68,308 subjects. Scand J Gastroenterol. 1994;29(5):468–73. PMID: 8036464. 10.3109/00365529409096840 8036464
13. Miller EA, Pinsky PF, Schoen RE, . Effect of flexible sigmoidoscopy screening on colorectal cancer incidence and mortality: long-term follow-up of the randomised US PLCO cancer screening trial. Lancet Gastroenterol Hepatol. 2019;4(2):101–10. PMID: 30502933. 10.1016/S2468-1253(18)30358-3 30502933
  a. Doroudi M, Schoen RE, Pinsky PF. Early detection versus primary prevention in the PLCO flexible sigmoidoscopy screening trial: which has the greatest impact on mortality? Cancer. 2017;123(24):4815–22. PMID: 28976536. 10.1002/cncr.31034 28976536
  b. Laiyemo AO, Doubeni C, Pinsky PF, . Occurrence of distal colorectal neoplasia among whites and blacks following negative flexible sigmoidoscopy: an analysis of PLCO Trial. J Gen Intern Med. 2015;30(10):1447–53. PMID: 25835747. 10.1007/s11606-015-3297-3 25835747
  c. Pinsky P, Miller E, Zhu C, . Overall mortality in men and women in the randomized Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. J Med Screen [serial on the Internet]. 2019 [cited Bridge 1 - CENTRAL: Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01941335/full https://journals.sagepub.com/doi/pdf/10.1177/0969141319839097
  d. Schoen RE, Pinsky PF, Weissfeld JL, . Colorectal-cancer incidence and mortality with screening flexible sigmoidoscopy. N Engl J Med. 2012;366(25):2345–57. PMID: 22612596. 10.1016/S2468-1253(18)30358-3 22612596
  e. Schoen RE, Razzak A, Yu KJ, . Incidence and mortality of colorectal cancer in individuals with a family history of colorectal cancer. Gastroenterology. 2015;149(6):1438–45.e1. PMID: 26255045. 10.1053/j.gastro.2015.07.055 26255045
  f. Weissfeld JL, Schoen RE, Pinsky PF, . Flexible sigmoidoscopy in the PLCO cancer screening trial: results from the baseline screening examination of a randomized trial. J Natl Cancer Inst. 2005;97(13):989–97. PMID: 15998952. 10.1093/jnci/dji175 15998952
14. Nishihara R, Wu K, Lochhead P, . Long-term colorectal-cancer incidence and mortality after lower endoscopy. N Engl J Med. 2013;369(12):1095–105. PMID: 24047059. 10.1056/NEJMoa1301969 24047059
15. Passamonti B, Malaspina M, Fraser CG, . A comparative effectiveness trial of two faecal immunochemical tests for haemoglobin (FIT). Assessment of test performance and adherence in a single round of a population-based screening programme for colorectal cancer. Gut. 2018;67(3):485–96. PMID: 27974550. 10.1136/gutjnl-2016-312716 27974550
16. Pitkaniemi J, Seppa K, Hakama M, . Effectiveness of screening for colorectal cancer with a faecal occult-blood test, in Finland. BMJ Open Gastroenterology. 2015;2:e000034. PMID: 26462283. 10.1136/bmjgast-2015-000034 26462283
  a. Koskenvuo L, Malila N, Pitkaniemi J, . Sex differences in faecal occult blood test screening for colorectal cancer. Br J Surg. 2019;106(4):436–447. PMID: 30460999. 10.1002/bjs.11011 30460999
  b. Malila N, Oivanen T, Malminiemi O, . Test, episode, and programme sensitivities of screening for colorectal cancer as a public health policy in Finland: experimental design. BMJ. 2008;337:a2261. PMID: 19022840. 10.1136/bmj.a2261 19022840
  c. Malila N, Palva T, Malminiemi O, . Coverage and performance of colorectal cancer screening with the faecal occult blood test in Finland. J Med Screen. 2011;18(1):18–23. PMID: 21536812. 10.1258/jms.2010.010036 21536812
17. Quintero E, Castells A, Bujanda L, . Colonoscopy versus fecal immunochemical testing in colorectal-cancer screening. N Engl J Med. 2012;366(8):697–706. PMID: 22356323. 10.1056/NEJMoa1108895 22356323
  a. Castells A, Quintero E. Programmatic screening for colorectal cancer: the COLONPREV study. Dig Dis Sci. 2015;60(3):672–80. PMID: 25492501. 10.1007/s10620-014-3446-2 25492501
  b. Parra-Blanco A, Nicolas-Perez D, Gimeno-Garcia A, . The timing of bowel preparation before colonoscopy determines the quality of cleansing, and is a significant factor contributing to the detection of flat lesions: a randomized study. World J Gastroenterol. 2006;12(38):6161–6. PMID: 17036388. 10.3748/wjg.v12.i38.6161 17036388
18. Rasmussen M, Kronborg O, Fenger C, . Possible advantages and drawbacks of adding flexible sigmoidoscopy to hemoccult-II in screening for colorectal cancer. A randomized study. Scand J Gastroenterol. 1999;34(1):73–8. PMID: 10048736. 10.1080/00365529950172862 10048736
19. Regge D, Iussich G, Segnan N, . Comparing CT colonography and flexible sigmoidoscopy: a randomised trial within a population-based screening programme. Gut. 2017;66(8):1434–40. PMID: 27196588. 10.1136/gutjnl-2015-311278 27196588
  a. Senore C, Correale L, Regge D, . Flexible sigmoidoscopy and CT colonography screening: patients’ experience with and factors for undergoing screening-insight from the Proteus Colon Trial. Radiology. 2018;286(3):873–83. PMID: 29040021. 10.1148/radiol.2017170228 29040021
20. Sali L, Mascalchi M, Falchini M, . Reduced and full-preparation CT colonography, fecal immunochemical test, and colonoscopy for population screening of colorectal cancer: a randomized trial. J Natl Cancer Inst. 2016;108(2):djv319. PMID: 26719225 10.1093/jnci/djv319 26719225
21. Santare D, Kojalo I, Liepniece-Karele I, . Comparison of the yield from two faecal immunochemical tests at identical cutoff concentrations - a randomized trial in Latvia. Eur J Gastroenterol Hepatol. 2016;28(8):904–10. PMID: 27120388. 10.1097/MEG.0000000000000650 27120388
22. Scholefield JH, Moss SM, Mangham CM, . Nottingham trial of faecal occult blood testing for colorectal cancer: a 20-year follow-up. Gut. 2012;61(7):1036–40. PMID: 22052062. 10.1136/gutjnl-2011-300774 22052062
  a. Hardcastle JD, Chamberlain JO, Robinson MH, . Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348(9040):1472–7. PMID: 8942775. 10.1016/S0140-6736(96)03386-7 8942775
23. Schreuders EH, Grobbee EJ, Nieuwenburg SA, . Multiple rounds of one sample versus two sample faecal immunochemical test-based colorectal cancer screening: a population-based study. Lancet Gastroenterol Hepatol. 2019;4(8):622–631. PMID: 31196734.31196734
  a. Dube C, Tinmouth J. Number of samples in faecal immunochemical test screening: more might be less. Lancet Gastroenterol Hepatol. 2019;4(8):577–8. PMID: 31196733. 10.1016/S2468-1253(19)30191-8 31196733
  b. Kapidzic A, van Roon AH, van Leerdam ME, . Attendance and diagnostic yield of repeated two-sample faecal immunochemical test screening for colorectal cancer. Gut. 2017;66(1):118–23. 10.1136/gutjnl-2014-308957 26370109
  c. van Roon AH, Wilschut JA, Hol L, . Diagnostic yield improves with collection of 2 samples in fecal immunochemical test screening without affecting attendance. Clin Gastroenterol Hepatol. 2011;9(4):333–9. PMID: 21185397. 10.1016/j.cgh.2010.12.012 21185397
24. Segnan N, Armaroli P, Bonelli L, . Once-only sigmoidoscopy in colorectal cancer screening: follow-up findings of the Italian Randomized Controlled Trial--SCORE. J Natl Cancer Inst. 2011;103(17):1310–22. PMID: 21852264. 10.1093/jnci/djr284 21852264
  a. Segnan N, Senore C, Andreoni B, . Baseline findings of the Italian multicenter randomized controlled trial of “once-only sigmoidoscopy”--SCORE. J Natl Cancer Inst. 2002;94(23):1763–72. PMID: 12464648. 10.1093/jnci/94.23.1763 12464648
25. Segnan N, Senore C, Andreoni B, . Randomized trial of different screening strategies for colorectal cancer: patient response and detection rates. J Natl Cancer Inst. 2005;97(5):347–57. PMID: 1574157. 10.1093/jnci/dji050 15741571
26. Segnan N, Senore C, Andreoni B, . Comparing attendance and detection rate of colonoscopy with sigmoidoscopy and FIT for colorectal cancer screening. Gastroenterology. 2007;132(7):2304–12. PMID: 17570205. 10.1053/j.gastro.2007.03.030 17570205
27. Shaukat A, Mongin SJ, Geisser MS, . Long-term mortality after screening for colorectal cancer. N Engl J Med. 2013;369(12):1106–14. PMID: 24047060. 10.1056/NEJMoa1300720 24047060
  a. Mandel JS, Bond JH, Church TR, . Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med. 1993;328(19):1365–71. PMID: 8474513. 10.1056/NEJM199305133281901 8474513
  b. Mandel JS, Church TR, Bond JH, . The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. 2000;343(22):1603–7. PMID: 11096167. 10.1056/NEJM200011303432203 11096167
  c. Thomas W, White CM, Mah J, . Longitudinal compliance with annual screening for fecal occult blood. Minnesota Colon Cancer Control Study. Am J Epidemiol. 1995;142(2):176–82. PMID: 7598117. 10.1093/oxfordjournals.aje.a117616 7598117
28. Steele RJ, Carey FA, Stanners G, . Randomized controlled trial: flexible sigmoidoscopy as an adjunct to faecal occult blood testing in population screening. J Med Screen. 2020;27(2):59–67. 10.1177/0969141319879955 31690179
29. Stoop EM, de Haan MC, de Wijkerslooth TR, . Participation and yield of colonoscopy versus non-cathartic CT colonography in population-based screening for colorectal cancer: a randomised controlled trial. Lancet Oncol. 2012;13(1):55–64. PMID: 22088831. 10.1016/S1470-2045(11)70283-2 22088831
30. van Roon AH, Goede SL, van Balleooijen M, . Random comparison of repeated faecal immunochemical testing at different intervals for population-based colorectal cancer screening. Gut. 2013;62(3):409–15. PMID: 22387523. 10.1136/gutjnl-2011-301583 22387523
31. van Rossum LG, van Rijn AF, Laheij RJ, . Random comparison of guaiac and immunochemical fecal occult blood tests for colorectal cancer in a screening population. Gastroenterology. 2008;135(1):82–90. PMID: 18482589. 10.1053/j.gastro.2008.03.040 18482589
  a. Denters MJ, Deutekom M, Fockens P, . Implementation of population screening for colorectal cancer by repeated fecal occult blood test in the Netherlands. BMC Gastroenterology. 2009;9:28. PMID: 19393087. 10.1186/1471-230X-9-28 19393087
  b. Grobbee EJ, Wieten E, Hansen BE, . Fecal immunochemical test-based colorectal cancer screening: the gender dilemma. United European Gastroenterol. 2017;5(3):448–54. PMID: 28507758. 10.1177/2050640616659998 28507758
32. Verne JE, Aubrey R, Love SB, . Population based randomised study of uptake and yield of screening by flexible sigmoidoscopy compared with screening by faecal occult blood testing. BMJ. 1998;317(7152):182–5. PMID: 9665902. 10.1136/bmj.317.7152.182 9665902
33. Zubero MB, Arana-Arri E, Pijoan JI, . Population-based colorectal cancer screening: comparison of two fecal occult blood test. Front Pharmacol. 2014;4:175. PMID: 24454288. 10.3389/fphar.2013.00175 24454288

### Key Question 2

1. Ahlquist DA, Sargent DJ, Loprinzi CL, . Stool DNA and occult blood testing for screen detection of colorectal neoplasia. Ann Intern Med. 2008;149(7):441–50. PMID: 18838724. 10.7326/0003-4819-149-7-200810070-00004 18838724
2. Allison J, Tekawa IS, Ransom LJ, . A comparison of fecal occult-blood tests for colorectal-cancer screening. N Engl J Med. 1996;334(3):155–9. PMID: 8531970. 10.1056/NEJM199601183340304 8531970
3. Allison JE, Sakoda LC, Levin TR, . Screening for colorectal neoplasms with new fecal occult blood tests: update on performance characteristics. J Natl Cancer Inst. 2007;99(19):1462–70. PMID: 17895475. 10.1093/jnci/djm150 17895475
4. Arana-Arri E, Idigoras I, Uranga B, . Population-based colorectal cancer screening programmes using a faecal immunochemical test: should faecal haemoglobin cut-offs differ by age and sex? BMC Cancer. 2017;17(1):577. PMID: 28851318. 10.1186/s12885-017-3555-3 28851318
5. Brenner H, Chen H. Fecal occult blood versus DNA testing: indirect comparison in a colorectal cancer screening population. Clin Epidemiol. 2017;9:377–84. PMID: 28761377. 10.2147/CLEP.S136565 28761377
  a. Brenner H, Werner S. Selecting a cut-off for colorectal cancer screening with a fecal immunochemical test. Clin Transl Gastroenterol. 2017;8(8):e111. PMID: 28771240. 10.1038/ctg.2017.37 28771240
  b. Chen H, Werner S, Brenner H. Fresh vs frozen samples and ambient temperature have little effect on detection of colorectal cancer or adenomas by a fecal immunochemical test in a colorectal cancer screening cohort in Germany. Clin Gastroenterol Hepatol. 2017;15(10):1547–56.e5. PMID: 27793749. 10.1016/j.cgh.2016.10.018 27793749
  c. Niedermaier T, Weigl K, Hoffmeister M, . Diagnostic performance of one-off flexible sigmoidoscopy with fecal immunochemical testing in a large screening population. Epidemiology. 2018;29(3):397–406. PMID: 29287053. 10.1097/EDE.0000000000000795 29287053
6. Brenner H, Tao S. Superior diagnostic performance of faecal immunochemical tests for haemoglobin in a head-to-head comparison with guaiac based faecal occult blood test among 2235 participants of screening colonoscopy. Eur J Cancer. 2013;49(14):3049–54. PMID: 23706981. 10.1016/j.ejca.2013.04.023 23706981
  a. Brenner H, Haug U, Hundt S. Inter-test agreement and quantitative cross-validation of immunochromatographical fecal occult blood tests. Int J Cancer. 2010;127(7):1643–9. PMID: 20049840. 10.1002/ijc.25154 20049840
  b. Brenner H, Haug U, Hundt S. Sex differences in performance of fecal occult blood testing. Am J Gastroenterol. 2010;105(11):2457–64. PMID: 20700114. 10.1038/ajg.2010.301 20700114
  c. Brenner H, Niedermaier T, Chen H. Strong subsite-specific variation in detecting advanced adenomas by fecal immunochemical testing for hemoglobin. Int J Cancer. 2017;140(9):2015–22. PMID: 28152558. 10.1002/ijc.30629 28152558
  d. Brenner H, Qian J, Werner S. Variation of diagnostic performance of fecal immunochemical testing for hemoglobin by sex and age: results from a large screening cohort. Clin Epidemiol. 2018;10:381–9. PMID: 29670403. 10.2147/CLEP.S155548 29670403
  e. Hundt S, Haug U, Brenner H. Comparative evaluation of immunochemical fecal occult blood tests for colorectal adenoma detection. Ann Intern Med. 2009;150(3):162–9. PMID: 19189905. 10.7326/0003-4819-150-3-200902030-00005 19189905
  f. Haug U, Kuntz KM, Knudsen AB, . Sensitivity of immunochemical faecal occult blood testing for detecting left- vs right-sided colorectal neoplasia. Br J Cancer. 2011;104(11):1779–85. PMID: 21559011. 10.1038/bjc.2011.160 21559011
7. Bosch LJ, Melotte V, Mongera S, . Multitarget stool DNA test performance in an average-risk colorectal cancer screening population. Am J Gastroenterol. 2019;114(12):1909–18. 10.14309/ajg.0000000000000445 31764091
8. Castiglione G, Visioli CB, Ciatto S, . Sensitivity of latex agglutination faecal occult blood test in the Florence District population-based colorectal cancer screening programme. Br J Cancer. 2007;96(11):1750–4. PMID: 17453007. 10.1038/sj.bjc.6603759 17453007
  a. Grazzini G, Castiglione G, Ciabattoni C, . Colorectal cancer screening programme by faecal occult blood test in Tuscany: first round results. Eur J Cancer Prev. 2004;13(1):19–26. PMID: 15075784. 10.1097/00008469-200402000-00004 15075784
9. Chang LC, Shun CT, Hsu WF, . Fecal immunochemical test detects sessile serrated adenomas and polyps with a low level of sensitivity. Clin Gastroenterol Hepatol. 2017;15(6):872–9.e1. PMID: 27498176. 10.1016/j.cgh.2016.07.029 27498176
10. Chen CH, Wen CP, Tsai MK. Fecal immunochemical test for colorectal cancer from a prospective cohort with 513,283 individuals: providing detailed number needed to scope (NNS) before colonoscopy. Medicine (Baltimore). 2016;95(36):e4414. PMID: 27603337. 10.1097/MD.0000000000004414 27603337
11. Chen LS, Yen AM, Chiu SY, . Baseline faecal occult blood concentration as a predictor of incident colorectal neoplasia: longitudinal follow-up of a Taiwanese population-based colorectal cancer screening cohort. Lancet Oncol. 2011;12(6):551–8. PMID: 21592859. 10.1016/S1470-2045(11)70101-2 21592859
12. Chen SL, Hsu CY, Yen AM, . Demand for colonoscopy in colorectal cancer screening using a quantitative fecal immunochemical test and age/sex-specific thresholds for test positivity. Cancer Epidemiol Biomarkers Prev. 2018;27(6):704–9. PMID: 29593012. 10.1158/1055-9965.EPI-17-0387 29593012
  a. Chiang TH, Chuang SL, Chen SL, . Difference in performance of fecal immunochemical tests with the same hemoglobin cutoff concentration in a nationwide colorectal cancer screening program. Gastroenterology. 2014;147(6):1317–26. PMID: 25200099.25200099
13. Chen YY, Chen TH, Su MY, . Accuracy of immunochemical fecal occult blood test for detecting colorectal neoplasms in individuals undergoing health check-ups. Adv Dig Med. 2014;1(3):74–9.
14. Cheng TI, Wong JM, Hong CF, . Colorectal cancer screening in asymptomatic adults: comparison of colonoscopy, sigmoidoscopy and fecal occult blood tests. J Formos Med Assoc. 2002;101(10):685–90. PMID: 12517041.12517041
15. Chiu HM, Ching JY, Wu KC, . A risk-scoring system combined with a fecal immunochemical test is effective in screening high-risk subjects for early colonoscopy to detect advanced colorectal neoplasms. Gastroenterology. 2016;150(3):617–25.e3. PMID: 26627608. 10.1053/j.gastro.2015.11.042 26627608
16. Chiu HM, Lee YC, Tu CH, . Association between early stage colon neoplasms and false-negative results from the fecal immunochemical test. Clin Gastroenterol Hepatol. 2013;11(7):832–8. PMID: 23376002.23376002
17. Cooper GS, Markowitz SD, Chen Z, . Performance of multitarget stool DNA testing in African American patients. Cancer. 2018;124(19):3876–80. PMID: 30193399. 10.1002/cncr.31660 30193399
18. de Wijkerslooth TR, Stoop EM, Bossuyt PM, . Immunochemical fecal occult blood testing is equally sensitive for proximal and distal advanced neoplasia. Am J Gastroenterol. 2012;107(10):1570–8. PMID: 22850431.22850431
  a. Grobbee EJ, Wieten E, Hansen BE, . Fecal immunochemical test-based colorectal cancer screening: the gender dilemma. United European Gastroenterol. 2017;5(3):448–54. PMID: 28507758. 10.1177/2050640616659998 28507758
19. Deng L, Chang D, Foshaug RR, . Development and validation of a high-throughput mass spectrometry based urine metabolomic test for the detection of colonic adenomatous polyps. Metabolites. 2017;7(3):22. PMID: 28640228. 10.3390/metabo7030032 28640228
  a. Wang H, Tso V, Wong C, . Development and validation of a highly sensitive urine-based test to identify patients with colonic adenomatous polyps. Clin Transl Gastroenterol. 2014;5:e54. PMID: 24646506. 10.1038/ctg.2014.2 24646506
20. Fletcher JG, Silva AC, Fidler JL, . Noncathartic CT colonography: image quality assessment and performance and in a screening cohort. AJR Am J Roentgenol. 2013;201(4):787–94. PMID: 24059367.24059367
21. Garcia M, Domenech X, Vidal C, . Interval cancers in a population-based screening program for colorectal cancer in catalonia, Spain. Gastroenterol Res Pract. 2015;2015:672410. PMID: 25802515. 10.1155/2015/672410 25802515
22. Gies A, Cuk K, Schrotz-King P, . Direct comparison of diagnostic performance of 9 quantitative fecal immunochemical tests for colorectal cancer screening. Gastroenterology. 2018;154(1):93–104. 10.1053/j.gastro.2017.09.018 28958859
  a. Gies A, Cuk K, Schrotz-King P, . Combination of different fecal immunochemical tests in colorectal cancer screening: any gain in diagnostic performance? Cancers (Basel). 2019;11(1):20. PMID: 30669538. 10.3390/cancers11010120 30669538
  b. Gies A, Cuk K, Schrotz-King P, . Fecal immunochemical test for hemoglobin in combination with fecal transferrin in colorectal cancer screening. United European Gastroenterol. 2018;6(8):1223–31. PMID: 30288285. 10.1177/2050640618784053 30288285
23. Graser A, Stieber P, Nagel D, . Comparison of CT colonography, colonoscopy, sigmoidoscopy and faecal occult blood tests for the detection of advanced adenoma in an average risk population. Gut. 2009;58(2):241–8. PMID: 18852257.18852257
24. Haug U, Grobbee EJ, Lansdorp-Vogelaar I, . Immunochemical faecal occult blood testing to screen for colorectal cancer: can the screening interval be extended? Gut. 2017;66(7):1262–7. PMID: 27006184. 10.1136/gutjnl-2015-310102 27006184
25. Hernandez V, Cubiella J, Gonzalez-Mao MC, . Fecal immunochemical test accuracy in average-risk colorectal cancer screening. World J Gastroenterol. 2014;20(4):1038–47. PMID: 24574776.24574776
26. Imperiale TF, Ransohoff DF, Itzkowitz SH, . Multitarget stool DNA testing for colorectal-cancer screening. N Engl J Med. 2014;370(14):1287–97. PMID: 24645800. 10.1056/NEJMoa1311194 24645800
27. Itoh M, Takahashi K, Nishida H, . Estimation of the optimal cut off point in a new immunological faecal occult blood test in a corporate colorectal cancer screening programme. J Med Screen. 1996;3(2):66–71. PMID: 8849762. 10.1177/096914139600300204 8849762
28. Johnson CD, Chen MH, Toledano AY, . Accuracy of CT colonography for detection of large adenomas and cancers. N Engl J Med. 2008;359(12):1207–17. PMID: 18799557. 10.1056/NEJMoa0800996 18799557
  a. Johnson CD, Herman BA, Chen MH, . The National CT Colonography Trial: assessment of accuracy in participants 65 years of age and older. Radiology. 2012;263(2):401–8. PMID: 22361006. 10.1148/radiol.12102177 22361006
29. Johnson CD, Fletcher JG, MacCarty RL, . Effect of slice thickness and primary 2D versus 3D virtual dissection on colorectal lesion detection at CT colonography in 452 asymptomatic adults. AJR Am J Roentgenol. 2007;189(3):672–80. PMID: 17715116.17715116
30. Juul JS, Andersen B, Laurberg S, . Differences in diagnostic activity in general practice and findings for individuals invited to the danish screening programme for colorectal cancer: a population-based cohort study. Scand J Prim Health Care. 2018;36(3):281–90. PMID: 29929415. 10.1080/02813432.2018.1487378 29929415
31. Kim NH, Park JH, Park DI, . The fecal immunochemical test has high accuracy for detecting advanced colorectal neoplasia before age 50. Dig Liver Dis. 2017;49(5):557–61. PMID: 28065631. 10.1016/j.dld.2016.12.020 28065631
  a. Jung YS, Park CH, Kim NH, . Identifying the optimal strategy for screening of advanced colorectal neoplasia. J Gastroenterol Hepatol. 2017;32(5):1003–10. PMID: 28449340. 10.1111/jgh.13634 28449340
32. Kim YS, Kim N, Kim SH, . The efficacy of intravenous contrast-enhanced 16-raw multidetector CT colonography for detecting patients with colorectal polyps in an asymptomatic population in Korea. J Clin Gastroenterol. 2008;42(7):791–8. PMID: 18580500. 10.1097/MCG.0b013e31811edcb7 18580500
33. Launoy GD, Bertrand HJ, Berchi C, . Evaluation of an immunochemical fecal occult blood test with automated reading in screening for colorectal cancer in a general average-risk population. Int J Cancer. 2005;115(3):493–6. PMID: 15700317. 10.1002/ijc.20921 15700317
34. Lee YH, Hur M, Kim H, . Optimal cut-off concentration for a faecal immunochemical test for haemoglobin by Hemo Techt NS-Plus C15 system for the colorectal cancer screening. Clin Chem Lab Med. 2015;53(3):e69–71. PMID: 25153599. 10.1515/cclm-2014-0442 25153599
35. Lefere P, Silva C, Gryspeerdt S, . Teleradiology based CT colonography to screen a population group of a remote island; at average risk for colorectal cancer. Eur J Radiol. 2013;82(6):e262–e7. PMID: 23473734. 10.1016/j.ejrad.2013.02.010 23473734
36. Levi Z, Birkenfeld S, Vilkin A, . A higher detection rate for colorectal cancer and advanced adenomatous polyp for screening with immunochemical fecal occult blood test than guaiac fecal occult blood test, despite lower compliance rate. A prospective, controlled, feasibility study. Int J Cancer. 2011;128(10):2415–24. PMID: 20658527. 10.1002/ijc.25574 20658527
37. Levy BT, Bay C, Xu Y, . Test characteristics of faecal immunochemical tests (FIT) compared with optical colonoscopy. J Med Screen. 2014;21(3):133–43. PMID: 24958730. 10.1177/0969141314541109 24958730
38. Liles EG, Perrin N, Rosales AG, . Performance of a quantitative fecal immunochemical test for detecting advanced colorectal neoplasia: a prospective cohort study. BMC Cancer. 2018;18(1):509. 10.1186/s12885-018-4402-x 29720130
39. Macari M, Bini EJ, Jacobs SL, . Colorectal polyps and cancers in asymptomatic average-risk patients: evaluation with CT colonography. Radiology. 2004;230(3):629–36. PMID: 14739311. 10.1148/radiol.2303021624 14739311
40. Mlakar DN, Bric TK, Skrjanec AL, . Interval cancers after negative immunochemical test compared to screen and non-responders’ detected cancers in Slovenian colorectal cancer screening programme. Radiol Oncol. 2018;52(4):413–21. PMID: 30511936. 10.2478/raon-2018-0025 30511936
41. Morikawa T, Kato J, Yamaji Y, . A comparison of the immunochemical fecal occult blood test and total colonoscopy in the asymptomatic population. Gastroenterology. 2005;129(2):422–8. PMID: 16083699. 10.1016/j.gastro.2005.05.056 16083699
  a. Morikawa T, Kato J, Yamaji Y, . Sensitivity of immunochemical fecal occult blood test to small colorectal adenomas. Am J Gastroenterol. 2007;102(10):2259–64. PMID: 17617203. 10.1111/j.1572-0241.2007.01404.x 17617203
42. Nakama H, Kamijo N, Abdul Fattah AS, . Validity of immunological faecal occult blood screening for colorectal cancer: a follow up study. J Med Screen. 1996;3(2):63–5. PMID: 8849761. 10.1177/096914139600300203 8849761
43. Nakama H, Yamamoto M, Kamijo N, . Colonoscopic evaluation of immunochemical fecal occult blood test for detection of colorectal neoplasia. Hepatogastroenterology. 1999;46(25):228–31. PMID: 10228797.10228797
44. Ng SC, Ching JY, Chan V, . Diagnostic accuracy of faecal immunochemical test for screening individuals with a family history of colorectal cancer. Aliment Pharmacol Ther. 2013;38(7):835–41. PMID: 23957462. 10.1111/apt.12446 23957462
45. Park DI, Ryu S, Kim YH, . Comparison of guaiac-based and quantitative immunochemical fecal occult blood testing in a population at average risk undergoing colorectal cancer screening. Am J Gastroenterol. 2010;105(9):2017–25. PMID: 20502450. 10.1038/ajg.2010.179 20502450
46. Pickhardt PJ, Choi JR, Hwang I, . Computed tomographic virtual colonoscopy to screen for colorectal neoplasia in asymptomatic adults. N Engl J Med. 2003;349(23):2191–200. PMID: 14657426. 10.1056/NEJMoa031618 14657426
47. Potter NT, Hurban P, White MN, . Validation of a real-time PCR-based qualitative assay for the detection of methylated SEPT9 DNA in human plasma. Clin Chem. 2014:1183–91. PMID: 24938752. 10.1373/clinchem.2013.221044 24938752
  a. Church TR, Wandell M, Lofton-Day C, . Prospective evaluation of methylated SEPT9 in plasma for detection of asymptomatic colorectal cancer. Gut. 2014;63(2):317–25. PMID: 23408352. 10.1373/clinchem.2013.221044 23408352
48. Redwood DG, Asay ED, Blake ID, . Stool DNA testing for screening detection of colorectal neoplasia in Alaska Native people. Mayo Clin Proc. 2016;91(1):61–70. PMID: 26520415. 10.1016/j.mayocp.2015.10.008 26520415
49. Rex DK, Adler SN, Aisenberg J, . Accuracy of capsule colonoscopy in detecting colorectal polyps in a screening population. Gastroenterology. 2015;148(5):948–57.e2. PMID: 25620668. 10.1053/j.gastro.2015.01.025 25620668
50. Ribbing Wilen H, Blom J, Hoijer J, . Fecal immunochemical test in cancer screening - colonoscopy outcome in FIT positives and negatives. Scand J Gastroenterol. 2019;54(3):303–10. PMID: 30907196. 10.1080/00365521.2019.1585569 30907196
51. Selby K, Jensen CD, Lee JK, . Influence of varying quantitative fecal immunochemical test positivity thresholds on colorectal cancer detection: a community-based cohort study. Ann Intern Med. 2018;169(7):439–47. PMID: 30242328. 10.7326/M18-0244 30242328
52. Shapiro JA, Bobo JK, Church TR, . A comparison of fecal immunochemical and high-sensitivity guaiac tests for colorectal cancer screening. Am J Gastroenterol. 2017;112(11):1728–35. PMID: 29016558. 10.1038/ajg.2017.285 29016558
53. Sohn DK, Jeong SY, Choi HS, . Single immunochemical fecal occult blood test for detection of colorectal neoplasia. Cancer Res Treat. 2005;37(1):20–3. PMID: 19956505. 10.4143/crt.2005.37.1.20 19956505
54. Stegeman I, van Doorn SC, Mundt MW, . Participation, yield, and interval carcinomas in three rounds of biennial FIT-based colorectal cancer screening. Cancer Epidemiol. 2015;39(3):388–93. PMID: 25910865. 10.1016/j.canep.2015.03.012 25910865
55. Toes-Zoutendijk E, Kooyker AI, Dekker E, . Incidence of interval colorectal cancer after negative results from first-round fecal immunochemical screening tests, by cutoff value and participant sex and age. Clin Gastroenterol Hepatol. 2019;20:20. PMID: 31442598. 10.1016/j.cgh.2019.08.021 31442598
56. van der Vlugt M, Grobbee EJ, Bossuyt PM, . Interval colorectal cancer incidence among subjects undergoing multiple rounds of fecal immunochemical testing. Gastroenterology. 2017;153(2):439–47.e2. PMID: 28483499. 10.1053/j.gastro.2017.05.004 28483499
57. Voska M, Zavoral M, Grega T, . Accuracy of colon capsule endoscopy for colorectal neoplasia detection in individuals referred for a screening colonoscopy. Gastroenterol Res Pract. 2019;2019:5975438. 10.1155/2019/5975438 31565052
58. Wong MC, Ching JY, Chan VC, . Diagnostic accuracy of a qualitative fecal immunochemical test varies with location of neoplasia but not number of specimens. Clin Gastroenterol Hepatol. 2015;13(8):1472–9. PMID: 25724708. 10.1016/j.cgh.2015.02.021 25724708
59. Zalis ME, Blake MA, Cai W, . Diagnostic accuracy of laxative-free computed tomographic colonography for detection of adenomatous polyps in asymptomatic adults: a prospective evaluation. Ann Intern Med. 2012;156(10):692–702. PMID: 22586008. 10.7326/0003-4819-156-10-201205150-00005 22586008

### Key Question 3

1. Adeyemo A, Bannazadeh M, Riggs T, . Does sedation type affect colonoscopy perforation rates? Dis Colon Rectum. 2014;57(1):110–4. PMID: 24316954. 10.1097/DCR.0000000000000002 24316954
2. An S, Lee KH, Kim YH, . Screening CT colonography in an asymptomatic average-risk Asian population: a 2-year experience in a single institution. AJR Am J Roentgenol. 2008;191(3):W100–6. PMID: 18716076. 10.2214/AJR.07.3367 18716076
3. Arora G, Mannalithara A, Singh G, . Risk of perforation from a colonoscopy in adults: a large population-based study. Gastrointest Endosc. 2009;69(3 Pt 2):654–64. PMID: 19251006. 10.1016/j.gie.2008.09.008 19251006
4. Atkin WS, Hart A, Edwards R, . Uptake, yield of neoplasia, and adverse effects of flexible sigmoidoscopy screening. Gut. 1998;42(4):560–5. PMID: 9616321. 10.1136/gut.42.4.560 9616321
5. Atkin WS, Wooldrage K, Parkin DM, . Long term effects of once-only flexible sigmoidoscopy screening after 17 years of follow-up: the UK Flexible Sigmoidoscopy Screening randomised controlled trial. Lancet. 2017;389(10076):1624–33. PMID: 28236467. 10.1016/S0140-6736(17)30396-3 28236467
  a. Atkin WS. Single flexible sigmoidoscopy screening to prevent colorectal cancer: baseline findings of a UK multicentre randomised trial. Lancet. 2002;359(9314):1291–300. PMID: 11965274. 10.1016/S0140-6736(02)08268-5 11965274
  b. Atkin WS, Edwards R, Kralj-Hans I, . Once-only flexible sigmoidoscopy screening in prevention of colorectal cancer: a multicentre randomised controlled trial. Lancet. 2010;375(9726):1624–33. 10.1016/S0140-6736(10)60551-X 20430429
  c. Miles A, Wardle J, McCaffery K, . The effects of colorectal cancer screening on health attitudes and practices. Cancer Epidemiol Biomarkers Prev. 2003;12(7):651–5. PMID: 12869406.12869406
6. Bair D, Pham J, Seaton MB, . The quality of screening colonoscopies in an office-based endoscopy clinic. Can J Gastroenterol. 2009;23(1):41–7. PMID: 19172208. 10.1155/2009/831029 19172208
7. Basson MD, Persinger D, Newman WP. Association of colonoscopy with risk of appendicitis. JAMA Surg. 2018;153(1):90–1. PMID: 28979984. 10.1001/jamasurg.2017.3790 28979984
8. Berhane C, Denning D. Incidental finding of colorectal cancer in screening colonoscopy and its cost effectiveness. Am Surg. 2009;75(8):699–703. PMID: 19725293. 10.1155/2009/831029 19725293
9. Bielawska B, Day AG, Lieberman DA, . Risk factors for early colonoscopic perforation include non-gastroenterologist endoscopists: a multivariable analysis. Clin Gastroenterol Hepatol. 2014;12(1):85–92. PMID: 23891916.23891916
10. Bielawska B, Hookey LC, Sutradhar R, . Anesthesia assistance in outpatient colonoscopy and risk of aspiration pneumonia, bowel perforation, and splenic injury. Gastroenterology. 2018;154(1):77–85.e3. 10.1053/j.gastro.2017.08.043 28865733
11. Binefa G, Garcia M, Mila N, . Colorectal cancer screening programme in Spain: results of key performance indicators after five rounds (2000–2012). Sci Rep. 2016;6:19532. PMID: 26787510. 10.1038/srep19532 26787510
12. Blotiere PO, Weill A, Ricordeau P, . Perforations and haemorrhages after colonoscopy in 2010: a study based on comprehensive French health insurance data (SNIIRAM). Clin Res Hepatol Gastroenterol. 2014;38(1):112–7. PMID: 24268997.24268997
13. Bokemeyer B, Bock H, Huppe D, . Screening colonoscopy for colorectal cancer prevention: results from a German online registry on 269000 cases. Eur J Gastroenterol Hepatol. 2009;21(6):650–5. PMID: 19445041.19445041
14. Bretthauer M, Kaminski MF, Loberg M, . Population-based colonoscopy screening for colorectal cancer: a randomized clinical trial. JAMA Intern Med. 2016;176(7):894–902. PMID: 27214731. doi: 10.1001/jamainternmed.2016.0960 27214731
15. Brevinge H, Lindholm E, Buntzen S, . Screening for colorectal neoplasia with faecal occult blood testing compared with flexible sigmoidoscopy directly in a 55–56 years’ old population. Int J Colorectal Dis. 1997;12(5):291–5. PMID: 9401844.9401844
16. Cash BD, Riddle MS, Bhattacharya I, . CT colonography of a Medicare-aged population: outcomes observed in an analysis of more than 1400 patients. AJR Am J Roentgenol. 2012;199(1):W27–34. PMID: 22733929. doi: 10.2214/AJR.11.7729 22733929
17. Castro G, Azrak MF, Seeff LC, . Outpatient colonoscopy complications in the CDC’s Colorectal Cancer Screening Demonstration Program: a prospective analysis. Cancer. 2013;119(Suppl 15):2849–54. PMID: 23868479.23868479
18. Chin M, Mendelson R, Edwards J, . Computed tomographic colonography: prevalence, nature, and clinical significance of extracolonic findings in a community screening program. Am J Gastroenterol. 2005;100(12):2771–6. PMID: 16393234.16393234
19. Chukmaitov A, Bradley CJ, Dahman B, . Association of polypectomy techniques, endoscopist volume, and facility type with colonoscopy complications. Gastrointest Endosc. 2013;77(3):436–46. PMID: 2329077323290773
20. Chukmaitov A, Dahman B, Bradley CJ. Outpatient facility volume, facility type, and the risk of serious colonoscopy-related adverse events in patients with comorbid conditions: a population-based study. Int J Colorectal Dis. 2019;34(7):1203–10. 10.1007/s00384-019-03304-3 31093737
21. Chukmaitov A, Siangphoe U, Dahman B, . Patient comorbidity and serious adverse events after outpatient colonoscopy: population-based study from three states, 2006 to 2009. Dis Colon Rectum. 2016;59(7):677–87. PMID: 27270521. 10.1097/DCR.0000000000000603 27270521
22. Cooper GS, Kou TD, Rex DK. Complications following colonoscopy with anesthesia assistance: a population-based analysis. JAMA Intern Med. 2013;173(7):551–6. PMID: 23478904.23478904
23. Cotterill M, Gasparelli R, Kirby E. Colorectal cancer detection in a rural community. Development of a colonoscopy screening program. Can Fam Physician. 2005;51:1224–8. PMID: 16190175.16190175
24. Crispin A, Birkner B, Munte A, . Process quality and incidence of acute complications in a series of more than 230,000 outpatient colonoscopies. Endoscopy. 2009;41(12):1018–25. PMID: 19856246.19856246
25. Dancourt V, Lejeune C, Lepage C, . Immunochemical faecal occult blood tests are superior to guaiac-based tests for the detection of colorectal neoplasms. Eur J Cancer. 2008;44(15):2254–8. PMID: 18760592.18760592
26. Derbyshire E, Hungin P, Nickerson C, . Colonoscopic perforations in the English National Health Service Bowel Cancer Screening Programme. Endoscopy. 2018;50(9):861–70. 10.1055/a-0584-7138 29590669
  a. Derbyshire E, Hungin P, Nickerson C, . Post-polypectomy bleeding in the English National Health Service Bowel Cancer Screening Programme. Endoscopy. 2017;49(9):899–908. PMID: 28753697. 10.1055/s-0043-113442 28753697
27. Dominitz JA, Baldwin LM, Green P, . Regional variation in anesthesia assistance during outpatient colonoscopy is not associated with differences in polyp detection or complication rates. Gastroenterology. 2013;144(2):298–306. PMID: 23103615.23103615
28. Durbin JM, Stroup SP, Altamar HO, . Genitourinary abnormalities in an asymptomatic screening population: findings on virtual colonoscopy. Clin Nephrol. 2012;77(3):204–10. PMID: 22377251.22377251
29. Edwards JT, Mendelson RM, Fritschi L, . Colorectal neoplasia screening with CT colonography in average-risk asymptomatic subjects: community-based study. Radiology. 2004;230(2):459–64. PMID: 14688402.14688402
30. Faivre J, Dancourt V, Lejeune C, . Reduction in colorectal cancer mortality by fecal occult blood screening in a French controlled study. Gastroenterology. 2004;126(7):1674–80. PMID: 15188160.15188160
31. Ferlitsch M, Reinhart K, Pramhas S, . Sex-specific prevalence of adenomas, advanced adenomas, and colorectal cancer in individuals undergoing screening colonoscopy. JAMA. 2011;306(12):1352–8. PMID: 21954479.21954479
32. Fletcher JG, Silva AC, Fidler JL, . Noncathartic CT colonography: image quality assessment and performance and in a screening cohort. AJR Am J Roentgenol. 2013;201(4):787–94. PMID: 24059367.24059367
33. Flicker MS, Tsoukas AT, Hazra A, . Economic impact of extracolonic findings at computed tomographic colonography. J Comput Assist Tomogr. 2008;32(4):497–503. PMID: 18664832.18664832
34. Forsberg A, Hammar U, Ekbom A, . A register-based study: adverse events in colonoscopies performed in Sweden 2001–2013. Scand J Gastroenterol. 2017;52(9):1042–7. 10.1080/00365521.2017.1334812 28562115
35. Garcia-Albeniz X, Hsu J, Bretthauer M, . Effectiveness of screening colonoscopy to prevent colorectal cancer among medicare beneficiaries aged 70 to 79 years: a prospective observational study. Ann Intern Med. 2017;166(1):18–26. PMID: 27669524. 10.7326/M16-0758 27669524
36. Ginnerup PB, Rosenkilde M, Christiansen TE, . Extracolonic findings at computed tomography colonography are a challenge. Gut. 2003;52(12):1744–7. PMID: 14633954.14633954
37. Gluecker TM, Johnson CD, Wilson LA, . Extracolonic findings at CT colonography: evaluation of prevalence and cost in a screening population. Gastroenterology. 2003;124(4):911–6. PMID: 12671887.12671887
38. Graser A, Stieber P, Nagel D, . Comparison of CT colonography, colonoscopy, sigmoidoscopy and faecal occult blood tests for the detection of advanced adenoma in an average risk population. Gut. 2009;58(2):241–8. PMID: 18852257.18852257
39. Grossberg LB, Vodonos A, Papamichael K, . Predictors of post-colonoscopy emergency department use. Gastrointest Endosc. 2018;87(2):517–25.e6. PMID: 28859952. 10.1016/j.gie.2017.08.019 28859952
40. Grossberg LB, Papamichael K, Leffler DA, . Patients over age 75 are at increased risk of emergency department visit and hospitalization following colonoscopy. Dig Dis Sci. 2019;29:29. PMID: 31784850. 10.1007/s10620-019-05962-3 31784850
41. Multicentre Austrailian Colorectal-neoplasia Screening (MACS) Group. A comparison of colorectal neoplasia screening tests: a multicentre community-based study of the impact of consumer choice. Med J Aust. 2006;184(11):546–50. PMID: 16768659.16768659
42. Hamdani U, Naeem R, Haider F, . Risk factors for colonoscopic perforation: a population-based study of 80118 cases. World J Gastroenterol. 2013;19(23):3596–601. PMID: 23801860.23801860
43. Hara AK, Johnson CD, MacCarty RL, . Incidental extracolonic findings at CT colonography. Radiology. 2000;215(2):353–7. PMID: 10796907.10796907
44. Ho JM, Gruneir A, Fischer HD, . Serious events in older Ontario residents receiving bowel preparations for outpatient colonoscopy with various comorbidity profiles: a descriptive, population-based study. Can J Gastroenterol. 2012;26(7):436–40. PMID: 22803018.22803018
45. Hoff G, de Lange T, Bretthauer M, . Patient-reported adverse events after colonoscopy in Norway. Endoscopy. 2017;49(8):745–53. 10.1055/s-0043-105265 28445903
46. Hoff G, Thiis-Evensen E, Grotmol T, . Do undesirable effects of screening affect all-cause mortality in flexible sigmoidoscopy programmes? Experience from the Telemark Polyp Study 1983–1996. Eur J Cancer Prev. 2001;10(2):131–7. PMID: 11330453.11330453
  a. Hoff G, Sauar J, Vatn MH, . Polypectomy of adenomas in the prevention of colorectal cancer: 10 years’ follow-up of the Telemark Polyp Study I. A prospective, controlled population study. Scand J Gastroenterol. 1996;31(10):1006–10. PMID: 8898422.8898422
  b. Thiis-Evensen E, Hoff GS, Sauar J, . Population-based surveillance by colonoscopy: effect on the incidence of colorectal cancer. Telemark Polyp Study I. Scand J Gastroenterol. 1999;34(4):414–20. PMID: 10365903.10365903
47. Holme O, Loberg M, Kalager M, . Long-term effectiveness of sigmoidoscopy screening on colorectal cancer incidence and mortality in women and men: a randomized trial. JAMA. 2018;168(11):775–782. PMID: 29710125. 10.7326/M17-1441 29710125
  a. Holme O, Loberg M, Kalager M, . Effect of flexible sigmoidoscopy screening on colorectal cancer incidence and mortality: a randomized clinical trial. Ann Intern Med. 2014;312(6):606–15. PMID: 2971012529710125
  b. Holme O, Bretthauer M, Eide TJ, . Long-term risk of colorectal cancer in individuals with serrated polyps. Gut. 2015;64(6):929–36. PMID: 25399542. 10.1136/gutjnl-2014-307793 25399542
  c. Jodal HC, Loberg M, Holme O, . Mortality from postscreening (interval) colorectal cancers is comparable to that from cancer in unscreened patients-a randomized sigmoidoscopy trial. Gastroenterology. 2018;155(6):1787–94.e3. PMID: 30165051. 10.1053/j.gastro.2018.08.035 30165051
  d. Hoff G, Grotmol T, Skovlund E, . Risk of colorectal cancer seven years after flexible sigmoidoscopy screening: randomised controlled trial. BMJ. 2009;338:b1846. PMID: 19483252.19483252
  e. Gondal G, Grotmol T, Hofstad B, . The Norwegian Colorectal Cancer Prevention (NORCCAP) screening study: baseline findings and implementations for clinical work-up in age groups 50–64 years. Scand J Gastroenterol. 2003;38(6):635–42. PMID: 12825872.12825872
48. Hsieh TK, Hung L, Kang FC, . Anesthesia does not increase the rate of bowel perforation during colonoscopy: a retrospective study. Acta Anaesthesiol Taiwan. 2009;47(4):162–6. PMID: 20015815.20015815
49. Iafrate F, Iussich G, Correale L, . Adverse events of computed tomography colonography: an Italian National Survey. Dig Liver Dis. 2013;45(8):645–50. PMID: 23643567.23643567
50. Ibanez J, Vanaclocha-Espi M, Perez-Sanz E, . Severe complications in colorectal cancer screening colonoscopies in the Valencian Community. Gastroenterol Hepatol. 2018;41(9):553–61. 10.1016/j.gastrohep.2018.06.007 30055861
51. Jain A, Falzarano J, Jain A, . Outcome of 5,000 flexible sigmoidoscopies done by nurse endoscopists for colorectal screening in asymptomatic patients. Hawaii Med J. 2002;61(6):118–20. PMID: 12148407.12148407
52. Johnson CD, Chen MH, Toledano AY, . Accuracy of CT colonography for detection of large adenomas and cancers. N Engl J Med. 2008;359(12):1207–17. PMID: 18799557.18799557
  a. Johnson CD, Herman BA, Chen MH, . The National CT Colonography Trial: assessment of accuracy in participants 65 years of age and older. Radiology. 2012;263(2):401–8. PMID: 22361006.22361006
53. Johnson DA, Lieberman D, Inadomi JM, . Increased post-procedural non-gastrointestinal adverse events after outpatient colonoscopy in high-risk patients. Clin Gastroenterol Hepatol. 2017;15(6):883–91.e9. 10.1016/j.cgh.2016.12.015 28017846
54. Kamath AS, Iqbal CW, Sarr MG, . Colonoscopic splenic injuries: incidence and management. J Gastrointest Surg. 2009;13(12):2136–40. PMID: 19830501.19830501
55. Kang HY, Kang HW, Kim SG, . Incidence and management of colonoscopic perforations in Korea. Digestion. 2008;78(4):218–23. PMID: 19142003.19142003
56. Kim DH, Pickhardt PJ, Hanson ME, . CT colonography: performance and program outcome measures in an older screening population. Radiology. 2010;254(2):493–500. PMID: 20093521.20093521
57. Kim DH, Pickhardt PJ, Taylor AJ, . CT colonography versus colonoscopy for the detection of advanced neoplasia. N Engl J Med. 2007;357(14):1403–12. PMID: 17914041.17914041
  a. Pickhardt PJ, Kim DH, Robbins JB. Flat (nonpolypoid) colorectal lesions identified at CT colonography in a U.S. screening population. Acad Radiol. 2010;17(6):784–90. PMID: 20227304.20227304
  b. Regula J, Polkowski M. CT colonography versus colonoscopy for the detection of advanced neoplasia. N Engl J Med. 2008;358(1):88–9. PMID: 18175382.18175382
58. Kim JS, Kim BW, Kim JI, . Endoscopic clip closure versus surgery for the treatment of iatrogenic colon perforations developed during diagnostic colonoscopy: a review of 115,285 patients. Surg Endosc. 2013;27(2):501–4. PMID: 22773239.22773239
59. Kim YS, Kim N, Kim SH, . The efficacy of intravenous contrast-enhanced 16-raw multidetector CT colonography for detecting patients with colorectal polyps in an asymptomatic population in Korea. J Clin Gastroenterol. 2008;42(7):791–8. PMID: 18580500.18580500
60. Kim YS, Kim N, Kim SY, . Extracolonic findings in an asymptomatic screening population undergoing intravenous contrast-enhanced computed tomography colonography. J Gastroenterol Hepatol. 2008;23(7 Pt 2):e49–57. PMID: 17645481.17645481
61. Ko CW, Riffle S, Michaels L, . Serious complications within 30 days of screening and surveillance colonoscopy are uncommon. Clin Gastroenterol Hepatol. 2010;8(2):166–73. PMID: 19850154.19850154
62. Ko CW, Riffle S, Shapiro JA, . Incidence of minor complications and time lost from normal activities after screening or surveillance colonoscopy. Gastrointest Endosc. 2007;65(4):648–56. PMID: 17173914.17173914
63. Kobiela J, Spychalski P, Wieszczy P, . Mortality and rate of hospitalization in a colonoscopy screening program from a randomized health services study. Clin Gastroenterol Hepatol. 2019;13:13. PMID: 31525515. 10.1016/j.cgh.2019.09.010 31525515
64. Korman LY, Overholt BF, Box T, . Perforation during colonoscopy in endoscopic ambulatory surgical centers. Gastrointest Endosc. 2003;58(4):554–7. PMID: 14520289.14520289
65. Kubisch CH, Crispin A, Mansmann U, . Screening for colorectal cancer is associated with lower disease stage: a population-based study. Clin Gastroenterol Hepatol. 2016;14(11):1612–8.e3. 10.1016/j.cgh.2016.04.008 27085763
66. Laanani M, Coste J, Blotiere PO, . Patient, procedure, and endoscopist risk factors for perforation, bleeding, and splenic injury after colonoscopies. Clin Gastroenterol Hepatol. 2019;17(4):719–727.e13. PMID: 30099110. 10.1016/j.cgh.2018.08.005 30099110
67. Larson ME, Pickhardt PJ. CT colonography screening in extracolonic cancer survivors: impact on rates of colorectal and extracolonic findings by cancer type. Abdom Radiol (NY). 2019;44(1):31–40. PMID: 30066170. 10.1007/s00261-018-1708-8 30066170
68. Layton JB, Klemmer PJ, Christiansen CF, . Sodium phosphate does not increase risk for acute kidney injury after routine colonoscopy, compared with polyethylene glycol. Clin Gastroenterol Hepatol. 2014;12(9):1514–21. PMID: 24486407.24486407
69. Lefere P, Silva C, Gryspeerdt S, . Teleradiology based CT colonography to screen a population group of a remote island; at average risk for colorectal cancer. Eur J Radiol. 2013;82(6):e262–e7. PMID: 23473734.23473734
70. Levin TR, Conell C, Shapiro JA, . Complications of screening flexible sigmoidoscopy. Gastroenterology. 2002;123(6):1786–92. PMID: 12454834.12454834
71. Levin TR, Zhao W, Conell C, . Complications of colonoscopy in an integrated health care delivery system. Ann Intern Med. 2006;145(12):880–6. PMID: 17179057.17179057
72. Lindholm E, Brevinge H, Haglind E. Survival benefit in a randomized clinical trial of faecal occult blood screening for colorectal cancer. Br J Surg. 2008;95(8):1029–36. PMID: 18563785.18563785
  a. Kewenter J, Brevinge H. Endoscopic and surgical complications of work-up in screening for colorectal cancer. Dis Colon Rectum. 1996;39(6):676–80. PMID: 8646956.8646956
  b. 779: Kewenter J, Brevinge H, Engaras B, . Results of screening, rescreening, and follow-up in a prospective randomized study for detection of colorectal cancer by fecal occult blood testing. Results for 68,308 subjects. Scand J Gastroenterol. 1994;29(5):468–73. PMID: 8036464.8036464
73. Loffeld RJ, Engel A, Dekkers PE. Incidence and causes of colonoscopic perforations: a single-center case series. Endoscopy. 2011;43(3):240–2. PMID: 21165826.21165826
74. Lorenzo-Zuniga V, Moreno dV, V, Domenech E, . Endoscopist experience as a risk factor for colonoscopic complications. Colorectal Dis. 2010;12(10 Online):e273–7. PMID: 19930145.19930145
75. Macari M, Nevsky G, Bonavita J, . CT colonography in senior versus nonsenior patients: extracolonic findings, recommendations for additional imaging, and polyp prevalence. Radiology. 2011;259(3):767–74. PMID: 21467252.21467252
76. Mansmann U, Crispin A, Henschel V, . Epidemiology and quality control of 245 000 outpatient colonoscopies. Dtsch Arztebl Int. 2008;105(24):434–40. PMID: 19626186.19626186
77. Mikkelsen EM, Thomsen MK, Tybjerg J, . Colonoscopy-related complications in a nationwide immunochemical fecal occult blood test-based colorectal cancer screening program. Clin Epidemiol. 2018;10:1649–55. PMID: 30519113. 10.2147/CLEP.S181204 30519113
78. Miller EA, Pinsky PF, Schoen RE, . Effect of flexible sigmoidoscopy screening on colorectal cancer incidence and mortality: long-term follow-up of the randomised US PLCO cancer screening trial. Lancet Gastroenterol Hepatol. 2019;4(2):101–10. PMID: 30502933. 10.1016/S2468-1253(18)30358-3 30502933
  a. Doroudi M, Schoen RE, Pinsky PF. Early detection versus primary prevention in the PLCO flexible sigmoidoscopy screening trial: which has the greatest impact on mortality? Cancer. 2017;123(24):4815–22. PMID: 28976536. 10.1002/cncr.31034 28976536
  b. Laiyemo AO, Doubeni C, Pinsky PF, . Occurrence of distal colorectal neoplasia among whites and blacks following negative flexible sigmoidoscopy: an analysis of PLCO trial. J Gen Intern Med. 2015;30(10):1447–53. PMID: 25835747. 10.1007/s11606-015-3297-3 25835747
  c. Pinsky P, Miller E, Zhu C, . Overall mortality in men and women in the randomized Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. J Med Screen [serial on the Internet]. 2019 [cited Bridge 1 - CENTRAL: Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01941335/full https://journals.sagepub.com/doi/pdf/10.1177/0969141319839097.
  d. Schoen RE, Pinsky PF, Weissfeld JL, . Colorectal-cancer incidence and mortality with screening flexible sigmoidoscopy. N Engl J Med. 2012;366(25):2345–57. PMID: 22612596. 10.1016/S2468-1253(18)30358-3 22612596
  e. Schoen RE, Razzak A, Yu KJ, . Incidence and mortality of colorectal cancer in individuals with a family history of colorectal cancer. Gastroenterology. 2015;149(6):1438–45.e1. PMID: 26255045. 10.1053/j.gastro.2015.07.055 26255045
  f. Weissfeld JL, Schoen RE, Pinsky PF, . Flexible sigmoidoscopy in the PLCO cancer screening trial: results from the baseline screening examination of a randomized trial. J Natl Cancer Inst. 2005;97(13):989–97. PMID: 15998952.15998952
79. Moreno CC, Fibus TF, Krupinski EA, . Addressing racial disparity in colorectal cancer screening with CT colonography: experience in an African-American cohort. Clin Colorectal Cancer. 2018;17(2):e363–e7. PMID: 29572136. 10.1016/j.clcc.2018.02.007 29572136
80. Nelson DB, McQuaid KR, Bond JH, . Procedural success and complications of large-scale screening colonoscopy. Gastrointest Endosc. 2002;55(3):307–14. PMID: 11868001.11868001
81. O’Connor SD, Pickhardt PJ, Kim DH, . Incidental finding of renal masses at unenhanced CT: prevalence and analysis of features for guiding management. AJR Am J Roentgenol. 2011;197(1):139–45. PMID: 21701022.21701022
82. Parente F, Boemo C, Ardizzoia A, . Outcomes and cost evaluation of the first two rounds of a colorectal cancer screening program based on immunochemical fecal occult blood test in northern Italy. Endoscopy. 2013;45(1):27–34. PMID: 23254404.23254404
83. Penz D, Ferlitsch A, Waldmann E, . Impact of adenoma detection rate on detection of advanced adenomas and endoscopic adverse events in a study of over 200,000 screening colonoscopies. Gastrointest Endosc. 2019;06:06. PMID: 31499041. 10.1016/j.gie.2019.08.038 31499041
84. Pickhardt PJ. Incidence of colonic perforation at CT colonography: review of existing data and implications for screening of asymptomatic adults. Radiology 2006;239(2):313–6. PMID: 16641348.16641348
85. Pickhardt PJ, Boyce CJ, Kim DH, . Should small sliding hiatal hernias be reported at CT colonography? AJR Am J Roentgenol. 2011;196(4):W400–4. PMID: 21427303.21427303
86. Pickhardt PJ, Choi JR, Hwang I, . Computed tomographic virtual colonoscopy to screen for colorectal neoplasia in asymptomatic adults. N Engl J Med. 2003;349(23):2191–200. PMID: 14657426.14657426
87. Pickhardt PJ, Hanson ME, Vanness DJ, . Unsuspected extracolonic findings at screening CT colonography: clinical and economic impact. Radiology. 2008;249(1):151–9. PMID: 18796673.18796673
88. Pickhardt PJ, Kim DH, Meiners RJ, . Colorectal and extracolonic cancers detected at screening CT colonography in 10,286 asymptomatic adults. Radiology. 2010;255(1):83–8. PMID: 20308446.20308446
89. Pickhardt PJ, Kim DH, Taylor AJ, . Extracolonic tumors of the gastrointestinal tract detected incidentally at screening CT colonography. Dis Colon Rectum. 2007;50(1):56–63. PMID: 17115333.17115333
90. Polter DE. Risk of colon perforation during colonoscopy at Baylor University Medical Center. Baylor Univ Med Cent Proc. 2015;28(1):3–6. PMID: 25552784.25552784
91. Pooler BD, Kim DH, Pickhardt PJ. Potentially important extracolonic findings at screening CT colonography: incidence and outcomes data from a clinical screening program. AJR Am J Roentgenol. 2016;206(2):313–8. 10.2214/AJR.15.15193 26491809
  a. Pooler BD, Kim DH, Pickhardt PJ. Indeterminate but likely unimportant extracolonic findings at screening CT colonography (C-RADS Category E3): incidence and outcomes data from a clinical screening program. AJR Am J Roentgenol. 2016;207(5):996–1001. PMID: 27505184.27505184
92. Pox CP, Altenhofen L, Brenner H, . Efficacy of a nationwide screening colonoscopy program for colorectal cancer. Gastroenterology. 2012;142(7):1460–7. PMID: 22446606.22446606
93. Quallick MR, Brown WR. Rectal perforation during colonoscopic retroflexion: a large, prospective experience in an academic center. Gastrointest Endosc. 2009;69(4):960–3. PMID: 19327487.19327487
94. Quintero E, Castells A, Bujanda L, . Colonoscopy versus fecal immunochemical testing in colorectal-cancer screening. N Engl J Med. 2012;366(8):697–706. PMID: 22356323.22356323
  a. Parra-Blanco A, Nicolas-Perez D, Gimeno-Garcia A, . The timing of bowel preparation before colonoscopy determines the quality of cleansing, and is a significant factor contributing to the detection of flat lesions: a randomized study. World J Gastroenterol. 2006;12(38):6161–6.17036388
  b. Castells A, Quintero E. Programmatic screening for colorectal cancer: the COLONPREV study. Dig Dis Sci. 2015;60(3):672–80. PMID: 25492501. 10.1007/s10620-014-3446-2 25492501
95. Rabeneck L, Paszat LF, Hilsden RJ, . Bleeding and perforation after outpatient colonoscopy and their risk factors in usual clinical practice. Gastroenterology. 2008;135(6):1899–906. PMID: 18938166.18938166
96. Rasmussen M, Kronborg O, Fenger C, . Possible advantages and drawbacks of adding flexible sigmoidoscopy to hemoccult-II in screening for colorectal cancer. A randomized study. Scand J Gastroenterol. 1999;34(1):73–8. PMID: 10048736.10048736
97. Rathgaber SW, Wick TM. Colonoscopy completion and complication rates in a community gastroenterology practice. Gastrointest Endosc. 2006;64(4):556–62. PMID: 16996349.16996349
98. Regge D, Iussich G, Segnan N, . Comparing CT colonography and flexible sigmoidoscopy: a randomised trial within a population-based screening programme. Gut. 2017;66(8):1434–40. PMID: 27196588. 10.1136/gutjnl-2015-311278 27196588
  a. Senore C, Correale L, Regge D, . Flexible sigmoidoscopy and CT colonography screening: patients’ experience with and factors for undergoing screening-insight from the Proteus Colon Trial. Radiology. 2018;286(3):873–83. PMID: 29040021. 10.1148/radiol.2017170228 29040021
99. Rex DK, Adler SN, Aisenberg J, . Accuracy of capsule colonoscopy in detecting colorectal polyps in a screening population. Gastroenterology. 2015;148(5):948–57.e2. 10.1053/j.gastro.2015.01.025 25620668
100. Rim JH, Youk T, Kang JG, . Fecal occult blood test results of the national colorectal cancer screening program in South Korea (2006–2013). Sci Rep. 2017;7(1):2804. PMID: 28584248. 10.1038/s41598-017-03134-9 28584248
101. Rutter CM, Johnson E, Miglioretti DL, . Adverse events after screening and follow-up colonoscopy. Cancer Causes Control. 2012;23(2):289–96. PMID: 22105578.22105578
102. Sagawa T, Kakizaki S, Iizuka H, . Analysis of colonoscopic perforations at a local clinic and a tertiary hospital. World J Gastroenterol. 2012;18(35):4898–904. PMID: 23002362.23002362
103. Sali L, Mascalchi M, Falchini M, . Reduced and Full-Preparation CT Colonography, Fecal Immunochemical Test, and Colonoscopy for Population Screening of Colorectal Cancer: a Randomized Trial. Journal of the national cancer institute [serial on the Internet]. 2016 [cited Search 1 - CENTRAL; 108(2): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01168529/full.
104. Saraste D, Martling A, Nilsson PJ, . Complications after colonoscopy and surgery in a population-based colorectal cancer screening programme. J Med Screen. 2016;23(3):135–40. PMID: 26940962. 10.1177/0969141315625701 26940962
105. Scholefield JH, Moss SM, Mangham CM, . Nottingham trial of faecal occult blood testing for colorectal cancer: a 20-year follow-up. Gut. 2012;61(7):1036–40. PMID: 22052062.22052062
  a. Hardcastle JD, Chamberlain JO, Robinson MH, . Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348(9040):1472–7. PMID: 8942775.8942775
106. Segnan N, Armaroli P, Bonelli L, . Once-only sigmoidoscopy in colorectal cancer screening: follow-up findings of the Italian Randomized Controlled Trial--SCORE. J Natl Cancer Inst. 2011;103(17):1310–22. PMID: 21852264.21852264
  a. Segnan N, Senore C, Andreoni B, . Baseline findings of the Italian multicenter randomized controlled trial of “once-only sigmoidoscopy”--SCORE. J Natl Cancer Inst. 2002;94(23):1763–72. PMID: 1246464812464648
107. Segnan N, Senore C, Andreoni B, . Randomized trial of different screening strategies for colorectal cancer: patient response and detection rates. J Natl Cancer Inst. 2005;97(5):347–57. PMID: 15741571.15741571
108. Segnan N, Senore C, Andreoni B, . Comparing attendance and detection rate of colonoscopy with sigmoidoscopy and FIT for colorectal cancer screening. Gastroenterology. 2007;132(7):2304–12. PMID: 17570205.17570205
  a. Senore C, Ederle A, Fantin A, . Acceptability and side-effects of colonoscopy and sigmoidoscopy in a screening setting. J Med Screen. 2011;18(3):128–34. PMID: 22045821.22045821
109. Shaukat A, Mongin SJ, Geisser MS, . Long-term mortality after screening for colorectal cancer. N Engl J Med. 2013;369(12):1106–14. PMID: 2404706024047060
  a. Mandel JS, Bond JH, Church TR, . Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med. 1993;328(19):1365–71. PMID: 8474513. 10.1056/NEJM199305133281901 8474513
  b. Mandel JS, Church TR, Bond JH, . The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. 2000;343(22):1603–7. PMID: 11096167. 10.1056/NEJM200011303432203 11096167
  c. Thomas W, White CM, Mah J, . Longitudinal compliance with annual screening for fecal occult blood. Minnesota Colon Cancer Control Study. Am J Epidemiol. 1995;142(2):176–82. PMID: 7598117. 10.1093/oxfordjournals.aje.a117616 7598117
110. Sieg A, Hachmoeller-Eisenbach U, Eisenbach T. Prospective evaluation of complications in outpatient GI endoscopy: a survey among German gastroenterologists. Gastrointest Endosc. 2001;53(6):620–7. PMID: 11323588.11323588
111. Singh H, Penfold RB, DeCoster C, . Colonoscopy and its complications across a Canadian regional health authority. Gastrointest Endosc. 2009;69(3 Pt 2):665–71. PMID: 19251007.19251007
112. Sosna J, Blachar A, Amitai M, . Colonic perforation at CT colonography: assessment of risk in a multicenter large cohort. Radiology. 2006;239(2):457–63. PMID: 16543590.16543590
113. Steele RJ, Carey FA, Stanners G, . Randomized controlled trial: flexible sigmoidoscopy as an adjunct to faecal occult blood testing in population screening. J Med Screen. 2020;27(2):59–67. PMID: 31690179. 10.1177/0969141319879955 31690179
114. Stock C, Ihle P, Sieg A, . Adverse events requiring hospitalization within 30 days after outpatient screening and nonscreening colonoscopies. Gastrointest Endosc. 2013;77(3):419–29. PMID: 23410698.23410698
115. Stoop EM, de Haan MC, de Wijkerslooth TR, . Participation and yield of colonoscopy versus non-cathartic CT colonography in population-based screening for colorectal cancer: a randomised controlled trial. Lancet Oncol. 2012;13(1):55–64. PMID: 22088831.22088831
116. Strul H, Kariv R, Leshno M, . The prevalence rate and anatomic location of colorectal adenoma and cancer detected by colonoscopy in average-risk individuals aged 40–80 years. Am J Gastroenterol. 2006;101(2):255–62. PMID: 16454827.16454827
117. Suissa A, Bentur OS, Lachter J, . Outcome and complications of colonoscopy: a prospective multicenter study in northern Israel. Diagn Ther Endosc. 2012;2012:612542. PMID: 22778539.22778539
118. Tam MS, Abbas MA. Perforation following colorectal endoscopy: what happens beyond the endoscopy suite? Perm J. 2013;17(2):17–21. PMID: 23704838.23704838
119. Taya M, McHargue C, Ricci ZJ, . Comparison of extracolonic findings and clinical outcomes in a screening and diagnostic CT colonography population. Abdom Radiol (NY). 2019;44(2):429–437. PMID: 30209542. 10.1007/s00261-018-1753-3 30209542
120. Thulin T, Hammar U, Ekbom A, . Perforations and bleeding in a population-based cohort of all registered colonoscopies in Sweden from 2001 to 2013. United European Gastroenterol. 2019;7(1):130–7. PMID: 30788125. 10.1177/2050640618809782 30788125
121. Veerappan GR, Ally MR, Choi JH, . Extracolonic findings on CT colonography increases yield of colorectal cancer screening. AJR Am J Roentgenol. 2010;195(3):677–86. PMID: 20729446.20729446
122. Verne JE, Aubrey R, Love SB, . Population based randomised study of uptake and yield of screening by flexible sigmoidoscopy compared with screening by faecal occult blood testing. BMJ. 1998;317(7152):182–5. PMID: 9665902.9665902
123. Viiala CH, Olynyk JK. Outcomes after 10 years of a community-based flexible sigmoidoscopy screening program for colorectal carcinoma. Med J Australia. 2007;187(5):274–7. PMID: 17767431.17767431
124. Wallace MB, Kemp JA, Meyer F, . Screening for colorectal cancer with flexible sigmoidoscopy by nonphysician endoscopists. Am J Med. 1999;107(3):214–8. PMID: 10492313.10492313
125. Wang L, Mannalithara A, Singh G, . Low rates of gastrointestinal and non-gastrointestinal complications for screening or surveillance colonoscopies in a population-based study. Gastroenterology. 2018;154(3):540–55.e8. PMID: 29031502. 10.1053/j.gastro.2017.10.006 29031502
126. Wang P, Xu T, Ngamruengphong S, . Rates of infection after colonoscopy and osophagogastroduodenoscopy in ambulatory surgery centres in the USA. Gut. 2018;67(9):1626–36. 10.1136/gutjnl-2017-315308 29777042
127. Warren JL, Klabunde CN, Mariotto AB, . Adverse events after outpatient colonoscopy in the Medicare population. Ann Intern Med. 2009;150(12):849–57. PMID: 19528563.19528563
128. Xirasagar S, Hurley TG, Sros L, . Quality and safety of screening colonoscopies performed by primary care physicians with standby specialist support. Med Care. 2010;48(8):703–9. PMID: 20613663.20613663
129. Zafar HM, Harhay MO, Yang J, . Adverse events following computed tomographic colonography compared to optical colonoscopy in the elderly. Prev Med Rep. 2014;1:3–8. PMID: 25530940.25530940
130. Zalis ME, Blake MA, Cai W, . Diagnostic accuracy of laxative-free computed tomographic colonography for detection of adenomatous polyps in asymptomatic adults: a prospective evaluation. Ann Intern Med. 2012;156(10):692–702. PMID: 22586008.22586008
131. Zwink N, Holleczek B, Stegmaier C, . Complication rates in colonoscopy screening for cancer. Dtsch Arztebl Int. 2017;114(18):321–7. PMID: 28587708. 10.3238/arztebl.2017.0321 28587708