# Appendix A Detailed Methods

## Literature Search Strategies for Primary Literature

Key:

- / = MeSH subject heading
- $ = truncation
- * = truncation
- ab = word in abstract
- ae = adverse effects
- adj# = adjacent within x number of words
- kf=keyword heading [word not phrase indexed]
- kw=keyword
- mo=mortality
- pt = publication type
- st=standards
- ti = word in title

Cochrane Central Register of Controlled Clinical Trials

Issue 12 of 12, December 2019

#1 (colorectal or colon or colonic or rectal or rectum or rectosigmoid or adenomat*):ti,ab,kw near/3 (cancer* or carcinoma* or adenocarcinoma* or malignan* or tumor* or tumour* or neoplas* or polyp*):ti,ab,kw
#2 screen*:ti,ab,kw or detect*:ti,ab,kw
#3 #1 and #2
#4 colonoscop*:ti,ab,kw
#5 colonograph*:ti,ab,kw
#6 sigmoidoscop*:ti,ab,kw
#7 capsule:ti,ab,kw near/2 endoscop*:ti,ab,kw
#8 “pill camera”:ti,ab,kw
#9 “pill cam”:ti,ab,kw
#10 “pillcam”:ti,ab,kw
#11 (fecal or faecal or stool):ti,ab,kw near/5 molecular*:ti,ab,kw
#12 (fecal or faecal or stool):ti,ab,kw near/5 (DNA or “deoxyribonucleic acid”):ti,ab,kw
#13 (f-dna or fdna):ti,ab,kw
#14 (s-dna or sdna):ti,ab,kw
#15 (fecal or faecal or stool):ti,ab,kw near/5 test*:ti,ab,kw
#16 (fecal or faecal or stool):ti,ab,kw near/5 (immunochemical or immunoassay):ti,ab,kw
#17 (fecal or faecal or stool):ti,ab,kw next occult:ti,ab,kw
#18 “occult blood”:ti,ab,kw
#19 guaiac:ti,ab,kw
#20 (FOBT or IFOBT):ti,ab,kw
#21 (“SEPTIN 9” or SEPT9 or mSEPT9):ti,ab,kw
#22 #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #15 or #16 or #17 or #18 or #19 or #20 or #21 with Publication Year from 2015 to 2019, in Trials

MEDLINE search strategy

KQ1:

Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <1946 to December 16, 2019>, Ovid MEDLINE(R) Epub Ahead of Print < December 16, 2019>, Ovid MEDLINE(R) Daily Update < December 4, 2019>

Search Strategy:

------------------------------------------------------------

1. Colonoscopy/
2. colonoscop$.ti,ab,kf.
3. Sigmoidoscopy/
4. sigmoidoscop$.ti,ab,kf.
5. Colonography, Computed Tomographic/
6. colonograph$.ti,ab,kf.
7. Occult Blood/
8. occult blood.ti,ab,kf.
9. ((fecal or faecal or stool) adj occult).ti,ab,kf.
10. (fobt or ifobt or gfobt).ti,ab,kf.
11. guaiac.ti,ab,kf.
12. ((fecal or faecal or stool) adj5 test$).ti,ab,kf.
13. ((fecal or faecal or stool) and (immunochemical or immunoassay)).ti,ab,kf.
14. Capsule Endoscopy/
15. Capsule Endoscopes/
16. (capsule adj2 endoscop*).ti,ab,kf.
17. pill cam*.ti,ab,kf.
18. pillcam.ti,ab,kf.
19. DNA/
20. DNA Methylation/
21. DNA Mutational Analysis/
22. DNA, neoplasm/
23. 19 or 20 or 21 or 22
24. Feces/
25. 23 and 24
26. ((fecal or faecal or stool) adj5 (DNA or deoxyribonucleic acid)).ti,ab,kf.
27. ((fecal or faecal or stool) adj5 (genetic$ or genomic$)).ti,ab,kf.
28. ((fecal or faecal or stool) adj5 molecular).ti,ab,kf.
29. (f-dna or fdna or s-dna or sdna).ti,ab,kf.
30. “SEPT9 protein, human”.nm.
31. Septins/
32. (SEPTIN9 or SEPTIN 9 or SEPT9 or mSEPT9).ti,ab,kf.
33. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32
34. Mass screening/ or “Early Detection of Cancer”/
35. (screen$ or detect$).ti,ab,kf.
36. 34 or 35
37. 33 and 36
38. Colorectal Neoplasms/
39. Adenomatous Polyposis Coli/
40. Colonic Neoplasms/
41. Sigmoid Neoplasms/
42. Colorectal Neoplasms, Hereditary Nonpolyposis/
43. Rectal Neoplasms/
44. Anus Neoplasms/
45. Anal Gland Neoplasms/
46. Colonic Polyps/
47. Adenomatous Polyps/
48. 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47
49. ((colorectal or colon or colonic or rectal or rectum or rectosigmoid$ or adenomat$) adj3 (cancer$ or carcinoma$ or adenocarcinoma$ or malignan$ or tumor$ or tumour$ or neoplas$ or polyp$)).ti,ab,kf.
50. limit 49 to (“in data review” or in process or “pubmed not medline”)
51. 48 or 50
52. (screen$ or detect$).ti.
53. 51 and (34 or 52)
54. 37 or 53
55. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/
56. meta-analysis as topic/
57. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial or pragmatic clinical trial).pt.
58. control groups/ or double-blind method/ or single-blind method/
59. Random$.ti,ab,kf.
60. clinical trial$.ti,ab,kf.
61. controlled trial$.ti,ab,kf.
62. meta analy$.ti,ab,kf.
63. Cohort Studies/
64. cohort*.ti,ab,kf.
65. 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64
66. 54 and 65
67. Mortality/
68. mortality.fs.
69. Survival rate/
70. Survival analysis/
71. Life Expectancy/
72. “Cause of Death”/
73. mortality.ti,ab,kf.
74. (death or deaths).ti,ab,kf.
75. survival.ti,ab,kf.
76. (registry or registries).ti,ab,kf.
77. 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76
78. 54 and 77
79. 66 or 78
80. limit 79 to humans
81. limit 79 to animals
82. 81 not 80
83. 79 not 82
84. limit 83 to english language
85. limit 84 to yr=“2015 -Current”
86. remove duplicates from 85

KQ2:

Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <1946 to December 16, 2019>, Ovid MEDLINE(R) Epub Ahead of Print < December 16, 2019>, Ovid MEDLINE(R) Daily Update < December 4, 2019>

Search Strategy:

------------------------------------------------------------

1. Colonoscopy/
2. colonoscop$.ti,ab,kf.
3. Sigmoidoscopy/
4. sigmoidoscop$.ti,ab,kf.
5. Colonography, Computed Tomographic/
6. colonograph$.ti,ab,kf.
7. Occult Blood/
8. occult blood.ti,ab,kf.
9. ((fecal or faecal or stool) adj occult).ti,ab,kf.
10. (fobt or ifobt or gfobt).ti,ab,kf.
11. guaiac.ti,ab,kf.
12. ((fecal or faecal or stool) adj5 test$).ti,ab,kf.
13. ((fecal or faecal or stool) and (immunochemical or immunoassay)).ti,ab,kf.
14. Capsule Endoscopy/
15. Capsule Endoscopes/
16. (capsule adj2 endoscop*).ti,ab,kf.
17. pill cam*.ti,ab,kf.
18. pillcam.ti,ab,kf.
19. DNA/
20. DNA Methylation/
21. DNA Mutational Analysis/
22. DNA, neoplasm/
23. 19 or 20 or 21 or 22
24. Feces/
25. 23 and 24
26. ((fecal or faecal or stool) adj5 (DNA or deoxyribonucleic acid)).ti,ab,kf.
27. ((fecal or faecal or stool) adj5 (genetic$ or genomic$)).ti,ab,kf.
28. ((fecal or faecal or stool) adj5 molecular).ti,ab,kf.
29. (f-dna or fdna or s-dna or sdna).ti,ab,kf.
30. “SEPT9 protein, human”.nm.
31. Septins/
32. (SEPTIN9 or SEPTIN 9 or SEPT9 or mSEPT9).ti,ab,kf.
33. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32
34. “Sensitivity and Specificity”/
35. “Predictive Value of Tests”/
36. ROC Curve/
37. False Negative Reactions/
38. False Positive Reactions/
39. Diagnostic Errors/
40. “Reproducibility of Results”/
41. Reference Values/
42. Reference Standards/
43. Observer Variation/
44. Receiver operat$.ti,ab,kf.
45. ROC curve$.ti,ab,kf.
46. sensitivit$.ti,ab,kf.
47. specificit$.ti,ab,kf.
48. predictive value.ti,ab,kf.
49. accuracy.ti,ab,kf.
50. false positive$.ti,ab,kf.
51. false negative$.ti,ab,kf.
52. miss rate$.ti,ab,kf.
53. error rate$.ti,ab,kf.
54. detection rate$.ti,ab,kf.
55. diagnostic yield$.ti,ab,kf.
56. likelihood ratio$.ti,ab,kf.
57. diagnostic odds ratio$.ti,ab,kf.
58. 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57
59. 33 and 58
60. Colonoscopy/st
61. Sigmoidoscopy/st
62. Colonography, Computed Tomographic/st
63. Capsule Endoscopy/st
64. 60 or 61 or 62 or 63
65. 59 or 64
66. Mass screening/ or “Early Detection of Cancer”/
67. (screen$ or detect$).ti,ab,kf.
68. 66 or 67
69. 65 and 68
70. limit 69 to humans
71. limit 69 to animals
72. 71 not 70
73. 69 not 72
74. limit 73 to english language
75. limit 74 to yr=“2015 -Current”
76. remove duplicates from 75

KQ3

Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <1946 to December 16, 2019>, Ovid MEDLINE(R) Epub Ahead of Print < December 16, 2019>, Ovid MEDLINE(R) Daily Update < December 4, 2019>

Search Strategy:

------------------------------------------------------------

1. Colonoscopy/ae, mo [Adverse Effects, Mortality] (2016)
2. Sigmoidoscopy/ae, mo
3. Colonography, Computed Tomographic/ae, mo
4. Capsule Endoscopy/ae, mo
5. Capsule Endoscopes/ae, mo
6. 1 or 2 or 3 or 4 or 5
7. Colonoscopy/
8. Sigmoidoscopy/
9. Colonography, Computed Tomographic/
10. Occult Blood/
11. Capsule Endoscopy/
12. Capsule Endoscopes/
13. DNA/
14. DNA Methylation/
15. DNA Mutational Analysis/
16. DNA, neoplasm/
17. 13 or 14 or 15 or 16
18. Feces/
19. 17 and 18
20. “SEPT9 protein, human”.nm.
21. Septins/
22. 7 or 8 or 9 or 10 or 11 or 12 or 19 or 20 or 21
23. Colorectal Neoplasms/
24. Adenomatous Polyposis Coli/
25. Colonic Neoplasms/
26. Sigmoid Neoplasms/
27. Colorectal Neoplasms, Hereditary Nonpolyposis/
28. Rectal Neoplasms/
29. Anus Neoplasms/
30. Anal Gland Neoplasms/
31. Colonic Polyps/
32. Adenomatous Polyps/
33. 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32
34. Mass screening/ or “Early Detection of Cancer”/
35. (screen$ or detect$).ti.
36. 33 and (34 or 35)
37. Mortality/
38. Morbidity/
39. Death/
40. Hemorrhage/
41. Gastrointestinal hemorrhage/
42. Postoperative hemorrhage/
43. Intraoperative complications/
44. Postoperative complications/
45. incidental findings/
46. (harm or harms or harmful or harmed).ti.
47. (adverse adj (effect$ or event$ or outcome$)).ti.
48. safety.ti.
49. complication$.ti.
50. (death or deaths).ti.
51. (hemorrhag$ or haemorrhag$).ti.
52. bleed$.ti.
53. (death or deaths).ti.
54. ((incidental or extracolonic) adj finding$).ti.
55. 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 (964911)
56. (22 or 36) and 55
57. 6 or 56
58. limit 57 to humans
59. limit 57 to animals
60. 59 not 58
61. 57 not 60
62. limit 61 to (english language and yr=“2015 -Current”)
63. colonoscop$.ti,ab,kf.
64. sigmoidoscop$.ti,ab,kf.
65. colonograph$.ti,ab,kf.
66. occult blood.ti,ab,kf.
67. ((fecal or faecal) adj occult).ti,ab,kf.
68. (fobt or ifobt or gfobt).ti,ab,kf.
69. guaiac.ti,ab,kf.
70. (capsule adj2 endoscop*).ti,ab,kf.
71. pill cam*.ti,ab,kf.
72. pillcam.ti,ab,kf.
73. ((fecal or faecal or stool) adj5 test$).ti,ab,kf.
74. ((fecal or faecal or stool) and (immunochemical or immunoassay)).ti,ab,kf.
75. ((fecal or faecal or stool) adj5 (DNA or deoxyribonucleic acid)).ti,ab,kf.
76. ((fecal or faecal or stool) adj5 (genetic$ or genomic$)).ti,ab,kf.
77. ((fecal or faecal or stool) adj5 molecular).ti,ab,kf.
78. (f-dna or fdna or s-dna or sdna).ti,ab,kf.
79. (SEPTIN9 or SEPTIN 9 or SEPT9 or mSEPT9).ti,ab,kf.
80. 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75 or 76 or 77 or 78 or 79
81. ((colorectal or colon or colonic or rectal or rectum or rectosigmoid$ or adenomat$) adj3 (cancer$ or carcinoma$ or adenocarcinoma$ or malignan$ or tumor$ or tumour$ or neoplas$ or polyp$)).ti,ab,kf.
82. (screen$ or detect$).ti.
83. 81 and 82
84. 80 or 83
85. (harm or harms or harmful or harmed).ti,ab,kf.
86. (adverse adj (effect$ or event$ or outcome$)).ti,ab,kf.
87. safety.ti,ab,kf.
88. complication$.ti,ab,kf.
89. (death or deaths).ti,ab,kf.
90. (hemorrhag$ or haemorrhag$).ti,ab,kf.
91. bleed$.ti,ab,kf.
92. perforat$.ti,ab,kf.
93. ((incidental or extracolonic) adj finding$).ti,ab,kf.
94. 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93
95. 84 and 94
96. limit 95 to (“in data review” or in process or “pubmed not medline”)
97. limit 96 to (english language and yr=“2015 -Current”)
98. 62 or 97
99. remove duplicates from 98

PubMed search strategy [publisher-supplied references only]

#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #13 AND #14 Filters: Publication date from 2015/01/01 to 2019/12/31; English
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #13 AND #14 Filters: Publication date from 2015/01/01 to 2019/12/31
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #13 AND #14
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search publisher[sb]
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (“septin 9”[ti] OR septin9[ti] OR sept9[ti])
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (“fecal occult”[ti] OR “faecal occult”[ti] OR “stool occult”[ti] OR “occult blood”[ti] OR FOBT[ti] OR IFOBT[ti])
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (fecal[ti] OR faecal[ti] OR stool[ti]) AND (immunochemical[ti] OR immunoassay[ti])
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (fdna[ti] OR f-dna[ti] OR sdna[ti] OR s-dna[ti])
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (fecal[ti] OR faecal[ti] OR stool[ti]) AND (molecular[ti] OR genetic[ti] OR genetics[ti])
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (fecal[ti] OR faecal[ti] OR stool[ti]) AND (DNA[ti] OR “deoxyribonucleic acid”[ti])
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search “pill cam”[ti] OR pillcam[ti]
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search capsule[ti] AND endoscop*[ti]
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (colonoscop*[ti] OR colonograph*[ti] OR sigmoidoscop*[ti])
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #1 AND #2
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (screen*[ti] OR detect*[ti] OR surveillance[ti])
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (colorectal[ti] OR colon[ti] OR colonic[ti] OR rectal[ti] OR rectum[ti] OR rectosigmoid*[ti] OR adenoma*[ti]) AND (cancer*[ti] OR carcinoma*[ti] OR adenocarcinoma*[ti] OR malignan*[ti] OR tumor[ti] OR tumors[ti] OR tumour[ti] OR tumours[ti] OR neoplas*[ti] OR polyp[ti] OR polyps[ti] OR polyposis[ti])

Appendix A Table 1 Inclusion and Exclusion Criteria

| Included | Excluded
Populations | Adults age ≥40 years in average-risk or unselected populations; screening populations (i.e., no symptoms) | Populations selected for personal or family history of colorectal cancer (e.g., one or more first-degree relatives with colorectal cancer diagnosed before age 60 years or two or more first-degree relatives diagnosed at any age), known genetic susceptibility syndromes (e.g., Lynch Syndrome, familial adenomatous polyposis), or personal history of inflammatory bowel disease; nonscreening populations (e.g., persons who have symptoms, test positive on screening, have iron deficiency anemia, or are under surveillance for a previous colorectal lesion)
Settings | Settings representative of community practice for flexible sigmoidoscopy and colonoscopy studies; studies conducted in developed countries (categorized as “very high” on the 2017 Human Development Index,^a^ as defined by the United Nations Development Programme) | Primarily research-based settings for endoscopy studies (e.g., small studies aimed at evaluating new endoscopy technologies, studies with operator or resource characteristics that are not applicable to community practice); developing countries
Screening tests | KQ 1: Any program of colorectal cancer screening, including endoscopy, imaging, urine, stool or blood testing; KQs 2, 3:; Direct visualization tests:; - Colonoscopy; - Flexible sigmoidoscopy; - Computed tomography colonography; - Capsule endoscopy^b^; Stool-based tests:; - High-sensitivity guaiac fecal occult blood test; - Fecal immunochemical test (quantitative and qualitative testing); - Stool DNA test (with or without fecal immunochemical testing); Serum-based test:; - Circulating methylated septin 9 gene DNA test (mSEPT9)^b^; Urine-based test | KQs 2, 3: New technologic enhancements to colonoscopy or computed tomography colonography; Hemoccult II (review of test performance and harms limited to high-sensitivity guaiac fecal occult blood test); stool testing using in-office digital rectal examination; double-contrast barium enema; magnetic resonance colonography
Comparisons | KQ 1: No screening or alternate screening strategy; KQ 2: Diagnostic accuracy studies that use colonoscopy as a reference standard; KQ 3: No comparator necessary
Outcomes | KQ 1: Colorectal cancer incidence (by stage and location) or interval colorectal cancer; colorectal cancer–specific or all-cause mortality; KQ 2: Test accuracy, including: sensitivity and specificity (per person for all tests and per lesion for direct visualization tests), positive and negative predictive value (per person for all tests and per lesion for direct visualization tests), and false-positive and false-negative rates; for colorectal cancer, advanced adenoma (high-grade dysplasia, villous histology, and/or size ≥10 mm), or adenomatous or sessile serrated polyps by size (i.e., ≤5 mm, 6 to 9 mm, ≥10 mm) or by location (e.g., proximal or distal colon, rectum); KQ 3: Serious harms requiring unexpected or unwanted medical attention (e.g., requiring hospitalization) and/or resulting in death, including but not limited to perforation, major bleeding, severe abdominal symptoms, and cardiovascular events; extracolonic findings and subsequent diagnostic workup, and adverse events from diagnostic testing for incidental findings on computed tomography colonography; radiation exposure per each computed tomography colonography examination | KQ 1: Incidence of adenomas or advanced neoplasia (composite outcome of advanced adenomas and colorectal cancer); KQ 3: Minor harms, defined as those not necessarily needing or resulting in medical attention (e.g., patient dissatisfaction, anxiety or worry, minor gastrointestinal complaints)
Study design | All KQs: Fair- to good-quality studies; KQ 1: Randomized, controlled trials; controlled clinical trials; prospective cohort studies; KQ 2: Randomized, controlled trials; controlled clinical trials; cohort studies, nested case-control diagnostic accuracy studies, and screening registry studies; KQ 3: Randomized, controlled trials; controlled clinical trials; large screening registry or database observational studies, cohort studies, or systematically selected case series | All KQs: Poor-quality studies; KQ 1: Decision analyses^c^; KQ 2: Diagnostic accuracy studies without a reference standard or without representation of a full spectrum of disease (e.g., case-control studies, studies that excluded indeterminate results); KQ 3: Case studies

a Andorra, Argentina, Australia, Austria, Bahamas, Bahrain, Barbados, Belarus, Belgium, Brunei Darussalam, Bulgaria, Canada, Chile, Croatia, Cyprus, Czechia, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Kazakhstan, Korea (Republic of), Kuwait, Latvia, Liechtenstein, Lithuania, Luxembourg, Malaysia, Malta, Montenegro, Netherlands, New Zealand, Norway, Oman, Poland, Portugal, Qatar, Romania, Russian Federation, Saudi Arabia, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, UK, United Arab Emirates, Uruguay, US. Taiwan is not incorporated into HDI calculations for the People’s Republic of China and will be considered very high HDI based on calculations from Taiwan’s government.

b Technologies with conditional approval by the U.S. Food and Drug Administration for screening for colorectal cancer.

c This review will be accompanied by commissioned collaborative microsimulation decision analyses by CISNET.

Abbreviations: CCT = controlled clinical trial; CRC = colorectal cancer; CTC = computed tomography colonography; DRE = digital rectal exam; FIT = fecal immunochemical test; FIT-DNA = fecal immunochemical test plus deoxyribonucleic acid; FS = flexible sigmoidoscopy; gFOBT = guaiac fecal occult blood test; GI = gastrointestinal; mm = millimeter; MRC = magnetic resonance colonography; NPV = negative predictive value; PPV = positive predictive value; RCT = randomized controlled trial

Appendix A Table 2 Quality Assessment Criteria^*^

Study Design | Adapted Quality Criteria
Cohort studies, adapted from Newcastle-Ottawa Scale ^1^ | Bias arising in randomization process or due to confounding; - Balance in baseline characteristics; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias due to departures form intended interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias in classifying interventions; - Fidelity to intervention protocol; - Participants were analyzed as originally allocated; Bias from missing data; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Diagnostic accuracy studies, adapted from the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) II^2^ instrument | Patient Selection; - Was a consecutive or random sample of patients enrolled?; - Did the study avoid inappropriate exclusions?; Index Test; - Were the index test results interpreted without knowledge of the reference standard results?; - If a threshold was used, was it prespecified or was a range of values presented?; Reference Standard; - Is the reference standard likely to correctly classify the target condition?; - Were the reference standard results interpreted without knowledge of the index test?; - Were staff trained in the use of the reference standard?; - Was fidelity of the reference standard monitored or reported?; Flow and Timing; - Was there an appropriate interval between the index test and reference standard?; - Did all patients receive a reference standard?; - Did all patients receive the same reference standard?; ○ Were all patients included in the analysis?
Randomized clinical trials, adapted from U.S. Preventive Services Task Force Manual ^3^ | Bias arising in the randomization process or due to confounding; Valid random assignment/random sequence generation method used; Allocation concealed; Balance in baseline characteristics; Bias in selecting participants into the study; CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; Fidelity to the intervention protocol; Low risk of contamination between groups; Participants were analyzed as originally allocated; Bias from missing data; No, or minimal, post-randomization exclusions; Outcome data are reasonably complete and comparable between groups; Reasons for missing data are similar across groups; Missing data are unlikely to bias results; Bias in measurement of outcomes; Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* All randomized clinical trials were classified as good, fair, or poor according to the USPSTF Procedure Manual^3^

Appendix A Figure 1 Literature Flow Diagram

Appendix A Figure 1 shows the literature flow diagram. 11,295 citations were screened. 499 full text articles were assessed for eligibility. 33 studies in 66 articles were included for key question 1, 59 studies in 78 articles were included for key question 2, and 131 studies in 163 articles were included for key question 3.