# References

1 LeFevre ML. Screening for vitamin D deficiency in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2015 Jan 20;162(2):133–40. doi: 10.7326/m14-2450. PMID: 25419853.25419853
2 LeBlanc ES, Zakher B, Daeges M, . Screening for vitamin D deficiency: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2015 Jan 20;162(2):109–22. doi: 10.7326/m14-1659. PMID: 25419719.25419719
3 Institute of Medicine. Dietary reference intakes for calcium and vitamin D. Washington, DC: The National Academies Press; 2011.
4 Pludowski P, Holick MF, Pilz S, . Vitamin D effects on musculoskeletal health, immunity, autoimmunity, cardiovascular disease, cancer, fertility, pregnancy, dementia and mortality-a review of recent evidence. Autoimmun Rev. 2013 Aug;12(10):976–89. doi: 10.1016/j.autrev.2013.02.004. PMID: 23542507.23542507
5 Autier P, Mullie P, Macacu A, . Effect of vitamin D supplementation on non-skeletal disorders: a systematic review of meta-analyses and randomised trials. Lancet Diabetes Endocrinol. 2017 Dec;5(12):986–1004. doi: 10.1016/s2213-8587(17)30357-1. PMID: 29102433.29102433
6 Holick MF. The vitamin D deficiency pandemic: approaches for diagnosis, treatment and prevention. Rev Endocr Metab Disord. 2017 Jun;18(2):153–65. doi: 10.1007/s11154-017-9424-1. PMID: 28516265.28516265
7 Ross AC, Manson JE, Abrams SA, . The 2011 report on dietary reference intakes for calcium and vitamin D from the Institute of Medicine: what clinicians need to know. J Clin Endocrinol Metab. 2011;96(1):53–8. doi: 10.1210/jc.2010-2704. PMID: PMC3046611.21118827
8 Holick MF, Binkley NC, Bischoff-Ferrari HA, . Evaluation, treatment, and prevention of vitamin D deficiency: an Endocrine Society clinical practice guideline. J Clin Endocrinol Metab. 2011 Jul;96(7):1911–30. doi: 10.1210/jc.2011-0385. PMID: 21646368.21646368
9 Herrick KA, Storandt RJ, Afful J, . Vitamin D status in the United States, 2011-2014. Am J Clin Nutr. 2019 Jul 1;110(1):150–7. doi: 10.1093/ajcn/nqz037. PMID: 31076739.31076739
10 Yetley EA. Assessing the vitamin D status of the US population. Am J Clin Nutr. 2008 Aug;88(2):558s–64s. doi: 10.1093/ajcn/88.2.558S. PMID: 18689402.18689402
11 Taylor CL, Carriquiry AL, Bailey RL, . Appropriateness of the probability approach with a nutrient status biomarker to assess population inadequacy: a study using vitamin D. Am J Clin Nutr. 2013 Jan;97(1):72–8. doi: 10.3945/ajcn.112.046094. PMID: 23097269.23097269
12 Schleicher RL, Sternberg MR, Lacher DA, . The vitamin D status of the US population from 1988 to 2010 using standardized serum concentrations of 25-hydroxyvitamin D shows recent modest increases. Am J Clin Nutr. 2016 Aug;104(2):454–61. doi: 10.3945/ajcn.115.127985. PMID: 27385610.27385610
13 Orwoll E, Nielson CM, Marshall LM, . Vitamin D deficiency in older men. J Clin Endocrinol Metab. 2009 Apr;94(4):1214–22. doi: 10.1210/jc.2008-1784. PMID: 19174492.19174492
14 McCullough ML, Weinstein SJ, Freedman DM, . Correlates of circulating 25-hydroxyvitamin D: cohort consortium vitamin D pooling project of rarer cancers. Am J Epidemiol. 2010 Jul 1;172(1):21–35. doi: 10.1093/aje/kwq113. PMID: 20562191.20562191
15 Forrest KY, Stuhldreher WL. Prevalence and correlates of vitamin D deficiency in US adults. Nutr Res. 2011 Jan;31(1):48–54. doi: 10.1016/j.nutres.2010.12.001. PMID: 21310306.21310306
16 Holick MF. Vitamin D deficiency. N Engl J Med. 2007 Jul 19;357(3):266–81. doi: 10.1056/NEJMra070553. PMID: 17634462.17634462
17 Bhan A, Rao AD, Rao DS. Osteomalacia as a result of vitamin D deficiency. Endocrinol Metab Clin North Am. 2010 Jun;39(2):321–31, table of contents. doi: 10.1016/j.ecl.2010.02.001. PMID: 20511054.20511054
18 Theodoratou E, Tzoulaki I, Zgaga L, . Vitamin D and multiple health outcomes: umbrella review of systematic reviews and meta-analyses of observational studies and randomised trials. BMJ. 2014 Apr 1;348:g2035. doi: 10.1136/bmj.g2035. PMID: 24690624.24690624
19 Chowdhury R, Kunutsor S, Vitezova A, . Vitamin D and risk of cause specific death: systematic review and meta-analysis of observational cohort and randomised intervention studies. BMJ. 2014 Apr 1;348:g1903. doi: 10.1136/bmj.g1903. PMID: 24690623.24690623
20 Myung SK, Ju W, Cho B, . Efficacy of vitamin and antioxidant supplements in prevention of cardiovascular disease: systematic review and meta-analysis of randomised controlled trials. BMJ. 2013 Jan 18;346:f10. doi: 10.1136/bmj.f10. PMID: 23335472.23335472
21 Bolland MJ, Grey A, Gamble GD, . The effect of vitamin D supplementation on skeletal, vascular, or cancer outcomes: a trial sequential meta-analysis. Lancet Diabetes Endocrinol. 2014 Apr;2(4):307–20. doi: 10.1016/s2213-8587(13)70212-2. PMID: 24703049.24703049
22 Newberry SJ, Chung M, Shekelle PG, . Vitamin D and calcium: a systematic review of health outcomes (update). 2014.
23 Linos E, Keiser E, Kanzler M, . Sun protective behaviors and vitamin D levels in the US population: NHANES 2003-2006. Cancer Causes Control. 2012 Jan;23(1):133–40. doi: 10.1007/s10552-011-9862-0. PMID: 22045154.22045154
24 Millen AE, Wactawski-Wende J, Pettinger M, . Predictors of serum 25-hydroxyvitamin D concentrations among postmenopausal women: the Women’s Health Initiative Calcium plus Vitamin D clinical trial. Am J Clin Nutr. 2010 May;91(5):1324–35. doi: 10.3945/ajcn.2009.28908. PMID: 20219959.20219959
25 Jacques PF, Felson DT, Tucker KL, . Plasma 25-hydroxyvitamin D and its determinants in an elderly population sample. Am J Clin Nutr. 1997 Oct;66(4):929–36. doi: 10.1093/ajcn/66.4.929. PMID: 9322570.9322570
26 Matsuoka LY, Ide L, Wortsman J, . Sunscreens suppress cutaneous vitamin D3 synthesis. J Clin Endocrinol Metab. 1987 Jun;64(6):1165–8. doi: 10.1210/jcem-64-6-1165. PMID: 3033008.3033008
27 Norval M, Wulf HC. Does chronic sunscreen use reduce vitamin D production to insufficient levels? Br J Dermatol. 2009 Oct;161(4):732–6. doi: 10.1111/j.1365-2133.2009.09332.x. PMID: 19663879.19663879
28 Faurschou A, Beyer DM, Schmedes A, . The relation between sunscreen layer thickness and vitamin D production after ultraviolet B exposure: a randomized clinical trial. Br J Dermatol. 2012 Aug;167(2):391–5. doi: 10.1111/j.1365-2133.2012.11004.x. PMID: 22512875.22512875
29 Cancer IAfRo. Vitamin D and cancer. IARC Working group reports. 2008;5:251–60.
30 Samuel L, Borrell LN. The effect of body mass index on optimal vitamin D status in U.S. adults: the National Health and Nutrition Examination Survey 2001-2006. Ann Epidemiol. 2013 Jul;23(7):409–14. doi: 10.1016/j.annepidem.2013.05.011. PMID: 23790345.23790345
31 Ginde AA, Liu MC, Camargo CA, Jr. Demographic differences and trends of vitamin D insufficiency in the US population, 1988-2004. Arch Intern Med. 2009 Mar 23;169(6):626–32. doi: 10.1001/archinternmed.2008.604. PMID: 19307527.19307527
32 Giovannucci E, Liu Y, Rimm EB, . Prospective study of predictors of vitamin D status and cancer incidence and mortality in men. J Natl Cancer Inst. 2006 Apr 5;98(7):451–9. doi: 10.1093/jnci/djj101. PMID: 16595781.16595781
33 Wang TJ, Zhang F, Richards JB, . Common genetic determinants of vitamin D insufficiency: a genome-wide association study. Lancet. 2010 Jul 17;376(9736):180–8. doi: 10.1016/s0140-6736(10)60588-0. PMID: 20541252.20541252
34 Sempos CT, Heijboer AC, Bikle DD, . Vitamin D assays and the definition of hypovitaminosis D: results from the First International Conference on Controversies in Vitamin D. Br J Clin Pharmacol. 2018 Oct;84(10):2194–207. doi: 10.1111/bcp.13652. PMID: 29851137.29851137
35 Hanley DA, Cranney A, Jones G, . Vitamin D in adult health and disease: a review and guideline statement from Osteoporosis Canada. CMAJ. 2010 Sep 7;182(12):E610–8. doi: 10.1503/cmaj.080663. PMID: 20624868.20624868
36 McKee J. Studies find patients have low levels of vitamin D. AAOS Now. 2014;8(11).
37 Dawson-Hughes B, Mithal A, Bonjour JP, . IOF position statement: vitamin D recommendations for older adults. Osteoporos Int. 2010 Jul;21(7):1151–4. doi: 10.1007/s00198-010-1285-3. PMID: 20422154.20422154
38 Cosman F, de Beur SJ, LeBoff MS, . Clinician’s guide to prevention and treatment of osteoporosis. Osteoporos Int. 2014 Oct;25(10):2359–81. doi: 10.1007/s00198-014-2794-2. PMID: 25182228.25182228
39 International Osteoporosis Foundation. International osteoporosis foundation statement of new IOM dietary reference intakes for calcium and vitamin D. Accessed 7/7/2018, 2018.
40 Chung M, Balk EM, Brendel M, . Vitamin D and calcium: a systematic review of health outcomes. Evid Rep Technol Assess (Full Rep). 2009;183(183):1–420.
41 Tripkovic L, Lambert H, Hart K, . Comparison of vitamin D2 and vitamin D3 supplementation in raising serum 25-hydroxyvitamin D status: a systematic review and meta-analysis. Am J Clin Nutr. 2012 Jun;95(6):1357–64. doi: 10.3945/ajcn.111.031070. PMID: 22552031.22552031
42 Sanders KM, Stuart AL, Williamson EJ, . Annual high-dose oral vitamin D and falls and fractures in older women: a randomized controlled trial. JAMA. 2010 May 12;303(18):1815–22. doi: 10.1001/jama.2010.594. PMID: 20460620.20460620
43 Ginde AA, Blatchford P, Breese K, . High-dose monthly vitamin D for prevention of acute respiratory infection in older long-term care residents: a randomized clinical trial. J Am Geriatr Soc. 2017 Mar;65(3):496–503. doi: 10.1111/jgs.14679. PMID: 27861708.27861708
44 Smith H, Anderson F, Raphael H, . Effect of annual intramuscular vitamin D on fracture risk in elderly men and women--a population-based, randomized, double-blind, placebo-controlled trial. Rheumatology (Oxford). 2007 Dec;46(12):1852–7. doi: 10.1093/rheumatology/kem240. PMID: 17998225.17998225
45 Tripkovic L, Wilson LR, Hart K, . Daily supplementation with 15 mug vitamin D2 compared with vitamin D3 to increase wintertime 25-hydroxyvitamin D status in healthy South Asian and white European women: a 12-wk randomized, placebo-controlled food-fortification trial. Am J Clin Nutr. 2017 Aug;106(2):481–90. doi: 10.3945/ajcn.116.138693. PMID: 28679555.28679555
46 Itkonen ST, Skaffari E, Saaristo P, . Effects of vitamin D2-fortified bread v. supplementation with vitamin D2 or D3 on serum 25-hydroxyvitamin D metabolites: an 8-week randomised-controlled trial in young adult Finnish women. Br J Nutr. 2016 Apr 14;115(7):1232–9. doi: 10.1017/s0007114516000192. PMID: 26864127.26864127
47 Lehmann U, Hirche F, Stangl GI, . Bioavailability of vitamin D(2) and D(3) in healthy volunteers, a randomized placebo-controlled trial. J Clin Endocrinol Metab. 2013 Nov;98(11):4339–45. doi: 10.1210/jc.2012-4287. PMID: 24001747.24001747
48 Heaney RP, Dowell MS, Hale CA, . Calcium absorption varies within the reference range for serum 25-hydroxyvitamin D. J Am Coll Nutr. 2003 Apr;22(2):142–6. PMID: 12672710.12672710
49 Vieth R. What is the optimal vitamin D status for health? Prog Biophys Mol Biol. 2006 Sep;92(1):26–32. doi: 10.1016/j.pbiomolbio.2006.02.003. PMID: 16766239.16766239
50 Gallagher JC, Sai A, Templin T, 2nd, . Dose response to vitamin D supplementation in postmenopausal women: a randomized trial. Ann Intern Med. 2012 Mar 20;156(6):425–37. doi: 10.7326/0003-4819-156-6-201203200-00005. PMID: 22431675.22431675
51 Bischoff-Ferrari HA, Dawson-Hughes B, John Orav E, . Monthly high-dose Vitamin D treatment for the prevention of functional decline a randomized clinical trial. JAMA Internal Medicine. 2016;176(2):175–83. doi: 10.1001/jamainternmed.2015.7148.26747333
52 Pilz S, Zittermann A, Trummer C, . Vitamin D testing and treatment: a narrative review of current evidence. Endocr Connect. 2019 Feb 1;8(2):R27–R43. doi: 10.1530/EC-18-0432. PMID: 30650061.30650061
53 Durup D, Jorgensen HL, Christensen J, . A reverse J-shaped association between serum 25-hydroxyvitamin D and cardiovascular disease mortality: the CopD Study. J Clin Endocrinol Metab. 2015 Jun;100(6):2339–46. doi: 10.1210/jc.2014-4551. PMID: 25710567.25710567
54 Burt LA, Billington EO, Rose MS, . Effect of high-dose vitamin D supplementation on volumetric bone density and bone strength: a randomized clinical trial. JAMA. 2019 Aug 27;322(8):736–45. doi: 10.1001/jama.2019.11889. PMID: 31454046.31454046
55 Smith LM, Gallagher JC, Suiter C. Medium doses of daily vitamin D decrease falls and higher doses of daily vitamin D3 increase falls: A randomized clinical trial. J Steroid Biochem Mol Biol. 2017 Oct;173:317–22. doi: 10.1016/j.jsbmb.2017.03.015. PMID: 28049025.28323044
56 Holick MF. Vitamin D status: measurement, interpretation and clinical application. Ann Epidemiol. 2009 03/10;19(2):73–8. doi: 10.1016/j.annepidem.2007.12.001. PMID: PMC2665033.18329892
57 Rejnmark L, Avenell A, Masud T, . Vitamin D with calcium reduces mortality: patient level pooled analysis of 70,528 patients from eight major vitamin D trials. J Clin Endocrinol Metab. 2012 Aug;97(8):2670–81. doi: 10.1210/jc.2011-3328. PMID: 22605432.22605432
58 Patient level pooled analysis of 68 500 patients from seven major vitamin D fracture trials in US and Europe. BMJ. 2010 Jan 12;340:b5463. doi: 10.1136/bmj.b5463. PMID: 20068257.20068257
59 Kopecky SL, Bauer DC, Gulati M, . Lack of evidence linking calcium with or without vitamin D supplementation to cardiovascular disease in generally healthy adults: a clinical guideline from the National Osteoporosis Foundation and the American Society for Preventive Cardiology. Ann Intern Med. 2016 Dec 20;165(12):867–8. doi: 10.7326/m16-1743. PMID: 27776362.27776362
60 Kahwati LC, Weber RP, Pan H, . Vitamin D, calcium, or combined supplementation for the primary prevention of fractures in community-dwelling adults: evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2018 Apr 17;319(15):1600–12. doi: 10.1001/jama.2017.21640. PMID: 29677308.29677308
61 Crowe FL, Jolly K, MacArthur C, . Trends in the incidence of testing for vitamin D deficiency in primary care in the UK: a retrospective analysis of The Health Improvement Network (THIN), 2005-2015. BMJ Open. 2019 Jun 4;9(6):e028355. doi: 10.1136/bmjopen-2018-028355. PMID: 31167871.31167871
62 Ferrari R, Prosser C. Testing vitamin D levels and choosing wisely. JAMA Intern Med. 2016 Jul 1;176(7):1019–20. doi: 10.1001/jamainternmed.2016.1929. PMID: 27214530.27214530
63 Caillet P, Goyer-Joos A, Viprey M, . Increase of vitamin D assays prescriptions and associated factors: a population-based cohort study. Sci Rep. 2017 Sep 4;7(1):10361. doi: 10.1038/s41598-017-10263-8. PMID: 28871163.28871163
64 United Nations Development Programme. Human development report 2016. United Nations Development Programme. New York City, NY: 2016. http://hdr.undp.org/sites/default/files/2016_human_development_report.pdf
65 Sterne JAC, Savović J, Page MJ, . RoB 2: a revised tool for assessing risk of bias in randomised trials. BMJ. 2019 Aug 28;366:l4898. doi: 10.1136/bmj.l4898. PMID: 31462531.31462531
66 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity. Methods Research Paper. AHRQ Publication No. 10-EHC070-EF. Rockville MD: Agency for Healthcare Research and Quality; September 2010. PMID: 2143333721433337. http://effectivehealthcare.ahrq.gov/
67 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986 Sep;7(3):177–88. PMID: 3802833.3802833
68 Higgins JP, Thomas J, Chandler J, Cumpston M, Li T, Page MJ, ., eds. Cochrane handbook for systematic reviews of interventions. Chichester, UK: John Wiley & Sons; 2019. www.handbook.cochrane.org. Accessed 12/11/19.
69 Agency for Healthcare Research and Quality. Methods guide for effectiveness and comparative effectiveness reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; January 2014. http://effectivehealthcare.ahrq.gov/
70 Hansen KE, Johnson RE, Chambers KR, . Treatment of vitamin D insufficiency in postmenopausal women: a randomized clinical trial. JAMA Intern Med. 2015 Oct;175(10):1612–21. doi: 10.1001/jamainternmed.2015.3874. PMID: 26237520.26237520
71 Bislev LS, Langagergaard Rødbro L, Rolighed L, . Bone microstructure in response to vitamin D3 supplementation: a randomized placebo-controlled trial. Calcif Tissue Int. 2019;104(2):160–70. doi: 10.1007/s00223-018-0481-6.30293198
72 Manson JE, Cook NR, Lee IM, . Vitamin D supplements and prevention of cancer and cardiovascular disease. N Engl J Med. 2019 Jan 3;380(1):33–44. doi: 10.1056/NEJMoa1809944. PMID: 30415629.30415629
73 Khaw KT, Stewart AW, Waayer D, . Effect of monthly high-dose vitamin D supplementation on falls and non-vertebral fractures: secondary and post-hoc outcomes from the randomised, double-blind, placebo-controlled ViDA trial. Lancet Diabetes Endocrinol. 2017 Jun;5(6):438–47. doi: 10.1016/s2213-8587(17)30103-1. PMID: 28461159.28461159
74 Hin H, Tomson J, Newman C, . Optimum dose of vitamin D for disease prevention in older people: BEST-D trial of vitamin D in primary care. Osteoporos Int. 2017 Mar;28(3):841–51. doi: 10.1007/s00198-016-3833-y. PMID: 27718150.27986983
75 Jorde R, Sollid ST, Svartberg J, . Vitamin D 20,000 IU per week for five years does not prevent progression from prediabetes to diabetes. J Clin Endocrinol Metab. 2016 Apr;101(4):1647–55. doi: 10.1210/jc.2015-4013. PMID: 27031473.26829443
76 Davidson MB, Duran P, Lee ML, . High-dose vitamin D supplementation in people with prediabetes and hypovitaminosis D. Diabetes Care. 2013 Feb;36(2):260–6. doi: 10.2337/dc12-1204. PMID: 23033239.23033239
77 Pittas AG, Dawson-Hughes B, Sheehan P, . Vitamin D supplementation and prevention of type 2 diabetes. N Engl J Med. 2019 Aug 8;381(6):520–30. doi: 10.1056/NEJMoa1900906. PMID: 30049963.31173679
78 Jorde R, Kubiak J. No improvement in depressive symptoms by vitamin D supplementation: results from a randomised controlled trial. J Nutr Sci. 2018;7:e30. doi: 10.1017/jns.2018.19. PMID: 30510695.30510695
79 Shea MK, Fielding RA, Dawson-Hughes B. The effect of vitamin D supplementation on lower-extremity power and function in older adults: a randomized controlled trial. Am J Clin Nutr. 2019 Feb 1;109(2):369–79. doi: 10.1093/ajcn/nqy290. PMID: 30204734.30715090
80 Jackson RD, LaCroix AZ, Gass M, . Calcium plus vitamin D supplementation and the risk of fractures. N Engl J Med. 2006;354(7):669–83.16481635
81 Kjaergaard M, Waterloo K, Wang CE, . Effect of vitamin D supplement on depression scores in people with low levels of serum 25-hydroxyvitamin D: nested case-control study and randomised clinical trial. Br. 2012;201(5):360–8.
82 Gallagher JC, Jindal PS, Smith LM. Vitamin D supplementation in young White and African American women. J Bone Miner Res. 2014 Jan;29(1):173–81. doi: 10.1002/jbmr.2010. PMID: 23761326.23761326
83 Arvold DS, Odean MJ, Dornfeld MP, . Correlation of symptoms with vitamin D deficiency and symptom response to cholecalciferol treatment: a randomized controlled trial. Endocr Pract. 2009;15(3):203–12. doi: 10.4158/EP.15.3.203. PMID: CN-00703940.19364687
84 Lips P, Binkley N, Pfeifer M, . Once-weekly dose of 8400 IU vitamin D(3) compared with placebo: effects on neuromuscular function and tolerability in older adults with vitamin D insufficiency. Am J Clin Nutr. 2010;91(4):985–91. doi: 10.3945/ajcn.2009.28113. PMID: 20130093.20130093
85 Pfeifer M, Begerow B, Minne HW, . Effects of a long-term vitamin D and calcium supplementation on falls and parameters of muscle function in community-dwelling older individuals. Osteoporos Int. 2009;20(2):315–22.18629569
86 Pfeifer M, Begerow B, Minne HW, . Effects of a short-term vitamin D and calcium supplementation on body sway and secondary hyperparathyroidism in elderly women. J Bone Miner Res. 2000;15(6):1113–8.10841179
87 Lips P, Graafmans WC, Ooms ME, . Vitamin D supplementation and fracture incidence in elderly persons. A randomized, placebo-controlled clinical trial. Ann Intern Med. 1996;124(4):400–6.8554248
88 Chapuy MC, Pamphile R, Paris E, . Combined calcium and vitamin D3 supplementation in elderly women: confirmation of reversal of secondary hyperparathyroidism and hip fracture risk: the Decalyos II study. Osteoporos Int. 2002;13(3):257–64.11991447
89 Brazier M, Grados F, Kamel S, . Clinical and laboratory safety of one year’s use of a combination calcium + vitamin D tablet in ambulatory elderly women with vitamin D insufficiency: results of a multicenter, randomized, double-blind, placebo-controlled study. Clin Ther. 2005;27(12):1885–93.16507374
90 Bischoff HA, Stähelin HB, Dick W, . Effects of vitamin D and calcium supplementation on falls: a randomized controlled trial. J Bone Miner Res. 2003;18(2):343–51.12568412
91 Janssen HCJP, Samson MM, Verhaar HJJ. Muscle strength and mobility in vitamin D-insufficient female geriatric patients: a randomized controlled trial on vitamin D and calcium supplementation. Aging Clin Exp Res. 2010;22(1):78–84.20305368
92 Krieg MA, Jacquet AF, Bremgartner M, . Effect of supplementation with vitamin D3 and calcium on quantitative ultrasound of bone in elderly institutionalized women: a longitudinal study. Osteoporos Int. 1999;9(6):483–8.10624454
93 Kärkkäinen MK, Tuppurainen M, Salovaara K, . Does daily vitamin D 800 IU and calcium 1000 mg supplementation decrease the risk of falling in ambulatory women aged 65-71 years? A 3-year randomized population-based trial (OSTPRE-FPS). Maturitas. 2010;65(4):359–65.20060665
94 Wood AD, Secombes KR, Thies F, . Vitamin D3 supplementation has no effect on conventional cardiovascular risk factors: a parallel-group, double-blind, placebo-controlled RCT. J Clin Endocrinol Metab. 2012;97(10):3557–68. doi: 10.1210/jc.2012-2126. PMID: 22865902.22865902
95 Grimnes G, Figenschau Y, Almås B, . Vitamin D, insulin secretion, sensitivity, and lipids: results from a case-control study and a randomized controlled trial using hyperglycemic clamp technique. Diabetes. 2011;60(11):2748–57.21911741
96 LaCroix AZ, Kotchen J, Anderson G, . Calcium plus vitamin D supplementation and mortality in postmenopausal women: the Women’s Health Initiative calcium-vitamin D randomized controlled trial. Journals of Gerontology. Series A, Biological sciences and medical sciences. 2009;64(5):559–67.
97 LeBoff MS, Murata EM, Cook NR, . VITamin D and OmegA-3 TriaL (VITAL): Effects of Vitamin D Supplements on Risk of Falls in the US Population. J Clin Endocrinol Metab. 2020 Sep 1;105(9):2929–38. doi: 10.1210/clinem/dgaa311. PMID: 32492153.32492153
98 de Boer IH, Tinker LF, Connelly S, . Calcium plus vitamin D supplementation and the risk of incident diabetes in the Women’s Health Initiative. Diabetes Care. 2008;31(4):701–7.18235052
99 Scragg R, Stewart AW, Waayer D, . Effect of monthly high-dose vitamin D supplementation on cardiovascular disease in the Vitamin D Assessment Study: a randomized clinical trial. JAMA Cardiol. 2017 Jun 1;2(6):608–16. doi: 10.1001/jamacardio.2017.0175. PMID: 28384800.28384800
100 Scragg R, Khaw KT, Toop L, . Monthly High-Dose Vitamin D Supplementation and Cancer Risk: A Post Hoc Analysis of the Vitamin D Assessment Randomized Clinical Trial. JAMA Oncol. 2018 Nov 1;4(11):e182178. doi: 10.1001/jamaoncol.2018.2178. PMID: 29316405.30027269
101 Wactawski-Wende J, Kotchen JM, Anderson GL, . Calcium plus vitamin D supplementation and the risk of colorectal cancer. N Engl J Med. 2006;354(7):684–96.16481636
102 Chlebowski RT, Johnson KC, Kooperberg C, . Calcium plus vitamin D supplementation and the risk of breast cancer. J Natl Cancer Inst. 2008;100(22):1581–91.19001601
103 Okereke OI, Reynolds CF, 3rd, Mischoulon D, . Effect of Long-term Vitamin D3 Supplementation vs Placebo on Risk of Depression or Clinically Relevant Depressive Symptoms and on Change in Mood Scores: A Randomized Clinical Trial. JAMA. 2020 Aug 4;324(5):471–80. doi: 10.1001/jama.2020.10224. PMID: 32749491.32749491
104 Honkanen R, Alhava E, Parviainen M, . The necessity and safety of calcium and vitamin D in the elderly. J Am Geriatr Soc. 1990;38(8):862–6.2387950
105 Witham MD, Adams F, Kabir G, . Effect of short-term vitamin D supplementation on markers of vascular health in South Asian women living in the UK--a randomised controlled trial. Atherosclerosis. 2013 Oct;230(2):293–9. doi: 10.1016/j.atherosclerosis.2013.08.005. PMID: 23738846.24075759
106 Gallagher JC, Peacock M, Yalamanchili V, . Effects of vitamin D supplementation in older African American women. J Clin Endocrinol Metab. 2013 Mar;98(3):1137–46. doi: 10.1210/jc.2012-3106. PMID: 23059649.23386641
107 Aloia JF, Talwar SA, Pollack S, . A randomized controlled trial of vitamin D3 supplementation in African American women. Arch Intern Med. 2005;165(14):1618–23.16043680
108 Knutsen KV, Madar AA, Lagerløv P, . Does vitamin D improve muscle strength in adults? A randomized, double-blind, placebo-controlled trial among ethnic minorities in Norway. J Clin Endocrinol Metab. 2014;99(1):194–202.24248184
109 Martineau AR, Wilkinson RJ, Wilkinson KA, . A single dose of vitamin D enhances immunity to mycobacteria. Am J Respir Crit Care Med. 2007;176(2):208–13.17463418
110 Wamberg L, Kampmann U, Stodkilde-Jorgensen H, . Effects of vitamin D supplementation on body fat accumulation, inflammation, and metabolic risk factors in obese adults with low vitamin D levels - results from a randomized trial. Eur J Intern Med. 2013 Oct;24(7):644–9. doi: 10.1016/j.ejim.2013.03.005. PMID: 23892991.23566943
111 Aloia J, Fazzari M, Islam S, . Vitamin D supplementation in elderly Black women does not prevent bone loss: a randomized controlled trial. J Bone Miner Res. 2018;(no pagination)doi: 10.1002/jbmr.3521. PMID: CN-01630422.
112 Borgi L, McMullan C, Wohlhueter A, . Effect of eitamin D on endothelial function: a randomized, double-blind, placebo-controlled trial. Am J Hypertens. 2017 Feb;30(2):124–9. doi: 10.1093/ajh/hpw135. PMID: 27776564.28077419
113 Gagnon C, Daly RM, Carpentier A, . Effects of combined calcium and vitamin D supplementation on insulin secretion, insulin sensitivity and beta-cell function in multi-ethnic vitamin D-deficient adults at risk for type 2 diabetes: a pilot randomized, placebo-controlled trial. PLoS One. 2014;9(10):e109607. doi: 10.1371/journal.pone.0109607. PMID: 24975273.25299668
114 Kearns MD, Binongo JN, Watson D, . The effect of a single, large bolus of vitamin D in healthy adults over the winter and following year: a randomized, double-blind, placebo-controlled trial. Eur J Clin Nutr. 2015 Feb;69(2):193–7. doi: 10.1038/ejcn.2014.209. PMID: 25476069.25271011
115 Lerchbaum E, Pilz S, Trummer C, . Vitamin D and testosterone in healthy men: a randomized controlled trial. J Clin Endocrinol Metab. 2017 Nov 1;102(11):4292–302. doi: 10.1210/jc.2017-01428. PMID: 28969731.28938446
116 Mason C, Xiao L, Imayama I, . Vitamin D3 supplementation during weight loss: a double-blind randomized controlled trial. Am J Clin Nutr. 2014 May;99(5):1015–25. doi: 10.3945/ajcn.113.073734. PMID: 24886848.24622804
117 Moreira-Lucas TS, Duncan AM, Rabasa-Lhoret R, . Effect of vitamin D supplementation on oral glucose tolerance in individuals with low vitamin D status and increased risk for developing type 2 diabetes (EVIDENCE): a double-blind, randomized, placebo-controlled clinical trial. Diabetes Obes Metab. 2017 Jan;19(1):133–41. doi: 10.1111/dom.12794. PMID: 27524803.27717236
118 Ng K, Scott JB, Drake BF, . Dose response to vitamin D supplementation in African Americans: results of a 4-arm, randomized, placebo-controlled trial. Am J Clin Nutr. 2014 Mar;99(3):587–98. doi: 10.3945/ajcn.113.067777. PMID: 24335055.24368437
119 Nowak A, Boesch L, Andres E, . Effect of vitamin D3 on self-perceived fatigue: a double-blind randomized placebo-controlled trial. Medicine (Baltimore). 2016 Dec;95(52):e5353. doi: 10.1097/md.0000000000005353. PMID: 27696575.28033244
120 Pilz S, Gaksch M, Kienreich K, . Effects of vitamin D on blood pressure and cardiovascular risk factors: a randomized controlled trial. Hypertension. 2015 Jun;65(6):1195–201. doi: 10.1161/hypertensionaha.115.05319. PMID: 25602255.25801871
121 Raed A, Bhagatwala J, Zhu H, . Dose responses of vitamin D3 supplementation on arterial stiffness in overweight African Americans with vitamin D deficiency: a placebo controlled randomized trial. PLoS One. 2017;12(12):e0188424. doi: 10.1371/journal.pone.0188424. PMID: 29027817.29216203
122 Tran B, Armstrong BK, Ebeling PR, . Effect of vitamin D supplementation on antibiotic use: a randomized controlled trial. Am J Clin Nutr. 2014 Jan;99(1):156–61. doi: 10.3945/ajcn.113.063271. PMID: 23566943.24108783
123 Guirguis-Blake JM, Michael YL, Perdue LA, . Interventions to prevent falls in older adults: updated evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2018 Apr 24;319(16):1705–16. doi: 10.1001/jama.2017.21962. PMID: 29710140.29710140
124 Grossman DC, Curry SJ, Owens DK, . Interventions to prevent falls in community-dwelling older adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2018 Apr 24;319(16):1696–704. doi: 10.1001/jama.2018.3097. PMID: 29710141.29710141
125 Bjelakovic G, Gluud LL, Nikolova D, . Vitamin D supplementation for prevention of cancer in adults. Cochrane Database Syst Rev. 2014;6:CD007469. doi: 10.1002/14651858.CD007469.pub2. PMID: 24953955.24953955
126 Keum N, Lee DH, Greenwood DC, . Vitamin D supplementation and total cancer incidence and mortality: a meta-analysis of randomized controlled trials. Ann Oncol. 2019 May;30(5):733–43. doi: 10.1093/annonc/mdz059. PMID: 31987340.30796437
127 Zhang Y, Fang F, Tang J, . Association between vitamin D supplementation and mortality: systematic review and meta-analysis. BMJ. 2019 Aug 12;366:l4673. doi: 10.1136/bmj.l4673. PMID: 31405892.31405892
128 Goulao B, Stewart F, Ford JA, . Cancer and vitamin D supplementation: a systematic review and meta-analysis. Am J Clin Nutr. 2018 Apr 1;107(4):652–63. doi: 10.1093/ajcn/nqx047. PMID: 29635490.29635490
129 Zhang Y, Tan H, Tang J, . Effects of Vitamin D Supplementation on Prevention of Type 2 Diabetes in Patients With Prediabetes: A Systematic Review and Meta-analysis. Diabetes Care. 2020;43(7):1650–8. doi: 10.2337/dc19-1708.33534730
130 Barbarawi M, Zayed Y, Barbarawi O, . Effect of Vitamin D Supplementation on the Incidence of Diabetes Mellitus. J Clin Endocrinol Metab. 2020 Aug 1;105(8)doi: 10.1210/clinem/dgaa335. PMID: 32491181.32491181
131 Malihi Z, Wu Z, Lawes CMM, . Adverse events from large dose vitamin D supplementation taken for one year or longer. J Steroid Biochem Mol Biol. 2019 Apr;188:29–37. doi: 10.1016/j.jsbmb.2018.12.002. PMID: 30529281.30529281
132 Malihi Z, Wu Z, Stewart AW, . Hypercalcemia, hypercalciuria, and kidney stones in long-term studies of vitamin D supplementation: a systematic review and meta-analysis. Am J Clin Nutr. 2016 Oct;104(4):1039–51. doi: 10.3945/ajcn.116.134981. PMID: 27604776.27604776
133 Avenell A, Mak JC, O’Connell D. Vitamin D and vitamin D analogues for preventing fractures in post-menopausal women and older men. Cochrane Database Syst Rev. 2014 Apr 14(4):CD000227. doi: 10.1002/14651858.CD000227.pub4. PMID: 24729336.24729336
134 lee JA, van Hecke O, Roberts N. Vitamin D: a rapid review of the evidence for treatment or prevention in COVID-19. Oxford: The Centre for Evidence-Based Medicine; 2020. Accessed December 7, 2020.
135 National Institute for Health and Care Excellence. Advisory statement on likely place in therapy. COVID-19 rapid evidence summary: vitamin D for COVID-19 | Advice | NICE. England: National Institute for Health and Care Excellence; 2020. Accessed December 7, 2020.
136 American Academy of Family Physicians. Clinical preventive service recommendation. Vitamin D deficiency: screening. Leawood, KS: American Academy of Family Physicians; 2014. https://www.aafp.org/patient-care/clinical-recommendations/all/vitamin-D-deficiency.html. Accessed July 12, 2018.
137 Camacho PM, Petak SM, Binkley N, . American Association of Clinical Endocrinologists and American College of Endocrinology Clinical Practice Guidelines for the Diagnosis and Treatment of Postmenopausal Osteoporosis - 2016. Endocr Pract. 2016 Sep 2;22(Suppl 4):1–42. doi: 10.4158/ep161435.Gl. PMID: 27662240.27662240
138 ACOG Practice Bulletin No. 129. Osteoporosis. Obstet Gynecol. 2012 Sep;120(3):718–34. doi: 10.1097/AOG.0b013e31826dc446. PMID: 22914492.22914492
139 Recommendations abstracted from the American Geriatrics Society Consensus Statement on vitamin D for Prevention of Falls and Their Consequences. J Am Geriatr Soc. 2014 Jan;62(1):147–52. doi: 10.1111/jgs.12631. PMID: 24350602.24350602
140 American Society for Clinical Pathology. Choosing wisely. Twenty things physicians and patients should question. Philadelphia, PA: American Society for Clinical Pathology, Choosing Wisely; 2017. https://www.ascp.org/content/docs/default-source/get-involved-pdfs/20-things-to-question.pdf?sfvrsn=4 Accessed July 12, 2018.
141 National Osteoporosis Foundation. Calcium and Vitamin D. Arlington, VA: National Osteoporosis Foundation; 2018. https://www.nof.org/patients/treatment/calciumvitamin-d/. Accessed December 29, 2019.
142 Talwar SA, Aloia JF, Pollack S, . Dose response to vitamin D supplementation among postmenopausal African American women. Am J Clin Nutr. 2007;86(6):1657–62.18065583
143 McMullan CJ, Borgi L, Curhan GC, . The effect of vitamin D on renin-angiotensin system activation and blood pressure: a randomized control trial. J Hypertens. 2017 Apr;35(4):822–9. doi: 10.1097/hjh.0000000000001220. PMID: 28345527.28033130
144 Jorde R, Sollid ST, Svartberg J, . Prevention of urinary tract infections with vitamin D supplementation 20,000 IU per week for five years. Results from an RCT including 511 subjects. Infect Dis (Lond). 2016 Nov–Dec;48(11–12):823–8. doi: 10.1080/23744235.2016.1201853. PMID: 27357103.27357103
145 Kärkkäinen M, Tuppurainen M, Salovaara K, . Effect of calcium and vitamin D supplementation on bone mineral density in women aged 65-71 years: a 3-year randomized population-based trial (OSTPRE-FPS). Osteoporos Int. 2010;21(12):2047–55.20204604
146 Ooms ME, Roos JC, Bezemer PD, . Prevention of bone loss by vitamin D supplementation in elderly women: a randomized double-blind trial. J Clin Endocrinol Metab. 1995;80(4):1052–8.7714065
147 Manson JE, Cook NR, Lee IM, . Marine n-3 fatty acids and prevention of cardiovascular disease and cancer. N Engl J Med. 2019 Jan 3;380(1):23–32. doi: 10.1056/NEJMoa1811403. PMID: 30415637.30415637
148 Manson JE, Bassuk SS, Lee IM, . The VITamin D and OmegA-3 TriaL (VITAL): rationale and design of a large randomized controlled trial of vitamin D and marine omega-3 fatty acid supplements for the primary prevention of cancer and cardiovascular disease. Contemp Clin Trials. 2012 Jan;33(1):159–71. doi: 10.1016/j.cct.2011.09.009. PMID: 21986389.21986389
149 Donlon CM, LeBoff MS, Chou SH, . Baseline characteristics of participants in the VITamin D and OmegA-3 TriaL (VITAL): Effects on Bone Structure and Architecture. Contemp Clin Trials. 2018 Apr;67:56–67. doi: 10.1016/j.cct.2018.02.003. PMID: 29408561.29408561
150 Bassuk SS, Manson JE, Lee IM, . Baseline characteristics of participants in the VITamin D and OmegA-3 TriaL (VITAL). Contemp Clin Trials. 2016 Mar;47:235–43. doi: 10.1016/j.cct.2015.12.022. PMID: 26767629.26767629
151 Chandler PD, Giovannucci EL, Scott JB, . Null association between vitamin D and PSA levels among black men in a vitamin D supplementation trial. Cancer Epidemiol Biomarkers Prev. 2014 Sep;23(9):1944–7. doi: 10.1158/1055-9965.Epi-14-0522. PMID: 24974252.24974387
152 Chandler PD, Scott JB, Drake BF, . Impact of vitamin D supplementation on inflammatory markers in African Americans: results of a four-arm, randomized, placebo-controlled trial. Cancer Prev Res (Phila). 2014 Feb;7(2):218–25. doi: 10.1158/1940-6207.Capr-13-0338-t. PMID: 24423309.24327720
153 Grubler MR, Gaksch M, Kienreich K, . Effects of vitamin D supplementation on glycated haemoglobin and fasting glucose levels in hypertensive patients: a randomized controlled trial. Diabetes Obes Metab. 2016 Oct;18(10):1006–12. doi: 10.1111/dom.12709. PMID: 27732653.27334070
154 Grubler MR, Gaksch M, Kienreich K, . Effects of vitamin D supplementation on plasma aldosterone and renin-a randomized placebo-controlled trial. J Clin Hypertens (Greenwich). 2016 Jul;18(7):608–13. doi: 10.1111/jch.12825. PMID: 26609169.27098193
155 Grubler MR, Gaksch M, Kienreich K, . Effects of vitamin D3 on asymmetric- and symmetric dimethylarginine in arterial hypertension. J Steroid Biochem Mol Biol. 2018 Jan;175:157–63. doi: 10.1016/j.jsbmb.2016.12.014. PMID: 27693095.28027911
156 Bhagatwala J, Zhu H, Parikh SJ, . Dose and time responses of vitamin D biomarkers to monthly vitamin D3 supplementation in overweight/obese African Americans with suboptimal vitamin d status: a placebo controlled randomized clinical trial. BMC Obes. 2015;2:27. doi: 10.1186/s40608-015-0056-2. PMID: 26217542.26217542
157 Tran B, Armstrong BK, Carlin JB, . Recruitment and results of a pilot trial of vitamin D supplementation in the general population of Australia. J Clin Endocrinol Metab. 2012 Dec;97(12):4473–80. doi: 10.1210/jc.2012-2682. PMID: 23066119.23066119
158 Wamberg L, Pedersen SB, Richelsen B, . The effect of high-dose vitamin D supplementation on calciotropic hormones and bone mineral density in obese subjects with low levels of circulating 25-hydroxyvitamin d: results from a randomized controlled study. Calcif Tissue Int. 2013 Jul;93(1):69–77. doi: 10.1007/s00223-013-9729-3. PMID: 23564348.23591713
159 Macdonald HM, Gryka A, Tang JCY, . Longevity of daily oral vitamin D3 supplementation: differences in 25OHD and 24,25(OH)2D observed 2 years after cessation of a 1-year randomised controlled trial (VICtORy RECALL). Osteoporos Int. 2017 Dec;28(12):3361–72. doi: 10.1007/s00198-017-4201-2. PMID: 29331793.28916992
160 Guyatt GH, Oxman AD, Kunz R, . GRADE guidelines 6. Rating the quality of evidence--imprecision. J Clin Epidemiol. 2011 Dec;64(12):1283–93. doi: 10.1016/j.jclinepi.2011.01.012. PMID: 21839614.21839614
161 Atef SH. Vitamin D assays in clinical laboratory: past, present and future challenges. J Steroid Biochem Mol Biol. 2018 Jan;175:136–7. doi: 10.1016/j.jsbmb.2017.02.011. PMID: 28242262.28242262
162 Stokes CS, Lammert F, Volmer DA. Analytical Methods for Quantification of Vitamin D and Implications for Research and Clinical Practice. Anticancer Res. 2018 Feb;38(2):1137–44. doi: 10.21873/anticanres.12332. PMID: 29374750.29374750
163 Sempos CT, Vesper HW, Phinney KW, . Vitamin D status as an international issue: national surveys and the problem of standardization. Scand J Clin Lab Invest Suppl. 2012;243:32–40. doi: 10.3109/00365513.2012.681935. PMID: 22536760.22536760
164 Binkley N, Sempos CT. Standardizing vitamin D assays: the way forward. J Bone Miner Res. 2014 Aug;29(8):1709–14. doi: 10.1002/jbmr.2252. PMID: 24737265.24737265
165 Tai SS, Bedner M, Phinney KW. Development of a candidate reference measurement procedure for the determination of 25-hydroxyvitamin D3 and 25-hydroxyvitamin D2 in human serum using isotope-dilution liquid chromatography-tandem mass spectrometry. Anal Chem. 2010 Mar 1;82(5):1942–8. doi: 10.1021/ac9026862. PMID: 20136128.20136128
166 Burdette CQ, Camara JE, Nalin F, . Establishing an accuracy basis for the vitamin D external quality assessment scheme (DEQAS). J AOAC Int. 2017 Sep 1;100(5):1277–87. doi: 10.5740/jaoacint.17-0306. PMID: 28847346.28847346
167 Wise SA, Phinney KW, Tai SS, . Baseline assessment of 25-hydroxyvitamin D assay performance: a Vitamin D Standardization Program (VDSP) interlaboratory comparison study. J AOAC Int. 2017 Sep 1;100(5):1244–52. doi: 10.5740/jaoacint.17-0258. PMID: 28822355.28822355
168 Stepman HC, Vanderroost A, Van Uytfanghe K, . Candidate reference measurement procedures for serum 25-hydroxyvitamin D3 and 25-hydroxyvitamin D2 by using isotope-dilution liquid chromatography-tandem mass spectrometry. Clin Chem. 2011 Mar;57(3):441–8. doi: 10.1373/clinchem.2010.152553. PMID: 21248072.21248072
169 Cavalier E, Souberbielle JC. Vitamin D and its metabolites: from now and beyond. Ejifcc. 2018 Jul;29(2):105–10. PMID: 30050393.30050393
170 Rabenberg M, Scheidt-Nave C, Busch MA, . Implications of standardization of serum 25-hydroxyvitamin D data for the evaluation of vitamin D status in Germany, including a temporal analysis. BMC Public Health. 2018 Jul 6;18(1):845. doi: 10.1186/s12889-018-5769-y. PMID: 29980236.29980236
171 Binkley N, Dawson-Hughes B, Durazo-Arvizu R, . Vitamin D measurement standardization: the way out of the chaos. J Steroid Biochem Mol Biol. 2017 Oct;173:117–21. doi: 10.1016/j.jsbmb.2016.12.002. PMID: 27979577.27979577
172 Durazo-Arvizu RA, Dawson-Hughes B, Kramer H, . The reverse J-shaped association between serum total 25-hydroxyvitamin D concentration and all-cause mortality: the impact of assay standardization. Am J Epidemiol. 2017 Apr 15;185(8):720–6. doi: 10.1093/aje/kww244. PMID: 28338905.28338905
173 CDC. VDSCP: List of Certified Participants. 2017. https://www.cdc.gov/labstandards/vdscp_participants.html. Accessed 10/1, 2019.
174 Hoofnagle AN, Eckfeldt JH, Lutsey PL. Vitamin D-binding protein concentrations quantified by mass spectrometry. N Engl J Med. 2015 Oct 8;373(15):1480–2. doi: 10.1056/NEJMc1502602. PMID: 26397952.26397952
175 Powe CE, Evans MK, Wenger J, . Vitamin D-binding protein and vitamin D status of black Americans and white Americans. N Engl J Med. 2013 Nov 21;369(21):1991–2000. doi: 10.1056/NEJMoa1306357. PMID: 24256378.24256378
176 Tryfonidou MA, Oosterlaken-Dijksterhuis MA, Mol JA, . 24-Hydroxylase: potential key regulator in hypervitaminosis D3 in growing dogs. Am J Physiol Endocrinol Metab. 2003 Mar;284(3):E505–13. doi: 10.1152/ajpendo.00236.2002. PMID: 12441310.12441310
177 Ginsberg C, Katz R, de Boer IH, . The 24,25 to 25-hydroxyvitamin D ratio and fracture risk in older adults: The cardiovascular health study. Bone. 2018 Feb;107:124–30. doi: 10.1016/j.bone.2017.11.011. PMID: 29155243.29155243
178 Berg AH, Powe CE, Evans MK, . 24,25-Dihydroxyvitamin d3 and vitamin D status of community-dwelling black and white Americans. Clin Chem. 2015 Jun;61(6):877–84. doi: 10.1373/clinchem.2015.240051. PMID: 25922442.25922442
179 Gaksch M, Jorde R, Grimnes G, . Vitamin D and mortality: individual participant data meta-analysis of standardized 25-hydroxyvitamin D in 26916 individuals from a European consortium. PLoS One. 2017;12(2):e0170791. doi: 10.1371/journal.pone.0170791. PMID: 28216561.28207791
180 Schottker B, Jorde R, Peasey A, . Vitamin D and mortality: meta-analysis of individual participant data from a large consortium of cohort studies from Europe and the United States. BMJ. 2014 Jun 17;348:g3656. doi: 10.1136/bmj.g3656. PMID: 23232064.24938302
181 Rush L, McCartney G, Walsh D, . Vitamin D and subsequent all-age and premature mortality: a systematic review. BMC Public Health. 2013 Jul 24;13:679. doi: 10.1186/1471-2458-13-679. PMID: 23314982.23883271
182 van den Berg KS, Marijnissen RM, van den Brink RH, . Vitamin D deficiency, depression course and mortality: longitudinal results from the Netherlands Study on Depression in Older persons (NESDO). J Psychosom Res. 2016 Apr;83:50–6. doi: 10.1016/j.jpsychores.2016.03.004. PMID: 26829443.27020077
183 Brenner H, Jansen L, Saum KU, . Vitamin D supplementation trials aimed at reducing mortality have much higher power when focusing on people with low serum 25-hydroxyvitamin D concentrations. J Nutr. 2017 Jul;147(7):1325–33. doi: 10.3945/jn.117.250191. PMID: 28468770.28539415
184 Schmutz EA, Zimmermann MB, Rohrmann S. The inverse association between serum 25-hydroxyvitamin D and mortality may be modified by vitamin A status and use of vitamin A supplements. Eur J Nutr. 2016 Feb;55(1):393–402. doi: 10.1007/s00394-015-0860-y. PMID: 25694350.25701092
185 Tomson J, Emberson J, Hill M, . Vitamin D and risk of death from vascular and non-vascular causes in the Whitehall study and meta-analyses of 12,000 deaths. Eur Heart J. 2013 May;34(18):1365–74. doi: 10.1093/eurheartj/ehs426. PMID: 24124339.23257953
186 Swanson CM, Srikanth P, Lee CG, . Associations of 25-Hydroxyvitamin D and 1,25-Dihydroxyvitamin D with bone mineral density, bone mineral density change, and incident nonvertebral fracture. J Bone Miner Res. 2015 Aug;30(8):1403–13. doi: 10.1002/jbmr.2487. PMID: 25734582.25707402
187 Annweiler C, Beauchet O. Questioning vitamin D status of elderly fallers and nonfallers: a meta-analysis to address a ‘forgotten step’. J Intern Med. 2015 Jan;277(1):16–44. doi: 10.1111/joim.12250. PMID: 29702603.24697944
188 Zhang R, Li B, Gao X, . Serum 25-hydroxyvitamin D and the risk of cardiovascular disease: dose-response meta-analysis of prospective studies. Am J Clin Nutr. 2017 Apr;105(4):810–9. doi: 10.3945/ajcn.116.140392. PMID: 27287826.28251933
189 Bajaj A, Stone KL, Peters K, . Circulating vitamin D, supplement use, and cardiovascular disease risk: the MrOS Sleep Study. J Clin Endocrinol Metab. 2014 Sep;99(9):3256–62. doi: 10.1210/jc.2013-4178. PMID: 25038058.24670083
190 Brondum-Jacobsen P, Nordestgaard BG, Schnohr P, . 25-hydroxyvitamin D and symptomatic ischemic stroke: an original study and meta-analysis. Ann Neurol. 2013 Jan;73(1):38–47. doi: 10.1002/ana.23738. PMID: 24026893.23225498
191 Alonso A, Misialek JR, Michos ED, . Serum 25-hydroxyvitamin D and the incidence of atrial fibrillation: the Atherosclerosis Risk in Communities (ARIC) study. Europace. 2016 Aug;18(8):1143–9. doi: 10.1093/europace/euv395. PMID: 26797718.26847078
192 Daraghmeh AH, Bertoia ML, Al-Qadi MO, . Evidence for the vitamin D hypothesis: the NHANES III extended mortality follow-up. Atherosclerosis. 2016 Dec;255:96–101. doi: 10.1016/j.atherosclerosis.2016.04.007. PMID: 27733394.27855294
193 Afzal S, Bojesen SE, Nordestgaard BG. Low 25-hydroxyvitamin D and risk of type 2 diabetes: a prospective cohort study and metaanalysis. Clin Chem. 2013 Feb;59(2):381–91. doi: 10.1373/clinchem.2012.193003. PMID: 25089537.23232064
194 Schottker B, Herder C, Rothenbacher D, . Serum 25-hydroxyvitamin D levels and incident diabetes mellitus type 2: a competing risk analysis in a large population-based cohort of older adults. Eur J Epidemiol. 2013 Mar;28(3):267–75. doi: 10.1007/s10654-013-9769-z. PMID: 23168298.23354985
195 Goodwill AM, Szoeke C. A systematic review and meta-analysis of the effect of low vitamin D on cognition. J Am Geriatr Soc. 2017 Oct;65(10):2161–8. doi: 10.1111/jgs.15012. PMID: 28549923.28758188
196 Beydoun MA, Hossain S, Fanelli-Kuczmarski MT, . Vitamin D status and intakes and their association with cognitive trajectory in a longitudinal study of urban adults. J Clin Endocrinol Metab. 2018 Apr 1;103(4):1654–68. doi: 10.1210/jc.2017-02462. PMID: 29490621.29409006
197 Maddock J, Geoffroy MC, Power C, . 25-Hydroxyvitamin D and cognitive performance in mid-life. Br J Nutr. 2014 Mar 14;111(5):904–14. doi: 10.1017/s0007114513003176. PMID: 25006678.24135155
198 Overman MJ, Pendleton N, O’Neill TW, . Evaluation of cognitive subdomains, 25-hydroxyvitamin D, and 1,25-dihydroxyvitamin D in the European Male Ageing Study. Eur J Nutr. 2017 Sep;56(6):2093–103. doi: 10.1007/s00394-016-1247-4. PMID: 27798247.27370643
199 Olsson E, Byberg L, Karlstrom B, . Vitamin D is not associated with incident dementia or cognitive impairment: an 18-y follow-up study in community-living old men. Am J Clin Nutr. 2017 Apr;105(4):936–43. doi: 10.3945/ajcn.116.141531. PMID: 28146321.28202477
200 Sadeghian M, Saneei P, Siassi F, . Vitamin D status in relation to Crohn’s disease: meta-analysis of observational studies. Nutrition. 2016 May;32(5):505–14. doi: 10.1016/j.nut.2015.11.008. PMID: 26156737.26837598
201 Ramagopalan SV, Goldacre R, Disanto G, . Hospital admissions for vitamin D related conditions and subsequent immune-mediated disease: record-linkage studies. BMC Med. 2013 Jul 25;11:171. doi: 10.1186/1741-7015-11-171. PMID: 23723170.23885887
202 Robertsen S, Grimnes G, Melbye H. Association between serum 25-hydroxyvitamin D concentration and symptoms of respiratory tract infection in a Norwegian population: the Tromso Study. Public Health Nutr. 2014 Apr;17(4):780–6. doi: 10.1017/s1368980013001134. PMID: 24327720.23659381
203 Deschasaux M, Souberbielle JC, Latino-Martel P, . A prospective study of plasma 25-hydroxyvitamin D concentration and prostate cancer risk. Br J Nutr. 2016 Jan 28;115(2):305–14. doi: 10.1017/s0007114515004353. PMID: 26282062.26568368
204 Schenk JM, Till CA, Tangen CM, . Serum 25-hydroxyvitamin D concentrations and risk of prostate cancer: results from the Prostate Cancer Prevention Trial. Cancer Epidemiol Biomarkers Prev. 2014 Aug;23(8):1484–93. doi: 10.1158/1055-9965.Epi-13-1340. PMID: 24732629.25085836
205 Chandler PD, Buring JE, Manson JE, . Circulating vitamin D levels and risk of colorectal cancer in women. Cancer Prev Res (Phila). 2015 Aug;8(8):675–82. doi: 10.1158/1940-6207.Capr-14-0470. PMID: 28486474.25813525
206 Deschasaux M, Souberbielle JC, Latino-Martel P, . Weight status and alcohol intake modify the association between vitamin D and breast cancer risk. J Nutr. 2016 Mar;146(3):576–85. doi: 10.3945/jn.115.221481. PMID: 28630081.26817718
207 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001 Apr;20(3 Suppl):21–35. PMID: 11306229.11306229
208 Berlin T, Emtestam L, Björkhem I. Studies on the relationship between vitamin D3 status and urinary excretion of calcium in healthy subjects: effects of increased levels of 25-hydroxyvitamin D3. Scand J Clin Lab Invest. 1986;46(8):723–9.3026026
209 Oliveri B, Mastaglia SR, Brito GM, . Vitamin D3 seems more appropriate than D2 to sustain adequate levels of 25OHD: a pharmacokinetic approach. Eur J Clin Nutr. 2015 Jun;69(6):697–702. doi: 10.1038/ejcn.2015.16. PMID: 25987791.25782422
210 Osmancevic A, Demeke T, Gillstedt M, . Vitamin D treatment in Somali women living in Sweden-two randomized, placebo-controlled studies. Clin Endocrinol (Oxf). 2016 Oct;85(4):535–43. doi: 10.1111/cen.13097. PMID: 26696653.27155232
211 Battaggia A, Donzelli A, Font M. Effects of proprotein convertase subtilisin/kexin type 9 antibodies in adults with hypercholesterolemia. Ann Intern Med. 2015 Aug 4;163(3):241–2. doi: 10.7326/l15-5118-2. PMID: 26237758.26237758