# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Howard Tracer, MD, AHRQ Medical Officer; Tracy Wolff, MD, MPH, Scientific Director, USPSTF Division, AHRQ; current members of the U.S. Preventive Services Task Force; expert peer reviewers: John Aloia, MD, New York University Winthrop Bone Mineral Research Center; JoAnn E. Manson, MD, MPH, DrPH, Harvard Medical School; Clifford Rosen, MD, Maine Medical Center Research Institute; and Christopher Sempos, PhD, Vitamin D Standardization Program, LLC; National Cancer Institute and Office of Dietary Supplements of the National Institutes of Health, and Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion Federal partner reviewers; and RTI International–University of North Carolina EPC staff: Carol Woodell, BSPH, EPC Program Manager; B. Lynn Whitener, DrPH, librarian; Sharon Barrell, MA, editor; Jennifer Schoden, BA, research analyst; and Loraine Monroe, publications specialist.