# Chapter 4 Discussion

## Summary of Evidence

We identified no direct evidence evaluating the benefits (KQ 1) or harms (KQ 2) of screening for vitamin D deficiency. We did identify evidence addressing the benefits and harms of treatment with vitamin D in deficient persons (KQ 3, KQ 4); however, the evidence for variation in effectiveness of benefits or harms by specific subgroups was limited. Table 3 summarizes the evidence synthesized in this report by KQ and provides our EPC’s assessment of the SOE.

Table 3 Summary of Evidence

Key Question | No. of Studies; Study Designs; No. of Participants | Summary of Findings | Consistency and Precision | Other Limitations | Strength of Evidence | Applicability
KQ 3 Mortality | 8 RCTs^50,^ ^70,^ ^74,^ ^82,^ ^84,^ ^89,^ ^93,^ ^95^; 2,006 participants; 1 nested CC^80^; 2,285 participants | Among community-dwelling populations, pooled ARD from RCTs 0.3% (95% CI, −0.6% to 1.1%; I^2^=0%).; Nested CC consistent with findings from RCTs. | Consistent, precise^*^ | Five of the RCTs were fair quality, mortality was not a primary outcome in any study, ascertainment of mortality was heterogenous across studies, followup was of short duration in some studies (particularly considering populations were relatively healthy at the start of study), and mortality events were rare in most studies. | Moderate for no benefit | Studies included community-dwelling males and females, applicable to various doses of vitamin D with or without calcium.
KQ 3 Any Fractures | 6 RCTs^70,^ ^71,^ ^73,^ ^74,^ ^85,^ ^86^; 2,186 participants; 1 nested CC^80^; 2,982 participants | Among community-dwelling populations: Pooled ARD from RCTs −0.3% (95% CI, −2.1% to 1.6%; I^2^=13.0%).; Nested CC consistent with findings from the RCTs. | Consistent, precise^†^ | Five of the RCTs were fair quality; type of fracture and methods of ascertainment heterogenous across studies and, in some cases, based on self-report without verification. | Moderate for no benefit | Community-dwelling populations, all but two studies were conducted among female and male populations, applicable to various doses of vitamin D with or without calcium.
KQ 3 Hip Fractures | 4 RCTs^86–88,^ ^91^; 3,349 participants; 1 nested CC^80^; 714 participants | Pooled ARD from 3 RCTs −0.86% (95% CI, −3.5% to 1.8%; I^2^=47.4%).; Nested CC consistent with findings from the RCTs. | Consistent, imprecise^ǂ^ | All studies were fair quality, outcome ascertainment methods variable across studies. | Low for no benefit | Two of the studies were conducted in institutionalized populations; two of the studies were conducted exclusively in women; mean age 75-85 in the studies. Applicable to various doses of vitamin D with or without calcium.
KQ 3 Falls | Incidence of one or more falls: 6 RCTs^73,^ ^74,^ ^79,^ ^85,^ ^86,^ ^93^; 2,633 participants; Incidence of two or more falls: 1 RCT^72,^ ^97^ (subgroup N NR); Total number of falls:; 5 RCTs^70,^ ^85,^ ^86,^ ^93,^ ^94^; 2,838 person-years | Among community-dwelling populations:; Incidence of one or more falls:; Pooled ARD −4.3% (95% CI, −11.6% to 2.9%; I^2^=70.1%).; Incidence of two or more falls (1 RCT); Adjusted OR, 1.03 (95% CI, 0.59 to 1.79) for participants with vitamin D level <12 ng/ml; Adjusted OR, 1.13 (95% CI, 0.87 to 1.48) for participants with vitamin D level between >12 ng/ml and ≤20 ng/ml.; Total number of falls:; Pooled IRD −0.10 falls per person-year (95% CI, −0.19 to −0.002; I^2^=76.9%). | Inconsistent,^§^ imprecise^ǁ^ | Most studies were fair quality, outcome ascertainment methods were variable across studies, potential for selective outcome reporting (total falls vs. incidence of falls). | Low for no benefit | Community-dwelling populations; studies were predominantly in females but some included males; applicable to various doses of vitamin D with or without calcium.
KQ 3 Diabetes | 5 RCTs^75–77,^ ^80,^ ^94,^ ^98^; 3,356 participants | Pooled ARD 0.1% (95% CI, −1.3% to 1.6%; I^2^=0%). | Consistent, precise^¶^ | One good quality and four fair quality (two were planned subgroup analyses and one was unplanned), diabetes captured as an adverse event in one study (criteria and methods of ascertainment NR). | Moderate for no benefit | Four studies included males and females and all were community-dwelling, three studies included participants with prediabetes, impaired fasting glucose, or intolerance. Applicable to various doses of vitamin D with or without calcium.
KQ 3 Cardiovascular | 2 RCTs^72,^ ^73,^ ^99^; 3,271 subgroup participants | No difference in cardiovascular events between treatment and control groups were observed in either trial over a 3- to 5-year followup (VITAL RR, 1.09 [95% CI, 0.68 to 1.76], ViDA (NZ), 1.00 [95% CI, 0.74 to 1.35]). | Consistent, imprecise^#^ | Findings from both good-quality RCTs were from planned subgroup analyses, a broad definition of CVD events was used by one of the trials. | Moderate for no benefit | Both RCTs included males and females, all were community-dwelling populations, uncertain applicability to participants with preexisting cardiovascular disease, applicable to use of vitamin D without calcium.
KQ 3 Cancer | 2 RCTs^72,^ ^100^; 3,271 subgroup participants; 1 nested CC^80,^ ^101,^ ^102^; 1,201 participants | No difference in incident cancer (HR, 0.97 and 1.01 in the 2 RCTs), no significant association between active treatment exposure and incident breast or colorectal cancer in CC study. | Consistent, imprecise^**^ | Findings from both good-quality RCT were from planned subgroup analysis, nested CC study was fair quality. | Moderate for no benefit | The RCTs included both males and females, the nested CC only included females, applicable to participants without a prior history of cancer, applicable to use of vitamin D with or without calcium.
KQ 3 Depression | 3 RCTs^72,^ ^78,^ ^81,^ ^103^; 1,993 participants | No difference between active treatment and control groups on validated measures of depression in any study. | Consistent, imprecise^††^ | Two good-quality RCTs (one with subgroup findings) and one fair quality RCT, duration of intervention was 12 weeks, with measurement at 26 weeks in one study, 16 weeks in one study, and a median of 5.3 years in one study; unclear whether study enrolled participants with prevalent depression in two of the three RCTs. | Low for no benefit | RCTs included males and females, findings not applicable to patients with serious depression, applicable to use of vitamin D without calcium.
KQ 3 Physical Functioning | 2 RCTs^70,^ ^83^; 320 participants | One trial showed small, but statistically significant improvement on the fibromyalgia impact questionnaire at 8 weeks for active treatment group compared with control, the other trial showed no difference in change on the modified Stanford Health Assessment Questionnaire after 1 year. | Inconsistent, imprecise^††^ | One good-quality RCT, the fair quality RCT had differential attrition and unclear randomization and allocation concealment methods and was only conducted over 8 weeks, different measures used by the two trials. | Insufficient | One of the trials included both males and females, the other trial only included females, both studies conducted at single centers, applicable to use of vitamin D without calcium.
KQ 3 Infection | 1 RCT^75,^ ^144^; 173 subgroup participants | Lower incidence of urinary tract infection over 5 years for active treatment compared with control group (HR, 0.53; 95% CI, 0.17 to 1.64). | Consistency cannot be evaluated (single study body of evidence); Imprecise^††^ | Unplanned subgroup analysis from a fair-quality RCT with possible selective outcome reporting. | Insufficient | Study included both men and women, all had prediabetes.
KQ 4 Total Adverse Events | 24 RCTs; 3,938 participants | Incidence was similar between active treatment and control groups. | Consistent, imprecise^††^ | Five good-quality studies, the rest were fair quality. Methods of ascertainment varied greatly among studies likely leading to widely differing estimates of incidence. | Low for no harm | Studies included males and females, most of the evidence was from community-dwelling populations, applies to various doses of vitamin D with or without calcium.
KQ 4 Serious Adverse Events | 16 RCTs; 3,912 participants | Incidence was similar between active treatment and control groups. | Consistent, imprecise^††^ | Five good-quality studies, the rest were fair quality. Definitions of serious adverse events and methods of ascertainment varied greatly among studies likely leading to widely differing estimates of incidence. | Low for no harm | Studies included males and females, most of the evidence was from community-dwelling populations, applies to various doses of vitamin D with or without calcium.
KQ 4 Discontinuations due to Adverse Events | 7 RCTs; 1,677 participants | Incidence reported and was similar between active treatment and control groups. | Consistent, imprecise^††^ | One good-quality study, the rest were fair-quality. Methods of ascertaining adverse events varied greatly among studies likely leading to widely differing estimates of discontinuations. | Low for no harm | All but three studies conducted exclusively in females, most of the evidence was from community-dwelling populations, applies to vitamin D with or without calcium.
KQ 4 Kidney Stones | 10 RCTs; 2,120 participants | Only one event reported in the low-dose vitamin D group in one study. | Consistent, imprecise^††^ | Two good-quality studies, the rest were fair quality. Most studies did not report how this outcome was ascertained. | Low for no harm | Most of the evidence was from female community-dwelling populations, applies to various doses of vitamin D with or without calcium.
KQ 4 Other Harms | 5 RCTs; 1,459 participants | No difference between active treatment and control groups for various other specific harms reported (e.g., specific GI side effects). | Consistent, imprecise^††^ | Two good-quality studies, the rest were fair quality. Most studies did not report how these outcomes were ascertained, potential for selective outcome reporting (nonstandardized selection of outcomes and various approaches to reporting used). | Low for no harm | All but one study was conducted exclusively in females, applies to both community-dwelling and institutionalized populations, applies to various doses of vitamin D with or without calcium.

* Although this estimate could be considered imprecise based on strict interpretation of optimal information size criteria, the event rates were very low, resulting in excessively wide CIs around the relative effect measure, which was 1.13 (95% CI, 0.39 to 3.28). Because of this, we prioritized evaluation of the ARD and determined that the CI was precise enough to exclude a clinically meaningful benefit or harm. This approach is consistent with current GRADE recommendations for assessing precision.^160^

† The pooled RR was 0.84 (9% CI, 0.58 to 1.21); although this estimate could be considered imprecise based on strict interpretation of optimal information size criteria, we prioritized evaluation of the ARD and determined that the confidence interval was precise enough to exclude a clinically meaningful absolute benefit or harm. This approach is consistent with current GRADE recommendations for assessing precision.^160^

ǂ The pooled RR was 0.86 (95% CI, 0.50 to 1.47). Required sample size would be 13,658 assuming 5% control group risk, 80% power, alpha=0.05 for detecting effect size of RR 0.8.

§ Findings are inconsistent between outcomes (incidence of one or more falls vs. total falls). For incidence of falls, two studies among community-dwelling populations both conducted by the same author showed a larger beneficial effect compared with the other three studies that had findings close to and on both sides of the null effect. The RCT using a more stringent definition of falls (two or more) also showed no association even among participants with the lowest of vitamin D levels (<12 ng/ml); however, these estimates were imprecise. For total falls, a small, statistically significant benefit of treatment was observed among community-dwelling populations.

ǁ Required sample size 834 for RR, 0.8; control risk 50%, so OIS criteria are met, but CI does not exclude the null and the 95% CI cannot rule out a clinically meaningful effect.

¶ Required sample size 2,944 for RR, 0.8; control risk 20%, so OIS criteria are met. Pooled RR, 0.96 (95% CI, 0.80 to 1.15); however, CIs around ARD exclude a clinically meaningful effect.

# Required sample size 9,920, 7% control risk, 0.8 RR, alpha= 0.05. Data to calculate ARD not provided; cannot exclude a clinically meaningful treatment effect based on the RR alone.

** Required sample size 11,476, 6% control risk, 0.8 RR, alpha= 0.05 in order to meet OIS criteria. Data not provided in order to calculate ARDs.

†† OIS criteria will vary depending on outcome used but sample size combined with rare events means that OIS criteria are unlikely to be met.

Abbreviations: ARD=absolute risk difference; CC=case-control; CI=confidence interval; CVD=cardiovascular disease; GI=gastrointestinal; HR=hazard ratio; IRD=incidence rate difference; IRR=incidence rate ratio; KQ=key question; No.=number; NR=not reported; OIS=optimal information size; RCT=randomized, controlled trials; RR=relative risk; SAE=serious adverse event; ViDA (NZ)=Vitamin D Assessment Study; VITAL= VITamin D and OmegA-3 TriaL.

### Benefits of Treatment (Key Question 3)

Among community-dwelling populations, we assessed the SOE as moderate for no benefit for mortality, any fractures, incident diabetes, cardiovascular disease, and incident cancer. For these outcomes, we downgraded the SOE for study limitations or imprecision. We assessed the evidence as low for no benefit for hip fractures and depression and downgraded these bodies of evidence for study limitations and imprecision. We assessed the SOE for falls as low for no benefit; we downgraded the SOE because of inconsistency between the various fall measures (incidence vs. total falls) and for imprecision in effect estimates. We assessed the SOE for physical functioning, and infection as insufficient because of inconsistency, imprecision, and study limitations.

Despite a reasonable number of studies reporting on the incidence of falls, the body of evidence demonstrated somewhat inconsistent findings. Among the studies reporting the incidence of one or more falls, a numerical but not statistically significant decrease (ARD −4.3%) was observed among community-dwelling populations. The most recent good-quality trial reported the incidence of two or more falls among subgroups of participants with vitamin D levels less than 20 ng/ml and less than 12 ng/ml and found no association, though effect estimates were imprecise. Among the studies reporting total number of falls, a small but statistically significant decrease (−0.1 falls per person-year) in the total number of falls was observed. Estimates for both types of outcomes were inconsistent and imprecise. Some studies reported both outcomes, but others only reported one of these outcomes, raising the possibility of selective outcome reporting. One hypothesis to explain the difference between these two outcomes is that although vitamin D may not prevent a first fall, it may have some benefit in preventing repeat falls. However, a related systematic review on behalf of the USPSTF’s recommendation for fall prevention in community-dwelling populations at increased risk of falls found mixed findings for vitamin D interventions.^123^ There was also evidence of possible harms from high-dose vitamin D in such populations, resulting in a recommendation against vitamin D supplementation in community-dwelling adults age 65 years or older.^123,^ ^124^ The falls prevention review excluded studies conducted among vitamin D–deficient populations. Overall, the evidence suggests no benefit on incidence of falls, but a small beneficial effect on recurrent falls cannot be ruled out.

Findings regarding benefits of treatment in this review are not directly comparable with other reviews of vitamin D supplementation because this review was focused specifically on adults with low levels of vitamin D that would place them at risk for deficiency. Despite this key difference, the findings from this review are largely consistent with findings from other reviews conducted in broader populations with respect to most outcomes. One exception to this deserves mention. Several meta-analyses have specifically focused on the effect of vitamin D supplementation on both incident cancer and cancer mortality.^125–128^ These analyses do not all include the same set of studies, but all suggest no effect on cancer incidence. However, three^125–127^ of the four analyses suggest a small favorable effect of vitamin D supplementation on cancer deaths. Authors of these analyses cannot precisely identify the reason for the divergence between cancer incidence and mortality outcome but offer several biological theories that will require further research to fully elucidate.

### Harms of Treatment (Key Question 4)

We assessed the SOE as low for no harm for total adverse events, serious adverse events, discontinuations due to adverse events, kidney stones, and other harms. We downgraded the SOE for these outcomes because of imprecision and study limitations. Although studies were consistent in demonstrating no difference in harms between active treatment and control groups, the absolute incidence of reported adverse events varied vastly across studies. This is likely because of different approaches to defining and ascertaining these outcomes across the studies. Some studies proactively inquired about adverse events at regular, periodic study visits, while others relied on voluntary patient self-report of adverse events, while many studies provided no information about how these outcomes were ascertained.

## Limitations

### Limitations of the Evidence

We found no available evidence that directly evaluated the health benefits and harms of screening (KQs 1 and 2); thus, we could only assess the evidence related to the treatment of vitamin D deficiency (KQs 3 and 4). The doses and duration of treatment varied widely across this body of evidence as did the use of calcium as part of the treatment intervention or in both the treatment and control groups. The level used to define vitamin D deficiency varied across studies; however, our analyses suggest no impact of using a lower threshold (less than 20 ng/ml) as compared with using a higher threshold (less than 30 ng/ml) on the effect of treatment.

The use of standard outcome definitions and methods of ascertainment varies widely across studies, likely reflecting the fact that vitamin D is not regulated as a prescription drug. This fact affects how studies are designed, conducted, and reported, including less rigorous and transparent methodology and incomplete reporting, particularly for older studies. We note that more recently conducted studies appear to be of higher quality and/or have better reporting. For many outcomes, the followup time periods used by studies may not have been long enough to demonstrate an effect. Results from some studies were reported based on subgroup analyses, some of which were not prespecified. Of note, two of the large trials that were included for KQ 3 (benefits of treatment) because they examined health outcomes in prespecified subgroups with low vitamin D levels did not present data on harms by subgroup and thus could not be formally included for KQ 4 (harms of treatment).^72,^ ^77^ However, we note that the data on harms reported on the overall population in these two studies are similar to the findings from studies included for KQ 4 (i.e.., no difference between treatment and placebo groups). One of these trials (VITAL) also reported findings from the overall trial (not limited to vitamin D–deficient subgroup) stratified by subgroups. In these analyses, study authors reported no interaction between age, sex, or race and incident cancer of major cardiovascular events.^72^ A significant interaction was observed for BMI for incident cancer; fewer cases of incident cancer were observed among participants with BMI less than 25 for treatment with vitamin D compared with placebo. This effect was not observed among participants with BMI 25 to less than 30 or BMI greater than or equal to 30.

We identified few to no trials for some outcomes specified in our research plan, and few studies reported outcomes for prespecified patient subgroups of interest. Lastly, we did not have enough studies to evaluate the impact of different doses on benefits and harms, specifically the impact of intermittent, high doses of vitamin D, as some evidence has suggested adverse effects of high dose, intermittent regimens in studies that are not included in the scope of this review, specifically studies comparing low to high doses of vitamin D^43,^ ^51^ and studies in populations not defined based on deficiency.^42,^ ^44^ Two of the studies included in this review used a single, high-dose regimen (100,000 IU and 250,000 IU one time) but did not report any difference in total adverse effects between active treatment and control groups.^114,^ ^119^

### Limitations of the Review

We limited this review to English-language studies conducted in very highly developed countries. We selected studies in this review to include vitamin D–deficient populations, including those in institutionalized settings. However, our synthesis and SOE assessment focused mainly on community-dwelling populations because USPSTF recommendations focus on clinical preventive services in or referred from primary care settings. Studies focused on populations with a specific clinical condition to evaluate the treatment of vitamin D deficiency for the alleviation of specific symptoms or issues associated with that condition were not included (e.g., infertility, asthma). We did not assess the comparative benefits or harms of various vitamin D doses, formulations, or durations of treatment. This review included studies that enrolled participants based on 25(OH)D levels that used various assays and that may not have been standardized according to current criteria from the VDSP; it is uncertain whether findings would be different had all studies used standardized testing.

The treatment key questions of this review focused on asymptomatic populations known to have low serum vitamin D levels, typically less than 20 or 30 ng/ml. For the trials enrolling participants unselected with respect to vitamin D status, we only reported findings from the vitamin D–deficient subgroups. We did not include findings from the overall population, but these would likely be eligible to be included in the next update of a related review of vitamin D supplementation conducted on behalf of the USPSTF.^60^ We also note that findings from this review may not be directly comparable to other reviews of Vitamin D interventions because of differences in eligible study populations, interventions, and settings. For example, two recent meta-analyses evaluating vitamin D supplementation on the incidence of diabetes among normoglycemic and prediabetic populations reported findings suggestive of a small clinical benefit among some subgroups.^129,^ ^130^ However, these analyses were not limited to vitamin D deficient populations, included studies evaluating vitamin D analogs, or were conducted countries not considered as very highly developed per the UN Human Development Index.^64^

Consistent with USPSTF methods, this review focused on health outcomes and did not systematically evaluate asymptomatic benefits (e.g., effects on intermediate cardiovascular or metabolic measures) or harms (e.g., hypercalcemia, hypercalciuria, or nephrocalcinosis), yet few studies designated hard health outcomes as the primary study aim or powered their designs based on such outcomes. Further, some findings were reported after followup times that might not be long enough to demonstrate an impact on mortality and chronic disease outcomes such as diabetes, cancer, and cardiovascular events. Findings from RCTs related to the effect of vitamin D treatment on intermediate measures of health are summarized in Contextual Question 3 in Appendix A. Overall, there appears to be no relationship between treatment with vitamin D and intermediate outcomes such as bone mineral density, muscle/physical strength, blood pressure, fasting glucose of HgbA1C, cholesterol, weight or BMI, or precancerous outcomes (e.g., adenoma). In terms of asymptomatic harms, findings from a 2014 AHRQ Effective Health Care Review suggest sporadic cases of hypercalcemia or hypercalciuria in RCTs of vitamin D supplementation; however, these reviews were not limited to vitamin D–deficient populations.^22^ Two other reviews also not conducted solely among vitamin D–deficient populations also suggest increased risk for hypercalcemia and hypercalciruia but without any increased risk for kidney stones.^131,^ ^132^ A 2014 Cochrane review of vitamin D or vitamin D analogues with or without calcium to prevent fractures in postmenopausal women or older men described an increased risk for mild hypercalcemia (pooled RR, 2.28 [95% CI, 1.57 to 3.31]; 21 RCTs; 17,124 participants).^133^ This Cochrane review was also not limited to vitamin D–deficient populations.

Lastly, the search dates covered by this review were prior to the emergence of the COVID-19 pandemic. Since then, epidemiologic studies have been published exploring the relationship between vitamin D level and severity of COVID-19 illness or deaths from COVID-19, leading some to call for treatment with vitamin D to reduce severity and complications from COVID-19. However, there is overlap between groups at high risk for vitamin D deficiency and groups at high risk of severe COVID-19 illness.^134^ The UK National Institute for Health and Care Excellence issued an advisory statement in June 2020 stating there is no evidence to support taking vitamin D supplements specifically to prevent or treat COVID-19.^135^ Numerous trials are now ongoing to determine the impact of vitamin D on SARS-CoV-2 infection and COVID-19 complications.

## Future Research Needs

Over the past two decades, increased recognition of the possible consequences of low vitamin D levels has resulted in increased vitamin D level screening in routine practice among community-dwelling persons,^61–63^ despite no direct evidence of benefits or harms of this practice. Despite increasing standardization of vitamin D assays for measuring serum levels, the precise serum level at which any given individual is deficient may vary, and debate continues on what level should be considered as defining deficiency and whether additional markers should be used to augment the assessment for deficiency. Even if it is possible to screen and detect asymptomatic deficiency, it is not clear from the current evidence that a benefit of treatment exists for deficiency as defined by serum levels less than 20 ng/ml or less than 30 ng/ml. Future RCTs that randomize general populations of community-dwelling adults to either vitamin D screening or no screening would be needed to directly determine the benefits and harms of screening for vitamin D deficiency. In the absence of this direct evidence, rigorously designed and adequately powered placebo-controlled trials of treatment specifically in vitamin D–deficient populations would be needed to clarify the impact of vitamin D on some outcomes for which the current evidence is insufficient (e.g., infections, physical functioning, other outcomes) or where additional clarity is needed (e.g., falls) to determine optimal doses and regimens for benefits, to clarify potential harms from intermittent high dose regimens, and to further elucidate differential effects among patient subgroups (e.g., sex, race/ethnicity). Despite evidence for clinical equipoise of treatment and placebo for many outcomes, it is not clear whether conducting placebo-controlled trials would be feasible given the already widespread practice of treating asymptomatic low vitamin D levels.

## Conclusions

No studies have evaluated the direct benefit or harms of screening for vitamin D deficiency. Among asymptomatic, community-dwelling populations with low vitamin D levels, the evidence suggests that treatment with vitamin D (with or without calcium) has no effect on mortality or the incidence of fractures, falls, depression, diabetes, cardiovascular disease, cancer, or adverse events. The evidence is inconclusive about the impact of treatment on physical functioning and infection.