# Chapter 3 Results

We screened 1,618 titles and abstracts and 213 full-text articles and identified 46 studies from 77 publications for inclusion (Figure 2). The list of articles excluded during full-text review is in Appendix C. We did not identify any direct evidence for benefits (KQ 1) or harms (KQ 2) of screening. We identified 27 studies reporting on the benefits of treatment (KQ 3); ten of these studies are new to this update. We identified 36 studies reporting on the harms of treatment (KQ 4); 17 of these studies are new to this update.

Figure 2 Literature Flow Diagram for Systematic Review of Screening for Vitamin D Deficiency in Adults

Abbreviation: KQ=key question.

Figure 2 is titled “Literature Flow Diagram for Systematic Review of Screening for Vitamin D Deficiency in Adults.” This figure is a flow chart that summarizes the search and selection of articles. We identified 1,594 records through electronic database searches and 24 records by other sources, including hand search for screening at the title and abstract level. This resulted in a total of 1,618 titles and abstracts screened. Additionally, 36 articles (28 studies) were included from the previous review. Resulting in a total of 213 articles assessed for eligibility at full-text review. After full-text review, 136 were excluded: 11 that were systematic reviews that we used for hand search, 12 for ineligible publication type, 14 for ineligible country, 37 for ineligible population, 3 for ineligible screening/intervention, 2 for ineligible or no comparator, 30 for ineligible or no outcome, 7 for ineligible study design, 6 for being a duplicate or outdated (more recent data were available), 8 for being a study protocol or in progress, 1 for abstract only, 0 for ineligible language/non-English, 4 for poor quality, and 1 for other reasons. Seventy-seven articles representing 46 studies were included in the synthesis of the systematic review. No studies were identified for KQ 1 or KQ 2. Twenty-seven studies in 46 articles were identified for KQ 3. Ten of these studies were new, and 17 were from the previous review. Thirty-six studies in 52 articles were identified for KQ 4. 17 of these were new and 19 were from the previous review.

## Benefits of Screening (Key Question 1)

We did not identify any studies that evaluated the benefits of screening for vitamin D deficiency.

## Harms of Screening (Key Question 2)

We did not identify any studies that evaluated the harms of screening for vitamin D deficiency.

## Benefits of Treatment (Key Question 3)

We identified 46 publications describing the results from 26 RCTs and one nested case-control study from the Women’s Health Initiative (WHI) Calcium-Vitamin D RCT. Ten RCTs were new since the 2014 evidence report. Included studies reported on the effect of various doses of vitamin D with or without calcium compared with a control group across a range of health outcomes. Key findings are the following:

- Among community-dwelling participants with low vitamin D levels (i.e., less than 20 or 30 ng/ml), treatment with vitamin D, with or without calcium, likely has no association with mortality; fractures; and the incidence of diabetes, cardiovascular disease, cancer, or depression compared with control.
- Among community-dwelling participants, treatment with vitamin D with or without calcium likely has no association with the incidence of one or more falls; however, the studies are mixed as to whether there is an association between treatment and the total number of falls.
- The evidence was insufficient to draw conclusions about the effect of vitamin D on physical functioning and infection. Few studies reported these outcomes, findings were inconsistent and imprecise, and the studies reporting these outcomes had limitations.
- Treatment effects may vary by population setting (community dwelling vs. institutionalized) for some outcomes (e.g., mortality), but outcomes were similar in studies using a 20 ng/ml versus a 30 ng/ml threshold for deficiency. The evidence was limited for drawing conclusions about other subpopulations.

### Study Characteristics

The studies included for the benefits of treatment (KQ 3) were conducted over the years 1990 to 2019; 17 were included in the prior Evidence Report and 10 are new to this update.^70–79^ All but one study were RCTs. The one non-RCT was a nested case-control study from the WHI Calcium-Vitamin D (Cal-D) trial.^80^ We assessed nine RCTs as good quality,^50,^ ^70–74,^ ^76,^ ^79,^ ^81^ and the rest were assessed as fair quality.

Nine studies were conducted in the United States;^50,^ ^70,^ ^72,^ ^76,^ ^77,^ ^79,^ ^80,^ ^82,^ ^83^ one was conducted in New Zealand,^73^ and one was a multicountry study conducted in Canada, United States, Germany, the Netherlands, and Mexico.^84^ The rest were conducted in various European countries. Twelve studies reported at least some industry funding;^74–76,^ ^79,^ ^82,^ ^84–90^ the rest were funded through government or foundation sponsorship. Table 2 describes the characteristics of included studies, with additional details in Appendix D Table 1 and Table 13. Individual study quality ratings are in Appendix E Tables 1, 2, and 3.

Table 2 Summary of Study Characteristics of Randomized, Controlled Trials Reporting Benefits and Harms of Treatment (KQ 3 and KQ 4)

Author (Year); Trial Name | Country | Study Quality | Interventions; (N randomized) | Calcium Use | Treatment Duration | Mean Age (SD) | N (%); Female | Setting | Outcomes Reported
Aloia et al (2005)^107^ & Talwar et al (2007)^142^ | United States | Fair | Placebo qd (104); Vitamin D3 800 IU qd, changed to 2000 IU qd at 2 yr (104) | Active and control intervention | 3 yr | Placebo: 61.2 (6.3); Vitamin D: 59.9 (6.2) | 208 (100) | Community dwelling | - Serious adverse events; - Kidney stones
Aloia et al (2018)^111^; PODA | United States | Fair | Placebo qd titrated to match Vitamin D group (130); vitamin D_3_ titrated to a serum level of 30 ng/m, dosage was adjusted every 3 months, doses provided as a single daily dose (130) | Active and control intervention | 3 yr | Median age (IQR): 68.2 (65.4 to 72.5) | 258 (100) | Community dwelling | - Total adverse events; - Serious adverse events
Arvold et al (2009)^83^ | United States | Fair | Placebo weekly (50); Vitamin D_3_ 50,000 IU weekly (50) | No calcium used | 8 wk | Placebo: 57.8 (15.8); Vitamin D: 59.7 (14.0) | Placebo: 15 (36); Vitamin D: 21 (44) | Community dwelling | - Physical functioning; - Total adverse events
Bischoff et al (2003)^90^ | Switzer-land | Fair | Placebo bid (60); Vitamin D_3_ 400 IU bid (total daily dose 800 IU) (62) | Active and control intervention | 12 wk | Placebo: 85.4 (5.9); Vitamin D: 84.9 (7.7) | 122 (100) | Institution-alized | - Falls; - Total adverse events; - Other harms
Bislev et al (2018)^71^ | Denmark | Good | Placebo qd (41); Vitamin D_3_ 2,800 IU qd (40) | No calcium used | 12 wk | NR, all women participating were between 60 and 79 years | 81 (100) | Community dwelling | - Fractures; - Total adverse events; - Serious adverse events
Borgi et al (2016)^112^ & McMullan et al (2017)^143^ | United States | Good | Placebo weekly (47); Vitamin D_2_ 50,000 unit tablets weekly (46) | No calcium used | 8 wk | 37 (12.3) | Placebo: 31 (66^*^); Vitamin D: 31 (67^*^) | Community dwelling | - Total adverse events; - Serious adverse events
Brazier et al (2005)^89^ | France | Fair | Placebo bid (97); 500 mg calcium carbonate + vitamin D_3_ 400 IU bid (1,000 mg/800 IU total daily dose) (95) | Active treatment intervention | 52 wk | 74.6 (6.9) | 192 (100) | Community dwelling | - Mortality; - Total adverse events; - Serious adverse events; - Discontinuation
Chapuy et al (2002)^88^; Decalyos II | France | Fair | Placebo qd (NR); Vitamin D_3_ 800 IU and 1,200 mg tricalcium phosphate as fixed combination (NR), vitamin D_3_ 800 IU and 1,200 mg tricalcium phosphate as separate combination (NR) | Active treatment intervention | 2 yr | Placebo: 85.7 (7.6); Vitamin D + calcium (fixed): 84.9 (6.6); Vitamin D + calcium (separate): 84.9 (7.0) | 583 (100) | Institution-alized | - Mortality; - Falls; - Fractures; - Other harms; - Kidney stones
Davidson et al (2013)^76^ | United States | Good | Placebo weekly (53); Vitamin D_3_ weekly, dosing based on body weight and baseline serum vitamin D level to achieve a target serum level of 65 ng/ml to 90 ng/ml. Average weekly dose 88,865 (16,154) IU (56) | No calcium used | 52 wk | Placebo: 52.5 (7.0); Vitamin D: 52.3 (8.0) | Placebo: 38^*^ (71); Vitamin D: 36^*^ (64) | Community dwelling | - Diabetes mellitus
Gagnon et al (2014)^113^ | Australia | Fair | Placebo qd (49); 2,000 IU vitamin D_3_, dose increased by 2,000 IU every 2 months if serum levels not at target (30 ng/ml) (46) | Active and control intervention | 26 wk | Placebo: 55.3 (11.1); Vitamin D: 53.8 (11.9) | Placebo: 30^*^(67); Vitamin D: 25^*^ (71) | Community dwelling | - Total adverse events; - Discontinuation; - Kidney stones
Gallagher et al (2013);^106^ Smith et al (2017);^55^ & Gallagher et al (2012)^50^; VIDOS | United States | Good | Placebo, qd (38);; vitamin D_3_ 400 IU qd (22); vitamin D_3_ 800 IU qd (45); vitamin D_3_ 1,600 IU qd (43); vitamin D_3_ 2,400 IU qd (44); vitamin D_3_ 3,200 IU qd (23; vitamin D_3_ 4,000 IU qd (24); vitamin D_3_ 4,800 IU qd (34) | Active and control intervention | 52 wk | White women: 67 (7.3); Black women: 66.6 (7.5) | 273 (100) | Community dwelling | - Mortality; - Serious adverse events; - Kidney stones; - Other harms
Gallagher et al (2014)^82^; VITADAS | United States | Fair | Placebo qd (38); Vitamin D_3_ 400 IU qd (37); Vitamin D_3_ 800 IU qd (42); Vitamin D_3_ 1,600 IU qd (41); Vitamin D_3_ 2,400 mg IU qd (40) | Active and control intervention | 52 wk | 36.7 (5.9) | 198 (100) | Community dwelling | - Mortality; - Serious adverse events; - Kidney stones
Grimnes et al (2011)^95^ | Norway | Fair | Placebo twice per week (53); Vitamin D_3_ 20,000 IU twice per week (weekly dose 40,000 IU) (51) | No calcium used | 26 wk | 52.1 (9.3) | 53 (49.1) | Community dwelling | - Mortality; - Total adverse events; - Kidney stones
Hansen et al (2015)^70^ | United States | Good | Placebo qd (76); Vitamin D_3_ 800 IU qd (75); Vitamin D_3_ 50,000 IU twice monthly after an initial loading dose of 50,000 IU qd for 15 d, women with serum levels <30 ng/ml at followup study visits had doses increased and titrated to target (79) | No calcium used | 52 wk | 61 (6) | 230 (100) | Community dwelling | - Mortality; - Falls; - Fractures; - Physical functioning; - Kidney stones
Hin et al (2016)^74^; BEST-D | United Kingdom | Good | Placebo qd (101); Vitamin D_3_ 2,000 IU qd (102); Vitamin D_3_ 4,000 IU qd (102) | No calcium used | 52 wk | Placebo: 72 (6); Vitamin D 2,000 IU: 72 (6); Vitamin D 4,000 IU: 71 (6) | Placebo: 49 (49); Vitamin D 2,000 IU: 51 (50); Vitamin D 4,000 IU: 50 (49) | Community dwelling | - Mortality; - Falls; - Fractures; - Serious adverse events
Honkanen et al (1990)^104^ | Finland | Fair | No intervention (63); Vitamin D_3_ 1,800 IU with calcium 1,558 mg qd (63) | Active treatment intervention | 11 wk | Mean age (SE) community dwelling; Control: 69.6 (0.49); Vitamin D: 69.4 (0.54); Hospital; Control: 82.8 (1.3); Vitamin D: 82.2 (1.0) | 126 (100) | Mixed | - Kidney stones; - Other harms
Janssen et al (2010)^91^ | Nether-lands | Fair | Placebo qd (34); Vitamin D_3_ 400 IU qd (36) | No calcium used | 24 wk | Placebo: 79.2 (6.7); Vitamin D: 82.4 (6.4) | 70 (100) | Institution-alized | - Mortality; - Fractures; - Total adverse events; - Discontinuation
Jorde et al (2016)^75,^ ^144^ | Norway | Fair | Unplanned subgroup analysis of 173 participants; Placebo once weekly; Vitamin D_3_ 20,000 IU weekly | No calcium used | 5 yr | Placebo^†^: 61.9 (9.2); Vitamin D^†^: 62.3 (8.1) | Placebo^†^: 102 (40.0); Vitamin D: 95 (37.1) ^†^ | Community dwelling | - Diabetes mellitus; - Infection
Jorde et al (2018)^78^ | Norway | Fair | Post hoc outcome analysis; Placebo, five-capsule loading dose followed by one capsule each week (202); Loading dose of 100,000 IU vitamin D_3_ capsules followed by 20,000 IU each week (206) | No calcium used | 16 wk | 52.0 (8.8) | 191 (46.8) | Community dwelling | - Depression; - Serious adverse events
Kärkkäinen et al (2010)^93,^ ^145^; OSTPRE-FPS | Finland | Fair | No intervention (313); Vitamin D_3_ 400 IU bid (total daily dose 800 IU) with calcium 500 mg bid (total daily dose 1,000 mg) (290) | Active treatment intervention | 3 yr | Control: 67.4 (1.9); Vitamin D: 67.4 (2.0) | 593 (100) | Community dwelling | - Mortality; - Falls; - Discontinuation
Kearns et al (2015)^114^ | United States | Fair | Five placebo pills by mouth at once (14); Five vitamin D_3_ 50,000 IU tablets by mouth once for a total single dose of 250,000 IU (14) | No calcium used | One-time dose, 1-yr of followup | Placebo: 26.5 (5.2); Vitamin D: 28.2 (6.7) | Placebo: 10 (71); Vitamin D: 12 (86) | Community dwelling | - Total adverse events
Kjaergaard et al (2012)^81^; Tromo Study | Norway | Good | Placebo weekly (121); Vitamin D_3_ 40,000 IU weekly (122) | No calcium used | 12 wk | Placebo: 53.3 (10.1); Vitamin D: 53.4 (10.3) | 129 (56) | Community dwelling | - Depression; - Total adverse events; - Discontinuation
Knutsen et al (2014)^108^ | Norway | Fair | Placebo qd (82); Vitamin D_3_ 400 IU qd (85); Vitamin D_3_ 1,000 IU qd (84) | No calcium used | 16 wk | Placebo: 39 (7.6); Vitamin D 400 IU: 37 (7.6); Vitamin D 1,000 IU: 36 (8.2) | Placebo: 63 (77); Vitamin D 400 IU: 61 (72); Vitamin D 1,000 IU: 58 (69) | Community dwelling | - Total adverse events; - Serious adverse events
Krieg et al (1999)^92^ | Switzer-land | Fair | No intervention (124); Vitamin D_3_ 880 IU + 1,000 mg calcium qd (124) | Active treatment intervention | 2 yr | Control^ǂ^: 85 (7); Vitamin D^ǂ^: 84 (8) | 248 (100) | Institution-alized | - Mortality; - Discontinuation
Lehmann et al (2013)^47^ | Germany | Fair | Placebo qd (20); Vitamin D_2_ 2,000 IU qd (50); Vitamin D_3_ 2,000 IU qd (49) | No calcium used | 8 wk | Placebo: 31.6 (9.3); Vitamin D2: 33.2 (12.4); Vitamin D3: 35.6 (13.5) | 68 (63.6) | Community dwelling | - Total adverse events
Lerchbaum et al (2017)^115^; Graz Vitamin D&TT-RCT | Austria | Fair | 50 placebo drops weekly (50); Vitamin D_3_ 20,000 IU as 50 drops weekly (50) | No calcium used | 12 wk | Median age (IQR): 37 (27 to 50) | 0 (0) | Community dwelling | - Total adverse events
Lips et al (1996)^87^ & Ooms et al (1995)^146^ | Nether-lands | Fair | Placebo qd (1,287); Vitamin D_3_ 400 IU qd (1,291) | No calcium used | 3 to 3.5 yr | 80 (6) | 1,916 (74) | Mixed^§^ | - Mortality; - Fractures
Lips et al (2010)^84^ | Multi-country, Canada, Germany, Nether-lands, Mexico, United States. | Fair | Placebo weekly (112); Vitamin D_3_ 8,400 IU weekly (114) | Active and control intervention | 16 wk | Placebo: 77.6 (6.6); Vitamin D: 78.5 (6.2) | NR | Mixed^§^ | - Mortality; - Total adverse events; - Serious adverse events; - Discontinuation; - Kidney stones
Manson et al (2019);^72^ LeBoff et al (2020);^97^ Manson et al (2019);^147^ Manson et al (2012);^148^ Donlon et al (2018);^149^ & Bassuk et al (2016)^150^; VITAL | United States | Good | Planned subgroup analysis of 2,001 participants; Placebo qd; Vitamin D_3_ 2,000 IU qd | No calcium used | NR, but median length of followup was 5.3 yr (IQR, 3.8 to 6.1) | 67 (7.1) | 13,085 (50.6) | Community dwelling | - Cancer; - Cardiovascular; - Falls; - Depression
Martineau et al (2007)^109^ | United Kingdom | Fair | Placebo (one-time dose) (96); Vitamin D_2_ 100,000 IU (one-time dose) (96) | No calcium used | NA | Median age (IQR); Placebo: 37.5 (29.8 to 45.2); Vitamin D: 30.1 (25.1 to 44.1) | 67 (51.2) | Community dwelling | - Total adverse events
Mason et al (2014)^116^; ViDA (US) | United States | Fair | Placebo qd (109); Vitamin D_3_ 2,000 IU qd (109) | No calcium used | 52 wk | 59.6 (5.1) | 218 (100) | Community dwelling | - Total adverse events; - Serious adverse events
Moreira-Lucas et al (2017)^117^ | Canada | Fair | Placebo cheese weekly (36); Vitamin D_3_ 28,000 IU in cheese weekly (35) | No calcium used | 24 wk | Placebo: 45.6 (14.3); Vitamin D: 49.1 (13.9) | Placebo: 20 (56); Vitamin D: 18 (51) | Community dwelling | - Total adverse events
Ng et al (2014);^118^ Chandler et al (2014);^151^ & Chandler et al (2013)^152^ | United States | Good | Placebo qd (81); Vitamin D_3_ 1,000 IU qd (81); Vitamin D_3_ 2,000 IU qd (83); Vitamin D_3_ 4,000 IU qd (83) | Active and control intervention | 12 wk | Median age (IQR): 51.0 (43.6 to 59.4) | 222 (67.7) | Community dwelling | - Other harms
Nowak et al (2016)^119^ | Switzer-land | Good | Placebo (one-time dose) (63); Vitamin D_3_ 100,000 IU (one-time dose) (59) | No calcium used | One-time dose (4-wk followup) | Placebo: 28 (6); Vitamin D: 29 (7) | Placebo: 33 (52); Vitamin D: 31 (53) | Community dwelling | - Total adverse events
Pfeifer et al (2000)^86^ | Germany | Fair | Calcium bid (74); Vitamin D_3_ 400 IU bid (total daily dose 800 IU) (74) | Active and control intervention | 8 wk | Calcium: 74.7 (0.5); Vitamin D: 74.8 (0.5) | 148 (100) | Community dwelling | - Falls; - Fractures
Pfeifer et al (2009)^85^ | Multi-country, Austria, Germany. | Fair | Calcium bid (121); Vitamin D_3_ 400 IU bid (total daily dose 800 IU) (121) | Active and control intervention | 1 yr | Calcium: 77 (4); Vitamin D: 76 (4) | Calcium: 91^*^ (75); Vitamin D: 90^*^ (74) | Community dwelling | - Falls; - Fractures
Pilz et al (2015);^120^ Grubler et al (2016);^153^ Grubler et al (2016);^154^ & Grubler et al (2018)^155^; Styrian Vitamin D Hypertension Trial | Austria | Fair | Placebo qd (100); Vitamin D_3_ 2,800 IU qd (100) | No calcium used | 8 wk | 60.0 (11.1) | 94^*^ (47) | Community dwelling | - Serious adverse events
Pittas et al (2019)^77^; D2d | United States | Fair | Planned subgroup analysis of 525 participants; Placebo qd; Vitamin D_3_ 4,000 IU qd | No calcium used | 2.5 yr | 60.0 (9.9)^†^ | 1,086 (44.8) ^†^ | Community dwelling | - Diabetes mellitus
Raed et al (2017)^121^ & Bhagatwala et al (2015)^156^ | United States | Fair | Placebo monthly (17); Vitamin D_3_ 18,000 IU monthly (equivalent to 600 IU qd) (17); Vitamin D_3_ 60,000 IU monthly (equivalent to 2,000 IU qd) (18); Vitamin D_3_ 120,000 IU monthly (equivalent to 4000 IU qd) (18) | No calcium used | 16 wk | Placebo: 27.8 (9.9); Vitamin D 18,000 IU: 26.2 (9.8); Vitamin D 60,000 IU: 24.4 (8.7); Vitamin D 120,000 IU: 25.5 (9.0) | Placebo: 13 (76); Vitamin D 18,000 IU: 15 (88); Vitamin D 60,000 IU: 15 (83); Vitamin D 120,000 IU: 16 (89) | Community dwelling | - Total adverse events
Scragg et al (2017);^99^ Khaw et al (2017)^7^;^3^ & Scragg et al (2018)^100^; ViDA (NZ) | New Zealand | Good | Planned subgroup analysis of 1,270 participants; Placebo monthly; Vitamin D_3_ 200,000 IU initial dose followed by monthly doses of 100,000 IU | No calcium used | 3.3 yr | 65.9 (8.3) ^†^ | 2,139 (41.9)^†^ | Community dwelling | - Falls; - Fractures; - Cardiovascular; - Cancer
Shea et al (2019)^79^ | United States | Good | Placebo bid (51); Vitamin D_3_ 858 IU daily (49) | No calcium used | 52 wk | Mean age (SD): 69.6 (6.9) | 36 (36^*^) | Community dwelling | - Falls
Tran et al (2014)^122^ & Tran et al (2012)^157^; D-Health | Australia | Good | Placebo monthly (214); Vitamin D_3_ 30,000 IU monthly (215); Vitamin D_3_ 60,000n IU monthly (215) | Active and control intervention | 48 wk | 72 (NR) | 288^*^ (47) | Community dwelling | - Total adverse events; - Serious adverse events
Wamberg et al (2013)^110,^ ^158^ | Denmark | Fair | Placebo qd (26); Vitamin D_3_ 7,000 IU qd (26) | No calcium used | 26 wk | Placebo: 41.2 (6.8); Vitamin D: 39.5 (8.0) | 39 (71) | Community dwelling | - Total adverse events
Witham et al (2013)^105^ | United Kingdom | Fair | Placebo once (25); Vitamin D_3_ 100,000 IU once (25) | No calcium used | One-time dose (8-wk followup) | Placebo: 39.4 (11.8); Vitamin D: 41.7 (13.4) | 50 (100) | Community dwelling | - Total adverse events; - Serious adverse events; - Kidney stones
Wood et al (2012)^94^ & Macdonald et al (2017)^159^ | United Kingdom | Fair | Placebo qd (102); Vitamin D_3_ 400 IU qd (102); Vitamin D_3_ 1,000 IU qd (101) | No calcium used | 52 wk | Placebo: 63.9 (2.3); Vitamin D 400 IU: 63.5 (1.9); Vitamin D 1,000 IU: 64.1 (2.3) | 305 (100) | Community dwelling | - Falls; - Diabetes mellitus; - Total adverse events; - Serious adverse events

* Represents a calculated value.

† Represents characteristic for the entire study population, not the subgroup that was vitamin D deficient.

ǂ Of those who completed the study.

§ Lips et al (1996)^87^ included a majority of participants from institutionalized settings; thus, this study was considered an institutionalized setting in all stratified analyses. Lips et al (2010)^84^ included a majority of participants from community-dwelling participants; thus, this study was considered community dwelling in all stratified analyses.

Abbreviations: bid=twice daily; IU=international unit; IQR= interquartile range; N=number of participants; NA=not applicable; NR=not reported; qd=every day; SD=standard deviation.

Five studies were conducted exclusively or predominantly among populations in nursing homes or homes for the elderly (i.e., “institutionalized” settings).^88,^ ^90–92^ The rest of the RCTs were conducted exclusively or predominantly among community-dwelling populations. Twelve studies were conducted exclusively among female populations,^50,^ ^70,^ ^71,^ ^80,^ ^82,^ ^86,^ ^88–90,^ ^92–94^ and the rest were conducted among populations of males and females. The race/ethnicity of the studied populations included multiple races and ethnicities in nine studies,^50,^ ^70,^ ^72,^ ^73,^ ^77,^ ^79,^ ^80,^ ^82,^ ^83^ was exclusively Caucasian in one study,^94^ was mostly Latino in one study,^76^and was not reported in the 16 remaining studies. The mean age of included populations ranged from a mean of 36 to 85, but half were conducted among study populations ages 60 to 75 years. The mean BMI ranged from 25 to 33 across studies.

The included studies varied with respect to other characteristics of the enrolled populations potentially relevant to the outcomes of interest in this review. Eleven studies excluded participants with osteoporosis or who were taking osteoporosis medications (e.g., bisphosphonates).^50,^ ^70,^ ^71,^ ^74,^ ^82,^ ^84–86,^ ^88–90^ One study reported that 15 to 17 percent of enrolled participants had osteoporosis;^71^ the rest of the studies did not report whether participants with osteoporosis were included. Five studies excluded participants with a recent history of fracture;^50,^ ^85–87,^ ^90^ one study reported that between 15 and 30 percent of participants had a history of fracture in adulthood,^71^ and the rest of the studies did not specify fracture history of enrolled participants. No studies excluded participants based on a previous history of falling, and all but four studies did not specify whether enrolled participants had a history of falling. Two of the studies that did specify whether participants had a history of falls were conducted among institutionalized populations; the percentage of enrolled participants with a fall in the 6 weeks before enrollment was 23 to 24 in one study^90^ and was 15 to 18 percent within the previous 3 months in the other study.^88^ Other characteristics known to be associated with vitamin D levels (e.g., UV exposure) were variably measured or reported.

Nine studies enrolled participants with serum vitamin D levels less than 20 ng/ml.^50,^ ^71,^ ^78,^ ^79,^ ^82,^ ^84,^ ^86,^ ^89,^ ^91^ Five studies enrolled participants using a higher serum vitamin D threshold (<25 ng/ml,^83^ <27 ng/ml,^70^ <22 ng/ml,^81^ <30 ng/ml,^76^ or <31.2 ng/ml^85^). Eight studies did not require participants to meet specific serum vitamin D–level criteria for enrollment, but the mean baseline serum vitamin D levels reported among the enrolled populations suggested that 90 percent or more of the enrolled participants had baseline levels less than 20 ng/ml in three studies^87,^ ^88,^ ^94^ and less than 30 ng/ml in five studies.^74,^ ^90,^ ^92,^ ^93,^ ^95^ Five studies did not require participants to be vitamin D deficient for study enrollment but reported results separately for the subgroup of participants with serum levels less than 20 ng/ml.^72,^ ^73,^ ^75,^ ^77,^ ^80^ Vitamin D assays used by studies varied (e.g., radioimmunoassay, competitive-binding protein assay, LC-MS/MS).

All studies used vitamin D_3_ as part of the active treatment intervention. Most studies used daily doses, which varied from as low as 400 IU to as high as 4,000 IU . Two studies used a high initial loading dose, followed by lower monthly doses;^70,^ ^73^ one of these studies also titrated the dose to reach a target serum level of 30 ng/ml.^70^ One study titrated the weekly dose to achieve a target serum level between 65 ng/ml and 90 ng/ml, resulting in an average weekly dose of 88,865 IU.^76^ The rest of the studies used weekly, twice weekly, twice monthly, or monthly doses. Two studies used a no-intervention control group;^92,^ ^93^ the rest used placebo controls. Four studies included various doses of oral calcium as part of the active treatment intervention.^88,^ ^89,^ ^92,^ ^93^ Six studies provided calcium to both the active vitamin D treatment group and control group.^50,^ ^82,^ ^84–86,^ ^90^ The rest of the included studies did not include any calcium as part of the active or control intervention. Treatment duration ranged from 8 weeks to 7 years.

### Findings

#### All-Cause Mortality

We identified 13 studies (12 RCTs^50,^ ^70,^ ^74,^ ^82,^ ^84,^ ^87–89,^ ^91–93,^ ^95^ and 1 nested case control study^80^) that reported mortality. Two RCTs are new to this update.^70,^ ^74^ Seven RCTs were good quality;^50,^ ^70–74,^ ^81^ the rest of the studies were fair quality. Four RCTs were conducted exclusively^88,^ ^91,^ ^92^ or predominantly^87^ in institutionalized populations; the rest were conducted exclusively or predominantly in community-dwelling populations. Four RCTs used calcium as part of the active vitamin D intervention,^88,^ ^89,^ ^92,^ ^93^ and three studies used calcium in both the active treatment and control groups.^50,^ ^82,^ ^84^ The treatment duration ranged from 16 weeks to 7 years. No studies specifically evaluated mortality as a primary study aim.

The pooled ARD in the eight RCTs conducted among community-dwelling populations was 0.3 percentage points (95% CI, −0.6% to 1.1%; 2,006 participants; I^2^=0%). The RR was 1.13 (95% CI, 0.39 to 3.28) (Figure 3). All of the RCTs individually excluded a statistically significant treatment effect; however, because events were rare, individual study estimates were imprecise. Because events were so rare, we conducted sensitivity analyses using different statistical approaches as recommended for situations with rare binary events (e.g., several approaches for continuity correction, use of Peto method). In sensitivity analyses, the ARD was stable, varying from 0% to 0.3%; however, the RR varied from 0.86 to 1.17, depending on the approach used (Appendix F Table 1 and Table 2). We found minimal difference in treatment effect based on whether RCTs enrolled community-dwelling participants with serum vitamin D levels predominantly less than 20 ng/ml versus enrolling participants with levels that were predominantly less than 30 ng/ml (Appendix F Figure 1). Results were too imprecise to draw any definitive conclusions about the effect of calcium use on treatment effect (Appendix F Figure 2).

Figure 3 Effect of Vitamin D Treatment on Mortality Stratified by Setting

Figure Note: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points).

Abbreviations: CI=confidence interval; Cntl=control; RD=absolute risk difference; RR=relative risk; Tx=treatment; Vit=vitamin; wk=week; yr=year.

Figure 3 is titled “Effects of Vitamin D Treatment vs. Control on Mortality by Setting.” This figure displays a forest plot reporting the absolute risk difference of mortality divided by setting (i.e. community dwelling versus institutionalized). Eight studies report on community dwelling populations (Grimnes, 2011; Hin, 2016; Hansen, 2015; Brazier, 2005; Karkkainen 2010, Gallagher, 2012; Gallagher, 2014; Lips, 2010) and 3 studies report on institutionalized populations (Lip, 1996, Chapuy, 2002, Krieg, 1999). Among the eight studies reporting on community dwelling populations, 3 include calcium in both arms (Gallagher, 2012; Gallagher, 2014; Lips, 2010), 2 include calcium in only the active arm (Brazier, 2005; Karkkainen, 2010) and 3 do not include calcium (Grimnes, 2011; Hin, 2016; Hansen, 2015). Among the 3 studies reporting on institutionalized populations 2 included calcium in only the active arm (Chapuy, 2002; Kreig, 1999) and 1 did not include calcium (Lips, 1996). The pooled absolute risk difference comparing active treatment with control among community dwelling participants was 0.30 percent (95% CI, −0.6% to 1.1%; 2,006 participants, I2=0%). No individual studies reported a significant difference between active treatment and control. The pooled absolute risk difference comparing active treatment with control among institutionalized populations was −2.8 percent (95% CI, −5.5% to −0.2%, 3,409 participants, I2=0%) and the pooled relative risk is 1.13 (95% CI, 0.39 to 3.28). No individual studies reported a significant difference between active treatment and control.

The findings from the WHI nested case-control study were consistent with the findings from the RCTs.^80,^ ^96^ In this nested case-control study of community-dwelling women, no association between treatment with vitamin D and calcium and all-cause mortality was observed among the participants with baseline vitamin D levels between 14 and 21 ng/ml or for participants with levels less than 14 ng/ml (Appendix D Table 14).

One of the RCTs conducted in institutional settings reported mortality (1 participant), but this was not reported by group, so it could not be included in the quantitative synthesis.^91^ Among the three RCTs conducted among institutionalized populations, an absolute risk decrease ranging from 2.2 to 5.6 percentage points was observed; however, no individual study estimates were precise enough to exclude the null effect (Figure 3). When pooled, the ARD was −2.8 percentage points (95% CI, −5.5% to −0.2%; 3,409 participants, I^2^=0%), equivalent to a decrease of 28 deaths per 1,000 participants with a number needed to treat of 35 (95% CI, 18 to 500). The RR was 0.86 (95% CI, 0.74 to 0.99). These findings suggest some beneficial treatment effect in this population.

#### Fractures

We identified 10 studies (9 RCTs^70,^ ^71,^ ^73,^ ^74,^ ^85–88,^ ^91^ and 1 nested case control study^80^) that reported one or more fracture outcomes. Four of the RCTs are new to this update.^70,^ ^71,^ ^73,^ ^74^ We assessed four studies as good quality,^70,^ ^71,^ ^73,^ ^74^ and the rest were fair quality. All but three RCTs^87,^ ^88,^ ^91^ were conducted among community-dwelling populations. One study enrolled participants without regard to vitamin D level but reported findings from a subgroup analysis of vitamin D–deficient (< 20 ng/ml) participants.^73^ One RCT used calcium as part of the active treatment intervention,^88^ and two RCTs used calcium as part of both the active and control interventions.^85,^ ^86^ Treatment duration and followup ranged from 12 weeks to 3.5 years.

Nine studies (8 RCTs and the 1 nested case-control study) reported on any type of fractures;^70,^ ^71,^ ^73,^ ^74,^ ^80,^ ^85–88^ fracture was not a study aim in any studies except for the two studies noted in the next paragraph that designated hip fractures as a primary study aim. Two studies were conducted exclusively or predominantly in institutionalized populations;^87,^ ^88^ the rest were conducted in community-dwelling populations. Two RCTs reported nonvertebral fractures; in one of these studies, fractures were ascertained based on International Classification of Diseases Tenth Revision (ICD-10) codes from national administrative datasets^73^ and in the other study from incidence reported at study visits every 3 months with systematic verification only for vertebral fractures.^88^ One RCT reported peripheral fractures as ascertained through patient questionnaire with verification from the general practitioner.^87^ Two RCTs reported all fractures that were verified by X-ray or medical report.^85,^ ^86^ Two RCTs reported “self-reported fractures,” but location was not defined.^70,^ ^74^ One RCT did not provide any information about location of fractures or method of ascertainment.^71^ The pooled ARD from RCTs for incidence of fractures among community-dwelling populations was −0.3 percentage points (95% CI, −2.1% to 1.6%; 2,186 participants; 6 RCTs; I^2^=13.0%)(Figure 4). The pooled RR was 0.84 (95% CI, 0.58 to 1.21). We found a minimal difference in treatment effect based on whether RCTs enrolled community-dwelling participants with serum vitamin D levels predominantly less than 20 ng/ml versus enrolling participants with levels that were predominantly less than 30 ng/ml (Appendix F Figure 3). Data were limited, and results were too imprecise to draw any definitive conclusions about the effect of calcium use on treatment effect on fracture incidence (Appendix F Figure 4).

Figure 4 Effect of Vitamin D Treatment on Incidence of Any Fracture in Community-Dwelling Participants

Figure Notes: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points)

Abbreviations: CI=confidence interval; Cntl=control; Fx=fracture, RD=absolute risk difference; RR=relative risk; Tx=treatment; Vit = vitamin; wk=weeks; yr=years.

Figure 4 is titled “Effects of Vitamin D vs. Control on Fractures, Community-dwelling Participants.” This figure displays a forest plot reporting the risk ratio for fractures in six studies (Scragg, 2017; Bislev, 2018; Hin, 2016; Hansen, 2015; Pfeifer, 2009; Pfeifer 2003). Three studies specifically defined these fractures one restricted to ‘non-vertebral’ fractures (Scragg, 2017) and two included any fracture (Pfeifer, 2009; Pfeifer, 2000). Three other studies did not specify which fractures were included (Bislev, 2018; Hin, 2016; Hansen, 2015). Among the six studies, 2 included calcium in both arms (Pfeifer, 2009; Pfeifer, 2000) and 4 did not include calcium (Scragg, 2017; Bislev, 2018; Hin, 2016; Hansen, 2015). The pooled risk ratio comparing active treatment with control was −0.3 percent (95% CI, −2.1 to 1.6%; 2,186 participants, I2=13%) and the pooled relative risk was 0.84 (95% CI, 0.58 to 1.21). No individual studies reported a significant difference between active treatment and control.

Four RCTs and one nested case-control study reported hip fracture outcomes;^80,^ ^86–88,^ ^91^ hip fractures were the primary study aim for two of these studies.^80,^ ^87^ Two studies were in exclusively or predominantly community-dwelling populations,^80,^ ^86^ and three were in exclusively or predominantly institutionalized populations.^87,^ ^88,^ ^91^ One RCT reported one participant with a hip fracture but did not specify the group; these results cannot be interpreted.^91^ Ascertainment methods across studies varied: hip fractures were captured as adverse events (no other information provided by authors) in one study,^91^ incidence was assessed at study visits every 3 months in one study,^88^ incidence was assessed with annual questionnaire with verification from the general practitioner in one study,^87^ and one study required hip fractures to be verified by X-ray reports and medical records.^86^ The pooled ARD for incidence of hip fractures was −0.9 percentage points (95% CI, −3.5% to 1.8%; 3,349 participants; 3 RCTs; I^2^=47.4%)(Figure 5). The pooled RR was 0.86 (95% CI, 0.50 to 1.47). In the one RCT conducted among community-dwelling populations, only one hip fracture occurred, leading to a very imprecise effect estimate for this study. The estimates from the two studies conducted among institutionalized populations were mixed; one study estimated a decrease^88^ and one study estimated an increase,^87^ but neither study could exclude the null effect. All studies enrolled participants with serum vitamin D levels predominantly less than 20 ng/ml; no calcium was used in two studies, while calcium was used as part of the active treatment intervention in one study and was used as part of both the active and control groups in one study.

Figure 5 Effect of Vitamin D Treatment on Incidence of Hip Fractures

Figure Note: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points).

Abbreviations: CI=confidence interval; Cntl=control; Fx=fracture; RD=absolute risk difference; RR=relative risk; Tx=treatment, wk=weeks; yr=years.

Figure 5 is titled “Effect of Vitamin D Treatment vs. Control on Hip Fractures.” This figure displays a forest plot reporting the absolute risk difference in hip fractures in 3 studies (Pfeifer, 2000; Lips, 1996; Chapuy, 2002). Of these three 2 were in institutionalized populations (Lips, 1996; Chapuy, 2002) and 1 was in a community-dwelling population (Pfeifer, 2000). One study included calcium in both arms (Pfeifer, 2000), 1 study included calcium in only the active arm (Chapuy, 2002), and 1 study did not include calcium (Lips, 1996). The pooled absolute risk difference was −0.9 percent (95% CI, −3.5% to 1.8%, 3,349, I2=47.4%) and the pooled relative risk was 0.86 (95% CI, 0.50 to 1.47). No individual studies reported a significant difference between active treatment and control.

Findings from the WHI nested case-control study confirmed findings from the RCTs for both any fracture and hip fracture outcomes. This study reported “clinical fractures,” defined as fractures at sites other than ribs, sternum, skull, fingers, toes, or cervical vertebrae.^80^ Further, blinded, central physician adjudicators reviewed imaging and operative reports to ascertain the incidence of hip fracture. Over 7 years of followup, there was no association between treatment using vitamin D with calcium and clinical fracture or hip fracture incidence among study participants with serum vitamin D levels less than 24 ng/ml at baseline (Appendix D Table 14).

#### Falls

Eleven RCTs reported fall outcomes;^70^ five are new to this update.^70,^ ^72–74,^ ^79,^ ^97^ Five were good quality^70,^ ^72–74,^ ^79,^ ^97^ and the rest were fair quality. Two RCTs were conducted in institutionalized settings;^88,^ ^90^ the rest were conducted among community-dwelling populations. Two RCTs reported that between 12 and 15 percent of the study population had a prior history of falls,^74,^ ^88^ and one RCT (conducted in an institutionalized setting) reported that 15 to 21 percent of the study population had a prior history of hip fracture.^90^ Two studies enrolled participants without regard to vitamin D level but reported findings from a subgroup analysis of vitamin D–deficient (< 20 ng/ml) participants.^73,^ ^97^ Calcium was used as part of the active treatment intervention in two RCTs^88,^ ^93^ and was used in both the active and control interventions in three RCTs.^85,^ ^86,^ ^90^

Treatment duration ranged from 8 weeks to more than 6 years, though followup measures were ascertained at between 1 year and a median followup of 5.3 years.

Falls were indicated as the primary study outcome in three of the RCTs.^85,^ ^90,^ ^93^ Four RCTs reported the number of participants who experienced one or more falls (i.e., incidence of fallers),^73,^ ^74,^ ^79,^ ^88^ two RCTs reported the total number of falls experienced in each group,^70,^ ^94^ and four RCTs reported both outcomes.^85,^ ^86,^ ^90,^ ^93^ One RCT, which reported on a subgroup of vitamin D–deficient participants, examined the incidence of two or more falls.^72,^ ^97^ A variety of means were used to ascertain falls, most commonly self-report at in-person or telephone study followup visits or questionnaires. In some cases, falls were recorded as part of adverse event monitoring. One study, conducted in an institutionalized setting, recorded falls as measured by a fall protocol in use within the unit.^90^

The pooled ARD for the incidence of participants with one or more falls in the six RCTs conducted among community-dwelling populations was −4.3 percentage points (95% CI, −11.6% to 2.9%; 2,633 participants; I^2^=70.1%) (Figure 6). The RR was 0.90 (95% CI, 0.75 to 1.08). Heterogeneity was high as indicated by the I^2^ statistic, and we observed inconsistency in the direction and magnitude of effect. Two studies conducted by the same first author observed a more than 10 percentage point absolute decrease in incidence;^85,^ ^86^ however, findings were only statistically significant in one of the studies.^85^ The other four studies observed smaller effects ranging from a decrease of 4.6 percentage points to an increase of 3.1 percentage points; these findings were not statistically significant.^73,^ ^74,^ ^79,^ ^93^ We found minimal difference in treatment effect based on whether RCTs enrolled community-dwelling participants with serum vitamin D levels predominantly less than 20 ng/ml versus enrolling participants with levels that were predominantly less than 30 ng/ml (Appendix F Figure 5). Data were limited and results were too imprecise to draw any definitive conclusions about the effect of calcium use on treatment effect on fall incidence (Appendix F Figure 6). In the good-quality RCT reporting on the incidence of two or more falls, a more stringent definition, no significant difference was observed between vitamin D and placebo groups among participants with baseline vitamin D levels less than 12 ng/ml (adjusted OR, 1.03; 95% CI, 0.59 to 1.79) or for participants with levels between 12 and 20 ng/ml (adjusted OR, 1.13; 95% CI, 0.87 to 1.48).^72,^ ^97^

Figure 6 Effect of Vitamin D Treatment on Incidence of Falls in Community-Dwelling Participants

Figure Note: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points).

Abbreviations: CI=confidence interval; Cntl=control; RD=absolute risk difference; RR=relative risk; Tx=treatment; Vit=vitamin; wk=weeks; yr=years.

Figure 6 is titled “Effects of Vitamin D vs. Control on Falls, Community-dwelling Participants.” This figure displays a forest plot reporting the absolute risk difference in hip fractures in 6 studies (Scragg, 2017; Hin, 2016; Shea, 2019; Karkkainen, 2010; Pfeifer, 2000; Pfeifer, 2009). Among the six studies 2 included calcium in both arms (Pfeifer, 2000; Pfeifer, 2009), 1 included calcium in only the active arm (Karkkainen, 2010) and 3 did not include calcium (Scragg, 2017; Hin, 2016; Shea, 2019). The pooled absolute risk difference was −4.3 percent (95% CI, −11.6% to 2.9%, I2=70.1%) and the pooled relative risk was 0.90 (95% CI, 0.75 to 1.08). One study (Pfeifer et al. 2009) demonstrated a significant difference between active treatment and control ARD −21.5% (95% CI, −33.8% to −9.2%).

Among the two RCTs conducted in institutionalized settings, one study observed a decrease of 7.4 percentage points (95% CI, −23.0% to 8.2%) in the absolute risk over 12 weeks, while the other observed an increase of 1.8 percentage points (95% CI, −6.6% to 10.1%) over 2 years, but findings were not statistically significant in either study. Both studies were conducted in very elderly populations (mean age 85); the study that observed a decrease used calcium in both the active treatment and control arms,^90^ while the other study only used calcium in the active treatment arm.^88^

Six RCTs reported the total number of falls by group over the duration of followup.^70,^ ^85,^ ^86,^ ^90,^ ^93,^ ^94^ Using these data, we calculated IRDs and IRRs (Figure 7). Among the five RCTs conducted in community-dwelling populations, participants allocated to active treatment had 0.10 fewer falls per person-year compared with placebo (95% CI, −0.19 to −0.002; 2,838 person-years; I^2^=76.9%), and the IRR was 0.76 (95% CI, 0.57 to 0.94) comparing active treatment to control. Heterogeneity was high as indicated by the I^2^ statistic. Three of the studies observed statistically significant decreases ranging from 0.07 to 0.32 falls per person-year.^85,^ ^93^ The other two studies observed nonsignificant findings, though one observed a decrease (−0.01)^94^ and the other observed an increase (0.03).^70^

Figure 7 Effect of Vitamin D Treatment on Total Number of Falls in Community-Dwelling Participants

Figure Note: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points).

Abbreviations: CI=confidence interval; Cntl=control; PY=person-year; RD=absolute risk difference; RR=relative risk; Tx=treatment; Vit= vitamin; wk=weeks; yr=years.

Figure 7 is titled “Effects of Vitamin D vs. Control on Total Number of Falls, Community-dwelling Participants.” This figure displays a forest plot reporting the absolute risk difference of falls in 5 studies (Hansen, 2015; Wood, 2012; Karkkainen, 2010; Pfeifer, 2000; Pfeifer, 2009). The pooled incident rate difference was −0.10 falls per person-year (95% CI, −0.19 to −0.001, 2,838 participants, I2=76.9%) and the pooled incidence rate ratio was 0.76 (95% CI, 0.57 to 0.94). Two of the studies showed statistically significant results comparing treatment with control groups (Pfeifer et al. 2000 and Pfeifer et al 2009).

In the one RCT conducted in an institutional setting, the incident rate difference was −2.2 falls per person-year (95% CI, −3.5 to −0.98), and the incident rate ratio was 0.44 (95% CI, 0.27 to 0.70).^90^

#### Diabetes

Four fair-quality RCTs^75,^ ^77,^ ^94,^ ^98^ and one good-quality RCT,^76^ all conducted among community-dwelling populations, reported the effect of vitamin D treatment on the incidence of diabetes. Three RCTs were new to this update and enrolled participants with prediabetes or impaired fasting glucose,^75–77^ and two trials specified incident diabetes as a primary study outcome.^75,^ ^77^ Three trials did not exclusively enroll vitamin D–deficient participants but reported findings among subgroups of vitamin D–deficient participants;^75,^ ^77,^ ^98^ however, these analyses were pre-specified in only one of the studies.^77^ One RCT used calcium as part of the active vitamin D intervention;^98^ the rest of the RCTs did not use calcium. One of the included trials was the WHI Cal-D trial.^80,^ ^98^ Other outcomes presented from the WHI study earlier in this report were reported from a nested case-control study design; in contrast, the incidence of diabetes outcome was reported from a post hoc analysis of the WHI Cal-D trial for the subgroup of participants with measured serum vitamin D at baseline.

The studies varied in the way this outcome was ascertained. In three RCTs, incident diabetes was based on glycemic testing using established thresholds for diagnosis.^75–77^ In one study, the incidence of diabetes was reported as an adverse event without any specific criteria for diagnosis listed,^94^ and in the subgroup analysis from the WHI CalD trial, diabetes was based on participant self-report of a doctor prescribing medication or insulin for diabetes.^98^ The pooled ARD for incident diabetes over 1 to 7 years was 0.1 percentage points (95% CI, −1.3% to 1.6%; 3,356 participants; I^2^=0%). The pooled RR was 0.96 (0.80 to 1.15) (Figure 8).

Figure 8 Effect of Vitamin D Treatment on Incidence of Type 2 Diabetes in Community-Dwelling Participants

Figure Note: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points). The direction of the risk difference is positive and the direction of the relative risk is negative because of the nature of the continuity correction used in the one study with zero events in the control group.^94^ A sensitivity analysis without this study confirmed consistency in the direction of effect suggesting a statistical artifact from the use of a continuity correction.

Abbreviations: CI=confidence interval; Cntl=control; RD=absolute risk difference; RR=relative risk; T2D=type 2 diabetes; Tx=treatment; Vit=vitamin; WHI=Women’s Health Initiative; wk=weeks; yr=years.

Figure 8 is titled “Effects of Vitamin D Treatment vs. Control on Incidence of Type 2 Diabetes, Community-Dwelling Participants.” This figure displays a forest plot reporting the absolute risk difference of incidence of type 2 diabetes for five studies. Among the five studies, one (WHI, 2008) included calcium in the active intervention arm. All others did not include calcium in either study arms. The pooled absolute risk difference comparing active treatment with control was 0.10 percent (95% CI, −1.3% to 1.6%; 3,356 participants, I2=0%) and the pooled relative risk was 0.96 (95% CI, 0.80 to 1.15). No individual studies reported a significant difference between active treatment and control.

Two studies reported subgroup analyses based on degree of baseline vitamin D deficiency.^77,^ ^98^ The hazard ratio (HR) for developing incident diabetes over 7 years of followup in the WHI trial varied by baseline vitamin D level (HR, 1.60 [95% CI, 0.80 to 3.18] for participants with serum vitamin D levels between 17 and 24 ng/ml; HR, 0.66 [95% CI, 0.36 to 1.23] for levels between 13 and 17 ng/ml; and HR, 1.07 [95% CI, 0.62 to 1.82] for levels less than 13 ng/ml).^98^ These findings were reported from a subgroup of 3,097 participants with serum vitamin D levels measured at baseline. Among the 525 participants with serum vitamin D levels less than 20 ng/ml enrolled in the D2d trial, the HR for incident diabetes was 0.87 (95% CI, 0.61 to 1.22) at a median of 2.5 years followup.^77^ This finding was consistent with the findings reported in participants with serum vitamin D levels greater than 20 ng/ml.^77^ However, in a post hoc subgroup analysis of participants (n=103) with serum vitamin D levels less than 12 ng/ml, an HR of 0.38 (95% CI, 0.18 to 0.80) was observed.^77^

#### Cardiovascular Disease

Two good-quality RCTs (Vitamin D Assessment Study [ViDA]^73,^ ^99^ and VITamin D and OmegA-3 TriaL [VITAL]^72^), both new to this update, enrolled community-dwelling males and females and reported the effect of vitamin D on the incidence of cardiovascular disease. These trials did not exclusively enroll participants with vitamin D deficiency but reported findings in preplanned subgroup analyses among participants with baseline serum vitamin D levels less than 20 ng/ml. VITAL specifically excluded participants with preexisting cardiovascular disease, while between 1 and 10 percent of enrolled participants had cardiovascular morbidities at baseline in the ViDA trial. In VITAL, participants were allocated to vitamin D_3_ alone or in combination with omega-3 fatty acids compared with placebo in a two-by-two factorial design.^72^ In ViDA, participants were allocated to vitamin D or placebo.^73,^ ^99^ Neither trial used calcium as part of the treatment intervention.

Both trials specified cardiovascular events as a primary outcome; however, the definition of cardiovascular events was somewhat broader in the ViDA trial and included venous thromboembolism, pulmonary embolism, inflammatory cardiac conditions, arrythmias and conduction disorders with ascertainment based on ICD-10 codes from administrative data. In VITAL, cardiovascular endpoints included myocardial infarction, stroke, and cardiovascular disease (CVD) mortality (primary composite) and an expanded composite that also included cardiac revascularization. These endpoints were based on established criteria and adjudicated by a committee masked to treatment assignment using all available data sources. Both trials observed no differences in cardiovascular events between active treatment groups and the placebo group among the subgroup of participants with serum vitamin D levels less than 20 ng/ml. Over a median followup of 5.3 years, the HR was 1.09 (95% CI, 0.68 to 1.76) in the VITAL trial (N=2,001 subgroup) and was 1.00 (95% CI, 0.74 to 1.35) over a mean of 3.3 years followup in the ViDA trial (N=1,270 subgroup).^72,^ ^73,^ ^99^

#### Cancer

Three studies, the good-quality VITAL^72^ and ViDA^73,^ ^99,^ ^100^ RCTs and the fair-quality WHI nested case-control study^80,^ ^101,^ ^102^ reported the effect of vitamin D on the incidence of cancer. VITAL and ViDA are new to this update. All studies enrolled participants without a history of cancer at baseline, but no studies exclusively enrolled participants with vitamin D deficiency; rather, outcomes were reported in a preplanned subgroup analysis for participants with deficiency. In VITAL, over 25,000 participants were allocated to vitamin D_3_ alone or in combination with omega-3 fatty acids compared with placebo in a two-by-two factorial design.^72^ In ViDA, participants were allocated to monthly 100,000 IU doses (after an initial dose of 200,000 IU) of vitamin D_3_ or placebo. In the WHI nested case-control study, participants were exposed to vitamin D_3_ plus calcium versus placebo.^80,^ ^101,^ ^102^ The VITAL study specified invasive cancer as a primary study outcome, and cancer cases were confirmed by histologic or cytologic data upon medical record review by blinded physician adjudicators. In ViDA, cases of cancer were identified through a national registry.^100^ In the WHI study, cases were verified by medical record and pathology reports by blinded physician adjudicators.^101,^ ^102^

Over a median followup of 5.3 years, the HR for incident invasive cancer (any type) was 0.97 (95% CI, 0.68 to 1.39) for vitamin D compared with placebo among the subgroup of 2,001 participants with serum vitamin D levels less than 20 ng/ml at baseline in the VITAL trial.^72^ In the ViDA trial, the HR for incident cancer among the subgroup of 1,270 participants with serum vitamin D levels less than 20 ng/ml at baseline was 1.01 (95% CI, 0.65 to 1.58) over a mean of 3.3 years of followup.^100^ In the WHI nested case-control study, the adjusted odds ratios (ORs) for incident breast or colorectal cancer over 7 years of followup did not demonstrate a statistically significant association between exposure to active treatment and incidence of breast or colorectal cancer among participants with vitamin D deficiency at baseline (Appendix D Table 14).^101,^ ^102^

#### Depression

Three RCTs, one good-quality RCT conducted in the United States (VITAL^72,^ ^103^) and two conducted in Norway (one fair quality^78^ and one good quality^81^), reported depression outcomes. Two were new to this update.^72,^ ^78,^ ^103^ VITAL-DEP (Depression Endpoint Prevention) was an ancillary study to the previously described VITAL study, an RCT of vitamin D and omega-3 focused on cardiovascular and cancer prevention.^72,^ ^103^ This subgroup of 1,328 participants with baseline serum vitamin D levels less than 20 ng/ml were not receiving depression treatment or having depression symptoms or comorbid psychiatric conditions including substance use disorder, bipolar disorder, or psychotic disorders at baseline. Among this subgroup, the mean difference in Personal Health Questionnaire Depression Scale (PHQ-8) score over the median followup of 5.3 years (difference in mean change −0.00; 95% CI, −0.17 to 0.17).^72,^ ^103^ This study did not evaluate the incidence of depression among the subgroup of participants with vitamin D levels less than 20 ng/ml, but no significant difference was observed in new depression events between those with levels less than 20 and those with levels greater than 20 (HR, 1.08; 95% CI, 0.87 to 1.35), and no significant difference in new depression events was observed in the full study population with respect to those allocated to vitamin D compared with placebo (HR, 0.97; 95% CI, 0.87 to 1.09).^72,^ ^103^

One RCT conducted with 243 participants reported on depression outcomes among community-dwelling adults ages 30 to 75 years with vitamin D levels less than 22 ng/ml who were randomized to vitamin D_3_ or placebo for 12 weeks with followup measured at 26 weeks;^81^ depression was the primary study aim. Three depression measures were used (Montgomery-Asberg Depression Rating Scale, Beck Depression Inventory, Hospital Anxiety and Depression Scale). Authors observed small improvements in depression as measured by all three scales in both the active treatment and placebo groups; the difference between active treatment and placebo groups was not statistically significant for any of the three scales (Appendix D Table 7). The other study was conducted among 422 participants with serum levels less than 16.8 ng/ml and compared vitamin D_3_ with placebo over 16 weeks;^78^ depression was not the primary study aim and appeared to be an outcome assessed in a post hoc analysis. This study reported a decrease of 1.9 on the Beck Depression Inventory II scores in the placebo group compared with a decrease of 1.5 in the active treatment group, a difference that was not statistically significant.

#### Physical Functioning

Two RCTs reported physical functioning measures;^70,^ ^83^ one of these is new to this update.^70^ Arvold et al (fair quality) evaluated a weekly dose of vitamin D_3_ compared with placebo among 90 outpatients (40% female, mean age 58) at a single study center in the United States.^83^ The authors reported findings with the fibromyalgia impact questionnaire, which ranges from 0 (minimal symptoms) to 100 (maximal symptoms). We note the authors stated they selected this questionnaire because it includes symptoms potentially relevant to vitamin D deficiency. The authors observed a statistically significant difference in the change in scores between active treatment and control at 8 weeks followup (−3.7 vs. 1.9, p=0.03). Hansen et al (good quality) evaluated two doses of vitamin D_3_ compared with placebo among women (mean age 61) at a single study center in the United States.^70^ The authors reported findings using a modified Stanford Health Assessment Questionnaire. After 1 year, no significant difference in scores was observed for either of the vitamin D doses compared with placebo (Appendix D Table 7).

#### Infection

One fair-quality RCT that was new to this update evaluated vitamin D_3_ compared with placebo over 5 years of followup.^75^ Participants were between the ages of 25 and 80 and had impaired fasting glucose. Participants were not enrolled based on vitamin D level; however, findings from an unplanned subgroup analysis for participants with baseline serum vitamin D levels less than 20 ng/ml were reported. The authors reported an HR of 0.53 (95% CI, 0.17 to 1.64) for incidence of first urinary tract infection for active treatment compared with placebo among the deficient participants.

### Effect of Vitamin D Treatment in Patient Subgroups

In this section, we summarize findings based on patient subgroups that were specified in our final research plan.

#### Population/Setting

Four studies were conducted among institutionalized populations;^88,^ ^90–92^ two were conducted among mixed community-dwelling and institutionalized populations,^84,^ ^104^ and the rest were conducted exclusively in community-dwelling populations. As noted in the previous section, we identified differences in treatment effect based on setting for mortality. A lower risk of mortality was observed for treatment compared with no treatment among institutionalized populations, while no effect of treatment was observed for community-dwelling participants. We did not observe any difference in treatment effect for fractures (all types) by setting; we did not have enough studies to draw conclusions about the influence of setting on hip fracture incidence. For falls, we did not observe any difference in the incidence of falls by treatment setting. However, when considering the total number of falls, the one study that was conducted in an institutionalized setting reported a larger decrease in the IRD and IRR for active treatment group compared with control group than what was observed among the five studies conducted in community-dwelling populations. However, only one study was conducted in institutionalized settings, which limits our ability to draw definitive conclusions.

The rest of the outcomes reported in the previous section (i.e., diabetes, cardiovascular incidence, cancer incidence, depression, physical functioning, and infection) were reported from studies conducted among exclusively community-dwelling populations, limiting our ability to determine the influence of setting on those outcomes.

#### Age

No studies reported benefits stratified by age. Only two studies reporting KQ 3 outcomes enrolled younger populations (mean age 30 to 40 years).^82,^ ^105^ Findings in these studies appeared similar to findings reported in studies enrolling older participants (mean age 50s, 60s, 70s, and 80s).

#### Race/Ethnicity

Only one study reported benefits of vitamin D treatment stratified by race or ethnicity.^50,^ ^106^ In this study, no mortality events occurred among either the white or African American populations enrolled. With the exception of one study conducted primarily among a Latino population,^76^ the six other studies reporting the race/ethnicity of the enrolled population were conducted among exclusively or majority white populations, and 14 studies did not report race/ethnicity. Thus, our ability to determine the influence of race/ethnicity on outcomes was limited.

#### Sex

About half of the studies reporting KQ 3 outcomes enrolled only females; the rest enrolled both males and females, but none enrolled exclusively males. Of the studies enrolling both sexes, no studies reported harms stratified by sex. For mortality, fracture, and fall outcomes, findings were similar whether reported in female-only or mixed male and female populations. We did not have enough studies to draw conclusions about the impact of sex on treatment effect for other outcomes.

#### Baseline Vitamin D Level

Nineteen studies were conducted among populations with vitamin D deficiency based on a lower serum level (approximately 20 ng/ml), and eight studies used higher thresholds (greater than 20 ng/ml but less than 30 ng/ml). Outcomes for mortality, fractures, and falls were similar between studies using the lower threshold compared with studies using a higher threshold. We did not have enough studies reporting other outcomes to draw conclusions about the impact of baseline vitamin D level on treatment effect for those outcomes.

#### Obesity Status

No studies reported benefits by obesity status, and the mean BMI of enrolled participants was similar across this body of evidence, precluding any assessment of the influence of obesity status on benefits.

#### Levels of Sun Exposure

More than half of the included studies did not provide any information about the level of sun exposure among participants at baseline. Among those that did report baseline sun exposure, no studies reported outcomes by sun exposure status. This characteristic was reported in very different ways across studies, precluding our ability to draw any conclusions about whether benefits vary by sun exposure.

## Harms of Treatment (Key Question 4)

We identified 36 studies (in 52 publications) that reported adverse events from treatment with vitamin D (with or without calcium) compared with a control group (e.g., placebo or no intervention) among vitamin D–deficient adults. These studies varied with respect to how adverse events were specified and ascertained. Overall, we identified five distinct adverse event outcomes reported by studies: total adverse events, serious adverse events, discontinuations due to adverse events, kidney stones, and other harms, which refers to specific adverse events reported by studies. Key findings:

- Adverse events and related harms were similar between active treatment and control groups.
- The evidence was limited for drawing conclusions about differences in harms based on various subpopulations.

### Study Characteristics

The 36 included studies were published over the years 1990 to 2019. Nineteen of these studies were included in the 2014 Evidence Report,^47,^ ^50,^ ^81–84,^ ^88–95,^ ^104,^ ^107–110^ and 17 are new to this update.^70,^ ^71,^ ^74,^ ^78,^ ^105,^ ^111–122^ Sixteen of the studies included for KQ 4 (harms of treatment) also reported KQ 3 (benefit of treatment) outcomes.^50,^ ^70,^ ^71,^ ^74,^ ^78,^ ^81–84,^ ^88–95^ A summary of study characteristics is provided in Table 2. We assessed nine of the studies as good quality;^50,^ ^70,^ ^71,^ ^74,^ ^81,^ ^112,^ ^118,^ ^119,^ ^122^ the rest were assessed as fair quality A common issue among studies that we assessed as fair quality was that these studies included no information about how harms were defined or ascertained. Additional study characteristics are described in Appendix D Table 1 and Table 13 and individual study quality ratings are in Appendix E Tables 1, 2, and 3.

All studies were RCTs; 11 were conducted in the United States,^50,^ ^70,^ ^82,^ ^83,^ ^107,^ ^111,^ ^112,^ ^114,^ ^116,^ ^118,^ ^121^ and one was a multicountry study (United States, Canada, Germany, Mexico). The rest were conducted in Australia,^113,^ ^122^ Canada,^117^ and various European countries.^47,^ ^71,^ ^74,^ ^78,^ ^81,^ ^88–95,^ ^104,^ ^105,^ ^108–110,^ ^115,^ ^119,^ ^120^ Four studies were conducted among institutionalized populations,^88,^ ^90–92^ two were conducted among mixed community-dwelling and institutionalized populations,^84,^ ^104^ and the rest were conducted exclusively in community-dwelling populations.

Eleven studies enrolled participants with serum vitamin D levels less than 20 ng/ml.^50,^ ^71,^ ^78,^ ^82,^ ^84,^ ^89,^ ^91,^ ^110,^ ^112,^ ^119,^ ^121^ Nine studies enrolled participants using a higher serum vitamin D threshold (<22 ng/ml,^81,^ ^113^ <25 ng/ml,^83^ <26 ng/ml,^111,^ ^117^ <27 ng/ml,^70^ <30 ng/ml^105,^ ^115,^ ^120^). Sixteen studies did not require participants to meet specific serum vitamin D level criteria for enrollment, but the baseline serum vitamin D levels reported among the enrolled populations suggested that 90 percent or more of the enrolled participants had baseline levels less than 20 ng/ml in four studies^88,^ ^92,^ ^94,^ ^108^ or less than 30 ng/ml in 12 studies.^47,^ ^74,^ ^90,^ ^93,^ ^95,^ ^104,^ ^107,^ ^109,^ ^114,^ ^116,^ ^118,^ ^122^ Vitamin D assays used by studies varied (e.g., radioimmunoassay, competitive-binding protein assay, LC-MS/MS).

Three studies evaluated vitamin D_2_ as a 2,000 IU daily dose,^47^ a 50,000 IU weekly dose,^112^ or a single 100,000 IU dose.^109^ The rest of the studies evaluated various daily, weekly, monthly, or single doses of vitamin D_3_. In the studies using daily doses, the doses ranged from as low as 400 IU to as high as 4,000 IU, and the studies using weekly doses ranged from 20,000 IU to 50,000 IU weekly. One study used a loading dose of vitamin D,^70^ and two studies titrated the dose of vitamin D to achieve a target serum vitamin D level.^111,^ ^113^ Three studies used a no-intervention control group;^92,^ ^93,^ ^104^ the rest used placebo controls. Five studies included various doses of oral calcium as part of the active treatment intervention.^88,^ ^89,^ ^92,^ ^93,^ ^104^ Nine studies provided calcium to both the active vitamin D treatment group and the control group.^50,^ ^82,^ ^84,^ ^90,^ ^107,^ ^111,^ ^113,^ ^118,^ ^122^ The rest of the included studies did not include any calcium as part of the active or control intervention. The duration of the intervention ranged from a single, one-time dose to 3 years; however, the duration of intervention was less than 6 months in 22 of the 36 studies.

No studies specified adverse events as primary outcomes. With one exception,^93^ primary outcomes included laboratory (e.g., serum vitamin D level), imaging (e.g., bone mineral density), or physical strength measures (e.g., grip strength). Seven studies collected data on adverse events at study visits,^84,^ ^90,^ ^110,^ ^113,^ ^114,^ ^116,^ ^119^ two used followup phone calls,^95,^ ^112^ one used a toll-free call-in line available to participants to report adverse events,^122^ and one study used multiple methods.^81^ Fourteen studies did not report how adverse events were ascertained.^47,^ ^71,^ ^78,^ ^83,^ ^89,^ ^91,^ ^94,^ ^105,^ ^108,^ ^109,^ ^111,^ ^115,^ ^117,^ ^121^ Lastly, a consistent definition for total and serious adverse events was not used across studies.

### Findings

#### Total Adverse Events

Twenty-four studies reported overall adverse events (Appendix D Table 8).^47,^ ^71,^ ^81,^ ^83,^ ^84,^ ^89–91,^ ^94,^ ^95,^ ^105,^ ^108–117,^ ^119,^ ^121,^ ^122^ We assessed five as good quality;^71,^ ^81,^ ^112,^ ^119,^ ^122^ the rest were fair quality. Twelve were new to this update.^71,^ ^105,^ ^111–117,^ ^119,^ ^121,^ ^122^ Three studies were conducted exclusively or predominantly among institutionalized populations.^84,^ ^90,^ ^91^ The rest were conducted exclusively in community-dwelling populations. Three studies used vitamin D_2_,^47,^ ^109,^ ^112^ and the rest used vitamin D_3_. One study used calcium as part of the active treatment intervention,^89^ and five studies used calcium as part of the active and control interventions.^84,^ ^90,^ ^111,^ ^113,^ ^122^ The duration of the intervention ranged from a single, one-time dose to 3 years, and the length of followup ranged from 4 weeks to 3 years.

The incidence of adverse events highly varied by study, ranging from 0 percent to 92 percent across the treatment and control groups. However, within any given study, the incidence of adverse events was generally similar between treatment and control groups. Seven studies reported no adverse events.^83,^ ^91,^ ^109,^ ^111,^ ^115,^ ^117,^ ^121^ However, one of the studies that reported no adverse events noted side effects (e.g., nausea) and discontinuations from the study.^91^ Of the remaining 18 studies, 13 studies reported adverse events by treatment group,^81,^ ^84,^ ^89,^ ^90,^ ^94,^ ^95,^ ^105,^ ^110–114,^ ^119^ whereas four studies reported total adverse events overall (i.e., not by group).^71,^ ^108,^ ^116,^ ^122^ Of these four studies, two reported that no significant difference in adverse events was observed between groups,^71,^ ^122^ one reported that events were “few, mild, and equally distributed between groups,”^108^ and one reported the specific nonserious adverse events that were reported by one to four women in the study.^116^ Of the 14 studies reporting total adverse events by group, only three conducted statistical significance testing, and all reported no significant differences between groups.^89,^ ^110,^ ^119^ Of the 10 studies that did not conduct statistical significance testing, results appeared similar between active treatment and control groups.^81,^ ^84,^ ^90,^ ^94,^ ^95,^ ^105,^ ^111–114^ Although many studies did not list the specific adverse events experienced by participants, those that did reported the following types of adverse events: abdominal discomfort, gastrointestinal issues, fatigue, musculoskeletal symptoms, nontoxic goiter, light-headedness, severe headaches, nausea, rash/hives, weakness, numbness, constipation, and itching.^90,^ ^91,^ ^110–113,^ ^116^

#### Serious Adverse Events

Sixteen RCTs reported serious adverse events (Appendix D Table 9).^50,^ ^71,^ ^74,^ ^78,^ ^82,^ ^84,^ ^89,^ ^94,^ ^105,^ ^107,^ ^108,^ ^111,^ ^112,^ ^116,^ ^120,^ ^122^ We assessed five studies as good quality;^50,^ ^71,^ ^74,^ ^112,^ ^122^ the rest were fair quality. Thirteen were new to this update.^70,^ ^72,^ ^73,^ ^75–77,^ ^113–115,^ ^117–119,^ ^121^ All were conducted exclusively or predominantly among community dwelling participants. Few studies were clear about their definition of a serious adverse event. Two studies used hospitalizations as a proxy for serious adverse events,^108,^ ^120^ and one defined “serious” according to National Institute on Aging guidelines.^50^ Six studies collected information about serious adverse events at study visits,^50,^ ^74,^ ^82,^ ^84,^ ^112,^ ^116^ and one study had a toll-free call-in line to report adverse events as well as a questionnaire at the end of the study.^122^ Eight studies did not report how this outcome was either defined or ascertained.^71,^ ^78,^ ^89,^ ^94,^ ^105,^ ^107,^ ^108,^ ^111,^ ^120^ The treatment duration and length of followup across this body of evidence ranged from 8 weeks to 3 years. One study used vitamin D_2_,^112^ the rest used vitamin D_3_. One study used calcium as part of the active treatment intervention,^89^ and six studies used calcium in both the active treatment and control interventions.^50,^ ^82,^ ^84,^ ^107,^ ^111,^ ^122^

The incidence of serious adverse events ranged from 0% to 29.4% across the groups within the studies; the incidence appeared similar between treatment and control groups, although formal statistical significance testing was not conducted in any study. Seven studies reported zero serious adverse events overall.^71,^ ^78,^ ^105,^ ^111,^ ^112,^ ^116,^ ^122^ Five studies reported serious adverse events but authors indicated that these were most likely unrelated to the study medication.^50,^ ^74,^ ^82,^ ^94,^ ^107^ Examples of such events were knee or hip replacement, syncope, heart failure, and internal bleeding from auto collision. The remaining four studies did not specify the nature of the serious adverse events reported or whether they were thought to be related to the study medication.^84,^ ^89,^ ^108,^ ^120^

#### Discontinuations Due to Adverse Events

Seven RCTs reported treatment discontinuations because of adverse events (Appendix D Table 10).^81,^ ^84,^ ^89,^ ^91–93,^ ^113^ We assessed one as good quality^81^ and the rest were fair quality. One RCT was new to this update.^113^ Two RCTs were conducted among institutionalized populations,^91,^ ^92^ and the rest were conducted exclusively or predominantly among community-dwelling populations. Only one study described how adverse events were ascertained (at study visits every 2 months).^113^ The treatment duration and length of followup ranged from 16 weeks to 3 years. All studies used vitamin D_3_. Three studies included calcium as part of the active treatment intervention^89,^ ^92,^ ^93^ and two used calcium in both the active treatment and control interventions.^84,^ ^113^

Across the studies that reported findings by treatment group, the incidence of discontinuations due to adverse events appeared similar in treatment and placebo groups, though no studies conducted formal statistical significance testing for this outcome. The incidence ranged from 0 percent to 15.8 percent in the vitamin D treatment groups and 0 percent to 17.7 percent in the placebo groups. In one study, Krieg et al reported treatment discontinuations due to the specific adverse event of upper gastrointestinal side effects (0% in the control group, 4.8% in the vitamin D group).^92^ In the one study that did not report by treatment group, Janssen et al reported 11 participants discontinued study treatment due to likely adverse events.^91^

#### Kidney Stones

Ten RCTs reported on kidney stones (Appendix D Table 11).^50,^ ^70,^ ^82,^ ^84,^ ^88,^ ^95,^ ^104,^ ^105,^ ^107,^ ^113^ We assessed two studies as good-quality^50,^ ^70^ and the rest as fair-quality. Two RCTs were new to this update.^70,^ ^105^ One study was conducted among institutionalized populations,^88^ one was conducted among mixed populations of institutionalized and community-dwelling,^104^ and the rest were conducted exclusively or predominantly among community-dwelling populations. Among six RCTs, the self-reported incidence of kidney stones was recorded at study visits.^50,^ ^70,^ ^84,^ ^88,^ ^104,^ ^113^ In one RCT, study nurses contacted participants to assess adverse events, including the incidence of kidney stones.^95^ The remaining three RCTs did not report the method of ascertainment of kidney stones.^82,^ ^105,^ ^107^ The duration of treatment and length of followup across this body of evidence ranged from 8 weeks to 3 years. All studies used vitamin D_3_. Two studies reported the use of calcium as part of the active treatment intervention,^88,^ ^104^ five studies used calcium as part of both the active treatment and control interventions.^50,^ ^82,^ ^84,^ ^107,^ ^113^

In all but one study, the incidence of kidney stones was reported in 0 percent of both the active treatment and control groups. In the study reporting more than zero events, one participant in the lower dose vitamin D (800 IU daily) group reported a kidney stone; no kidney stones were reported in the placebo group or in the higher dose vitamin D group (50,000 IU twice monthly).^70^ This study did not use calcium as part of the active treatment or control intervention.

#### Other Harms

Five RCTs reported on various specific harms, including gastrointestinal side effects (e.g. nausea, diarrhea, epigastric pain, constipation) and minor adverse events (Appendix D Table 12).^50,^ ^88,^ ^90,^ ^104,^ ^118^ We assessed two studies as good quality^50,^ ^118^ and the rest were fair quality. One RCT was new to this update.^118^ Two studies were conducted among institutionalized populations,^88,^ ^90^ one study was conducted among a mixed population of both institutionalized and community-dwelling participants,^104^ and the rest were conducted exclusively among community-dwelling populations. Three RCTs collected self-reported data on side effects at study visits.^50,^ ^88,^ ^118^ Conversely, one RCT^90^ continuously monitored study participants on a long-stay geriatric unit to assess for adverse events and one RCT^104^ did not report how other harms were ascertained. The treatment duration and length of followup ranged from 12 weeks to 2 years. All studies used vitamin D_3_. Two studies included calcium as part of the active treatment intervention,^88,^ ^104^ and three studies used calcium in both the active treatment and control interventions.^50,^ ^90,^ ^118^

One study reported mild gastrointestinal symptoms among nine participants (16.3%) in the active treatment group (vitamin D plus calcium); outcomes for the no-intervention group were not reported.^104^ One study reported two cases of constipation in the vitamin D group compared with 0 cases in participants treated with placebo.^90^ One study reported 16 (8.4%) cases of gastrointestinal disorders in the placebo group compared with 24 (6.1%) in the vitamin D with calcium group (calculated RR, 0.73 [95% CI, 0.40 to 1.33]).^88^ One study reported symptoms potentially attributed to hypercalcemia (pruritis, polydipsia, and polyuria) in two participants in the active treatment groups (control group not reported [NR]).^118^ Lastly, one study reported minor adverse events equally distributed within all vitamin D dose groups among black participants; however, actual values and descriptions of adverse events were not described, and data for white participants were not reported.^50^

### Effect of Vitamin D Treatment in Patient Subgroups

In this section, we summarize findings based on patient subgroups that were specified in our final research plan. Some harm outcomes occurred with very rare frequency, precluding any assessment of variation by subgroup.

#### Population/Setting

Four studies were conducted among institutionalized populations;^88,^ ^90–92^ two were conducted among mixed community-dwelling and institutionalized populations,^84,^ ^104^ and the rest were conducted exclusively in community-dwelling populations. The two studies that included mixed populations did not report harms by population setting (institutionalized vs. community dwelling). As previously noted, the incidence of adverse events varied widely across studies with no differences between active treatment and control; this finding held true whether studies were conducted among community-dwelling or institutionalized populations.

#### Age

No studies reported harms stratified by age. Twelve of the studies reporting KQ 4 outcomes enrolled younger populations (mean age 20s to 40s).^47,^ ^72,^ ^82,^ ^105,^ ^108,^ ^110,^ ^112,^ ^114,^ ^115,^ ^117,^ ^119,^ ^121^ Findings for adverse event outcomes in these studies appeared similar to findings reported in studies enrolling older participants (mean age 50s, 60s, 70s, and 80s).

#### Race/Ethnicity

No studies reported harms stratified by race/ethnicity. Many studies enrolled diverse racial and ethnic populations; of those, none reported harms stratified by race or ethnicity. Four studies enrolled exclusively black participants;^107,^ ^111,^ ^118,^ ^121^ one study enrolled a predominantly South Asian population,^109^ two studies enrolled mixed black and white populations,^50,^ ^82^ and one study enrolled a mixed Asian and white population.^113^ An additional six studies enrolled multiple races/ethnicities, but the majority of participants were white.^70,^ ^114,^ ^116,^ ^117,^ ^119,^ ^122^ As previously noted, the incidence of adverse events varied widely across studies with no differences between active treatment and control; this finding held true whether studies were conducted among exclusively black populations, diverse populations, or all-white populations.

#### Sex

The majority of the studies reporting KQ 4 outcomes enrolled only females. One study enrolled only males,^115^ and the rest enrolled both males and females. Of the studies enrolling both sexes, no studies reported harms stratified by sex. As previously noted, the incidence of adverse events varied widely across studies with no differences between active treatment and control, and this finding held true whether studies were conducted among female or mixed populations.

#### Baseline Serum Vitamin D Level

Twelve studies were conducted among populations with deficiency defined based on a lower serum level (approximately 20 ng/ml); nine studies used higher thresholds (greater than 20 ng/ml but less than 30 ng/ml). As previously noted, the incidence of adverse events varied widely across studies with no differences between active treatment and control, and this finding held true whether studies were conducted using lower or higher thresholds for defining deficiency.

#### Obesity Status

No studies reported harms by obesity status, and the mean BMI of enrolled participants was similar across this body of evidence, precluding any assessment of the influence of obesity status on harms.

#### Levels of Sun Exposure

More than half of the included studies did not provide any information about the level of sun exposure among participants at baseline. Among those that did report baseline sun exposure, no studies reported adverse event outcomes by sun exposure status. This characteristic was reported in very different ways across studies, precluding our ability to draw any conclusions about whether adverse events vary by sun exposure.