# Chapter 2 Methods

## Key Questions and Analytic Framework

The EPC investigators, USPSTF members, and AHRQ Medical Officers developed the scope and key questions (KQs) for this review. The analytic framework illustrates the KQs that guided the review (Figure 1). The KQs for this update were similar to the KQs used in the previous review for the USPSTF and were as follows:

1. a. Does screening for vitamin D deficiency improve health outcomes?
  b. Does screening efficacy vary among patient subpopulations at higher risk for vitamin D deficiency (e.g., persons residing in institutions, persons with obesity, persons with low levels of sun exposure, or older adults) or vary by race/ethnicity?
2. What are the harms of screening for vitamin D deficiency?
3. a. Does treatment of vitamin D deficiency with vitamin D improve health outcomes?
  b. Does treatment efficacy vary among patient subpopulations at higher risk for vitamin D deficiency (e.g., persons residing in institutions, persons with obesity, persons with low levels of sun exposure, or older adults) or vary by race/ethnicity?
4. a. What are the harms of treatment of vitamin D deficiency with vitamin D?
  b. Do harms vary among patient subpopulations at higher risk for vitamin D deficiency (e.g., persons residing in institutions, persons with obesity, persons with low levels of sun exposure, or older adults) or vary by race/ethnicity?

Figure 1 Analytic Framework for Systematic Review of Screening for Vitamin D Deficiency in Adults

Abbreviation: KQ=key question.

Figure 1 is titled “Analytic Framework for Systematic Review of Screening for Vitamin D Deficiency in Adults.” This figure depicts the key questions (KQs) within the context of the eligible populations, screenings/interventions, comparisons, outcomes, timing, and settings. On the left, the population of interest is specified as asymptomatic adults without underlying disorders of bone metabolism and who are not known to be vitamin D deficient. Moving from left to right, the figure illustrates the overarching question (key question 1): Does screening for vitamin D deficiency improve health outcomes (i.e., reduce mortality, incidence of fractures and falls, incidence of cancer, cardiovascular disease, diabetes, dementia, autoimmune disease, infections, improve physical functioning and quality of life)? The figure depicts the pathway from screening for vitamin D deficiency to determination of whether person is vitamin D deficient or not, to intermediate outcomes (improved physiologic parameters such as bone mineral density, blood pressure, glucose and lipid levels, improved physical fitenss measures such as grip strength and timed up and go tests). Key question 2 is depicted in the pathway to assess harms from screening. Key question 3 in the pathway assesss health outcomes from treatment for persons identified as vitamin D deficient, and key question 4 assesses harms from treatment.

In addition to our KQs, we looked for evidence related to three CQs.

1. What are the various assays for measuring serum vitamin D (including total and free 25-hydroxyvitamin D and 1,25-dihydroxycholecalciferol), and what is known about the intermethod and interlaboratory variability of these assays?
2. In observational studies, what is the association between vitamin D use or serum vitamin D levels and the incidence of selected health outcomes (i.e., mortality, fractures, falls, cardiovascular disease, cancer, diabetes, dementia, autoimmune disease, and infections)?
3. In RCTs, what is the effect of vitamin D treatment on selected intermediate outcomes (i.e., bone mineral density, blood pressure, glucose levels, lipid levels, and measures of physical or muscle strength)?

We do not show these CQs in the analytic framework because they were not analyzed using the same systematic review process as the KQs. Findings related to the CQs are summarized in Appendix A.

## Data Sources and Searches

### Data Sources

We searched the following electronic bibliographic databases for this review: MEDLINE^®^ via PubMed, Embase, the Database of Abstracts of Reviews of Effects, the National Institutes of Health (NIH) Research-Health Technology Assessment database, and Health Services Research Project database. We searched the following clinical trial registries: Cochrane Central Register of Controlled Trials, clinicaltrials.gov, and the World Health Organization International Clinical Trials Registry Platform, which consolidates many non-U.S. clinical trials registries. Our literature search also included the National Institute for Health and Care Excellence Web site, the NIH Web site, the Centers for Disease Control and Prevention (CDC) Web site, the National Institute for Health Research (United Kingdom), and Web sites of relevant professional societies.

### Search Strategy

We searched MEDLINE (via PubMed), Embase, and the Cochrane Library for English-language articles from January 1, 2013, through March 12, 2020, building on the literature included in the prior 2014 evidence review for the USPSTF. We used Medical Subject Headings (MeSH) terms when available and keywords to describe relevant screening and treatment interventions, populations, and study designs. The complete search terms and limits are detailed in Appendix B1. We also searched the clinicaltrials.gov registry and the World Health Organization International Clinical Trials Registry Platform and Health Services Research Projects in Process. To supplement the electronic database searches, we screened relevant systematic reviews and reference lists of included articles. We conducted surveillance of the literature through November 30, 2020.

## Study Selection

We developed inclusion and exclusion criteria for selecting studies based on populations, interventions, comparators, outcomes, timing, settings, and study designs; these are described in detail in Appendix B2. For all KQs, we selected systematic reviews similar in scope, controlled trials (randomized or nonrandomized), or case-control studies nested within an RCT that were conducted in nonpregnant adults. For the KQs on harms (KQs 2 and 4), controlled observational studies were also eligible for selection. Only studies conducted in the 51 countries categorized as very high on the 2016 Human Development Index were selected.^64^ For the KQs on treatment benefit or harms (KQs 3 and 4), we required 90 percent or more of study participants to have serum levels of less than 30 ng/ml or for study results to be reported stratified by vitamin D level. For all KQs, we excluded studies for which participants were selected for a specific clinical condition to assess the benefit of adding vitamin D to existing therapy for that condition. For example, we excluded studies that selected participants with asthma to evaluate the impact of adding vitamin D to an existing asthma regimen. For the KQs on the benefits and harms of screening (KQs 1 and 2), we selected studies that compared screening with a serum vitamin D assay with no screening. For the KQs on treatment benefit or harms (KQs 3 and 4), we selected studies that compared vitamin D_2_ or D_3_ treatment (with or without calcium) with placebo or no treatment. For the KQs on the benefits of screening or treatment (KQs 1 and 3), we selected studies that reported mortality, quality of life, self-reported physical functioning, or the incidence of specific morbidities including fractures, falls, diabetes, cardiovascular events, cancer, autoimmune disease, dementia, or infection and required outcomes to be measured after at least 8 weeks. For the KQs on the harms of screening or treatment (KQs 2 and 4), we selected studies that reported on harms of screening (e.g., anxiety, labeling) or treatment (e.g., toxicity, renal harms, adverse events), and we did not restrict study duration.

Two independent reviewers screened titles and abstracts and then full-text articles for selection; disagreements were resolved by discussion or by a third reviewer. We included English-language studies that met all study selection criteria and that were fair or good methodological quality. We reassessed studies included in the prior 2014 review^2^ against the study selection and methodological quality criteria for this update.

## Quality Assessment and Data Extraction

For each included study, one reviewer abstracted relevant study characteristics (i.e., population, intervention, comparator) and data for eligible outcomes into a structured form. A second reviewer checked all data for completeness and accuracy, and the lead investigator reviewed all abstracted information for consistency across included studies. We contacted study authors to clarify study data when needed.

Two senior reviewers independently assessed each study’s methodological quality using the Cochrane ROB 2.0 instrument^65^ and the predefined criteria developed by the USPSTF (Appendix B3), which uses study methodological quality ratings of poor, fair, and good. In addition to assessing the methodological quality of any newly identified studies, we reassessed the methodological quality of all previously included studies. Studies reporting multiple outcomes may have been assigned different quality ratings for different outcomes. Disagreements in study quality ratings were resolved through discussion.

## Data Synthesis and Analysis

We synthesized data in tabular and narrative formats. For each KQ, we assessed whether a quantitative synthesis was appropriate by evaluating the number of studies available and the clinical and methodological heterogeneity present among available studies based on established guidance, which includes evaluating the similarities in study population, medication, dose, and frequency and similarities in timing and specification of outcomes.^66^ When at least three similar studies were available, we performed a quantitative synthesis to generate pooled estimates of the absolute risk difference (ARD), the relative risk (RR), the incidence rate difference (IRD), or the incidence rate ratio (IRR). Specifically, we generated separate pooled analyses based on study population (community-dwelling vs. institutionalized) when at least three studies were available for each population. We used random effects models with the inverse-variance weighted method of DerSimonian and Laird in Stata (Version 16).^67^ For rare event outcomes, such as mortality, we also conducted sensitivity analyses using other estimators and models with and without continuity corrections to assess robustness of our main findings. We assessed statistical heterogeneity of findings with the I^2^ statistic; an I^2^ between 0 and 40 percent might not be important, 30 to 60 percent may represent moderate heterogeneity, and 50 to 90 percent may represent substantial heterogeneity.^68^ We did not have enough studies for any single outcome to formally assess publication bias through visual inspection of a funnel plot.

We assessed the strength of evidence (SOE) based on AHRQ’s Methods Guide for Effectiveness and Comparative Effectiveness Reviews, which specifies the assessment of study limitations, directness, consistency, precision, and reporting bias for each intervention comparison and major outcome of interest.^69^ Two senior reviewers independently developed initial SOE assessments for each relevant outcome; discrepancies were resolved through discussion and consultation with a third senior reviewer. We considered all outcomes to be direct because they were health outcomes selected by the USPSTF as important and relevant for consideration. For the benefits of treatment (KQ 3), we conducted SOE assessments focused on the studies with community-dwelling populations where possible. We evaluated the consistency domain by visually inspecting the forest plot and with the I^2^ statistic for pooled outcomes and by assessing the range of estimates and confidence intervals of individual studies where pooling was not possible. We also assessed whether any inconsistency could be explained by study population (e.g., community-dwelling vs. institutionalized populations, serum levels used to define deficiency [20 ng/ml vs. 30 ng/ml]), intervention (vitamin D with or without calcium), or study design characteristics. We evaluated the precision domain by calculating the optimal information size (i.e., sample size needed in a single adequately powered trial required to generate a precise estimate) and by evaluating whether the confidence intervals around pooled estimates crossed clinically meaningful thresholds of benefit or harm.

## U.S. Preventive Services Task Force Involvement

This review was funded by AHRQ. Staff of AHRQ and members of the USPSTF participated in developing the scope of work and will review draft reports, but the authors are solely responsible for the content.

## Expert Review and Public Comment

The draft research plan was posted for public comment on the USPSTF Web site from October 25, 2018, to November 21, 2018. In response to public comments, the USPSTF modified KQs 1b, 3b, and 4b to include race/ethnicity as a characteristic of interest. The USPSTF also added dementia, autoimmune diseases, and infections to the list of eligible health outcomes. In addition to these changes in scope, we clarified our analytic approach for KQ 3 with respect to stratifying analyses by threshold used to define deficiency (20 ng/mL vs. 30 ng/mL) and by population (community dwelling vs. institutionalized). A final research plan was posted on the USPSTF’s Web site in January 2019.

A draft version of this report was reviewed by four invited content experts, four individuals at three Federal partner agencies, USPSTF members, and AHRQ Medical Officers. Experts were selected based on their expertise with fundamental methodologic and content aspects of the review and were selected to obtain diverse informed perspectives. All comments were considered, and we revised the draft report to address relevant scientific concerns, enhance clarity, and ensure accuracy. All reviewer comments were shared with the USPSTF during its deliberation. A draft version of this report was posted for public comment on the USPSTF Web site from September 22, 2020, to October 20, 2020. All comments were considered, and additional minor modifications were made in response to comments received to add additional detail or enhance clarity.