# Chapter 1 Introduction

## Purpose

This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2014 statement on screening for vitamin D deficiency in adults.^1^ The 2014 USPSTF statement was informed by a 2014 systematic review conducted by the Pacific Northwest Evidence-based Practice Center (EPC).^2^ The 2014 statement is summarized as follows:

- The USPSTF concluded that the current evidence is insufficient to assess the balance of benefits and harms of screening for vitamin D deficiency in asymptomatic adults (I statement).

## Condition Definition

Vitamin D is a fat-soluble compound that performs a critical role in calcium homeostasis and bone metabolism and affects many other cellular regulatory functions outside the skeletal system.^3–5^ Vitamin D needs are met through synthesis of vitamin D in the skin after sun exposure and through foods that naturally contain vitamin D or that are fortified with vitamin D.^6^

Vitamin D deficiency refers to serum levels of vitamin D [serum total hydroxyvitamin D, or 25(OH)D] that are inadequate to support bodily needs and historically have been defined based on serum level of vitamin D at which an increase in circulating level of parathyroid hormone (PTH) was observed. No consensus exists regarding the precise serum levels of vitamin D that represent optimal health or deficiency. The National Academy of Medicine (formerly the Institute of Medicine [IOM]) defined the recommended dietary allowance for adults corresponding to a serum level of 20 ng/ml, which is the serum level they estimated would cover vitamin D requirements for 97.5% of the population.^3,^ ^7^ The IOM also reported that a serum level of 16 ng/ml covers the vitamin D requirements for half of the population.^3,^ ^7^ Relative to bone health, the IOM also reported that persons are at risk of deficiency at serum levels below 12 ng/ml, though some persons may be at risk between serum levels of 12 ng/ml and 20 ng/ml.^3^ The Endocrine Society considers serum vitamin D levels of 20 ng/ml or less as deficient and considers levels between 21 and 29 ng/ml as insufficient.^8^ Because vitamin D requirements vary across individuals, it is not possible to define a precise threshold below which deficiency is present; thus, thresholds used may more accurately reflect thresholds for which individuals may be at “at risk” for deficiency.

## Prevalence and Burden of Disease/Illness

The prevalence of vitamin D deficiency varies based on the serum level used to define deficiency. According to the National Health and Nutrition Examination Survey (NHANES), which used the liquid chromatography-tandem mass spectrometry (LC-MS/MS) assay to measure 25(OH)D levels during 2011 to 2014 survey, 5 percent of the population age 1 year or older had levels less than 12 ng/mL, 18 percent had levels between 12 ng/ml and 19 ng/mL, 73 percent had levels between 20 ng/ml and 50 ng/ml, and 4 percent had levels greater than 50 ng/ml.^9^ NHANES data from earlier years (2003-2004) suggest the prevalence of serum levels less than 20 ng/ml among persons ages 70 years or older may be as high as 30 percent.^10^ The Institute of Medicine (IOM) developed a statistical procedure to derive group prevalence estimates of nutritional inadequacy. This statistical model found that 19 percent of the population was at risk of 25(OH)D levels less than 20 ng/ml.^11^

The prevalence of vitamin D deficiency is 1.3 to 3 times higher in winter than summer months.^12^ The prevalence also varies by race and ethnicity. Depending on the serum threshold used to define deficiency, the prevalence of deficiency is 2 to 10 times higher in non-Hispanic black than in non-Hispanic white individuals. Hispanic individuals have a prevalence of deficiency that is 1.5 to 3 times the rate of non-Hispanic white individuals.^12–15^ However, these prevalence estimates are based on total 25(OH)D levels, and controversy remains about whether this is the best measure of vitamin D status among different racial and ethnic groups. More research is needed to determine the best indicator of vitamin D deficiency as it relates to clinical outcomes (i.e., bone health), especially in nonwhite populations.

In the most recent NHANES analyses examining 25(OH)D levels over time (as measured by or calibrated to the LC-MS/MS assay), mean 25(OH)D showed no changes from 1988 to 2006, but during 2007 to 2010, the mean measured 25(OH)D was modestly higher.^12^ The groups that showed the largest 25(OH)D increases included those who were older, female, non-Hispanic white, and those who used vitamin D supplements.

## Etiology and Risk Factors

Vitamin D is synthesized in the skin under the influence of ultraviolet (UV) light and can also be obtained from dietary sources and supplements. In the United States, the main dietary sources of vitamin D are fortified foods such as milk, milk products, orange juice, and cereals, as well as supplements. Naturally occurring foods that contain vitamin D include fatty fish, egg yolk, and mushrooms that have been exposed to sunlight or UV radiation. In healthy individuals, vitamin D deficiency most often results from either decreased dietary intake, reduced sun exposure, and/or reduced ability to produce vitamin D (e.g., due to increased skin pigmentation, aging, or both).^16^

Vitamin D has a variety of actions on calcium, phosphate, and bone metabolism. Low 25(OH)D concentrations are associated with impaired intestinal calcium and phosphate absorption, negative calcium balance, phosphaturia, and a compensatory rise in PTH, which results in excessive bone resorption. Severe vitamin D deficiency causes a mineralization defect in the skeleton.^16^ In children, vitamin D deficiency results in skeletal deformities classically called “rickets.” In adults, severe vitamin D deficiency can result in osteomalacia, which is associated with decreased bone mineral density (BMD), diffuse bone and joint pain, muscle weakness, and difficulty walking.^17^ Although rickets and osteomalacia are now uncommon in the United States, concern exists about subclinical vitamin D deficiency (i.e., low serum levels in the absence of overt symptoms), which may affect musculoskeletal health. Whether there is an association between subclinical deficiency and extraskeletal health is an area of active research.^6,^ ^18–22^

Little or no UVB exposure (e.g., due to winter season, high latitude, and sun avoidance) is also associated with an increased risk for low vitamin D levels.^13,^ ^14,^ ^23–25^ Although sunscreen reduces the skin’s ability to produce vitamin D in response to UVB in controlled research settings,^26^ this association has not been found in population-based studies.^12,^ ^23,^ ^27^ This finding in population-based studies is likely due to incomplete sunscreen application^28^ or because subjects who use sunscreen are more likely to be exposed to the sun for extended periods, or both.^29^ Low dietary vitamin D intake and/or lack of vitamin D supplements may also be associated with lower 25(OH)D levels,^12^ with a 2- to 5-fold increased risk of vitamin D deficiency when defined as serum levels less than 20 ng/mL.^13–15^

Obesity is associated with lower 25(OH)D levels,^12,^ ^30^ translating into a 1.3- to 2-fold increased risk of being vitamin D deficient depending on threshold used to define deficiency.^13–15,^ ^30^ The exact mechanism for this finding is not completely understood. Older theories speculated that it was due to sequestration of vitamin D in fat cells^7^ or due to lifestyle differences (e.g., lower physical activity levels or lower dietary vitamin D intake); however, newer theories suggest possibly altered metabolism of 25(OH)D in the liver. Little physical activity,^13,^ ^14,^ ^24^ low education attainment,^31^ and low health status^15,^ ^23^ are modestly associated with lower vitamin D levels in some studies. Differences in diet, supplement use, and UV exposure, however, could be mediating factors.

Cross-sectional studies have reported inconsistent findings on the association between older age and prevalence of vitamin D deficiency, although there may be an increased risk in persons age 85 years or older, but this may be related to less sun exposure, decreased dietary consumption, or both.^13–15,^ ^24,^ ^25^ The prevalence of deficiency by sex is also mixed.^12,^ ^14,^ ^15,^ ^25^

A significant proportion of the variability in 25(OH)D levels among persons is not explained by traditional risk factors, which seem to account for only 20 to 30 percent of the variation in 25(OH)D levels.^24,^ ^32^ Genetic factors may influence serum 25(OH)D concentrations, including genetic variants of vitamin D–metabolizing genes.^33^

## Rationale for Screening/Screening Strategies

The rationale for screening for vitamin D among asymptomatic adults is to identify a deficiency early and offer treatment before potential adverse clinical outcomes (e.g., falls, fractures, other outcomes) occur. Testing vitamin D levels in individuals with conditions known to be associated with low vitamin D levels (e.g., chronic kidney disease) is not within the scope of this review.

### Screening Tests

Total 25(OH)D is currently considered the best marker of vitamin D status because it incorporates endogenous synthesis from UV exposure and dietary intake from food or supplements or both.^7,^ ^34^ Total 25(OH)D is defined as the sum of 25 (OH)_2_ and 25(OH)_3_ and is measured by both binding and chemical assays. Binding assays include competitive protein binding assays, radioimmunoassays, and chemiluminescence immunoassays. Chemical assays include HPLC (liquid chromatography [LC] with UV detection), liquid chromatography–mass spectrometry (LC-MS), and LC-MS/MS. Historically, it has been difficult to measure 25(OH)D accurately, which has resulted in assay variability and bias with likely misclassification of vitamin D status, especially for levels close to a threshold, in both research studies and clinical practice. Currently, LC-MS/MS is considered a reference method; however, it is complex to perform and can still be subject to variation and error. Since the establishment of the Vitamin D Standardization Program (VDSP) in 2010, great strides have been made toward standardizing vitamin D assays. However, there are limited data on how quickly this standardization is being adopted by small and large commercial laboratories and as part of previous and ongoing research studies. Although several vitamin D metabolites are under active investigation as markers of vitamin D status, their association with clinical outcomes is much less studied than 25(OH)D, and the research on alternative assays suffers from the same assay standardization issues that have plagued 25(OH)D research until the recent development of the VDSP. Findings from a contextual question (CQ 1), located in Appendix A, provide additional information about vitamin D assays and other vitamin D measures proposed as potential markers of vitamin D status.

### Interventions/Treatment

For healthy individuals not known to be vitamin D deficient, the recommended dietary allowance for vitamin D is 600 international units (IU) per day for adults ages 18 to 70 years and 800 IU per day for adults over 70 years of age.^7^ Other expert bodies, however, suggest that the daily intake of vitamin D may need to be higher (e.g., 1,000 to 2,000 IU per day) to avoid vitamin D deficiency, especially in high-risk individuals.^8,^ ^35–39^ Vitamin D deficiency can be treated by increased dietary intake, vitamin D supplementation, and increased UV exposure. UV exposure is usually not recommended because of increased skin cancer risk. Although few foods naturally contain vitamin D, several food products (e.g., milk, cereals) are available that are fortified with vitamin D. A 2014 evidence report commissioned by the Agency for Healthcare Research and Quality (AHRQ) for the Effective Healthcare Program that assessed the effect of vitamin D and calcium intake on various health outcomes concluded that there was “good” evidence that dietary intake of vitamin D increases serum 25(OH)D levels among adults.^40^

Primary care physicians often treat vitamin D deficiency with oral vitamin D supplementation. There are two commonly available forms: vitamin D_3_ (cholecalciferol) and vitamin D_2_ (ergocalciferol) available as either a prescription or as an over-the-counter supplement. Although a 2012 meta-analysis of seven randomized trials concluded that vitamin D_3_ treatment increased serum 25(OH)D more efficiently than vitamin D_2_,^41–44^ there was significant between-study heterogeneity, and the difference was of uncertain clinical significance. Although more recent trials have also found that vitamin D_3_ may be more efficient in raising total 25(OH)D levels than vitamin D_2_ treatment,^45–47^ the clinical significance on health outcomes remains unclear. Neither the Endocrine Society nor the IOM recommends using vitamin D_3_ over vitamin D_2_.^7,^ ^8^

There are multiple forms (e.g., tablet, gel capsule, injectables), dosages (e.g., 200 to 500,000 IU), and dosing regimens (e.g., daily, weekly, monthly, yearly) for vitamin D treatment. In those with normal absorption, every additional daily equivalent of 100 IU of vitamin D_3_ is estimated to increase serum 25(OH)D concentrations by approximately 0.7 to 1.0 ng/mL.^48,^ ^49^ However, these effects vary depending on study participants’ characteristics such as baseline serum 25(OH)D status, body mass index (BMI), and the duration of treatment.^40,^ ^50^ Despite the variability in effect, evidence from 26 randomized, controlled trials (RCTs) summarized in the previously discussed AHRQ evidence review reported a definitive dose-response between supplemental vitamin D use and increased serum vitamin D levels.^22^ In practice, injectable vitamin D is rarely used and is mainly reserved for patients with gastrointestinal conditions or malabsorptive syndromes.

The amount of vitamin D required to effectively treat vitamin D deficiency also depends on an individual’s vitamin D absorptive capacity, their capacity to convert vitamin D to 25(OH)D in the liver, their baseline serum level, and genetic determinants. Because of these factors, many different dosages and dosage patterns are used clinically, but there are little data on the optimal regimen. The Endocrine Society, for example, recommends that adults with serum levels less than 30 ng/mL be treated with 50,000 IU of vitamin D once a week or 6,000 IU per day for 8 weeks followed by maintenance therapy of 1,500 to 2,000 IU per day. In obese people, the Endocrine Society recommends increasing the dose 2- or 3-fold.^8^ Other experts recommend using high weekly dosing for those with 25(OH)D levels of less than 12 ng/mL and suggest daily dosing of 600 IU to 1,000 IU per day for those with levels between 12 and 30 ng/mL. Some recommend caution when prescribing intermittent high-dose vitamin D (e.g., monthly and yearly dosing) because of evidence from some studies that it may be associated with increased risk of falls and fractures;^42–44,^ ^51^ however, not all studies have not noted such adverse effects,^21^ so more research is needed. Although optimal monitoring strategies during vitamin D treatment are also not well studied, most experts recommend measuring 25(OH)D levels after 2 to 4 months of high-dose therapy.^52^ Symptoms of vitamin D intoxication are unlikely below serum levels of 150 to 200 ng/ml, although some believe serum concentrations greater than 50 ng/mL may be associated with potential adverse effects.^7,^ ^53–56^

Vitamin D is often administered with oral calcium. Although some meta-analyses have suggested possible differences in health outcomes and harms between vitamin D alone and vitamin D with calcium,^21,^ ^57,^ ^58^ the previously discussed AHRQ systematic review concluded the addition of calcium to vitamin D had inconsistent associations with health outcomes.^22^ A 2016 clinical guidelines statement from the National Osteoporosis Foundation and the American Society for Preventive Cardiology stated that taking calcium amounts not exceeding 2,000 to 2,500 mg/day with vitamin D was safe.^59^ A recent systematic review in support of the USPSTF’s recommendation on supplementation using vitamin D with or without calcium for fracture prevention among nondeficient adults also found no differences between vitamin D alone or with calcium on fractures, cardiovascular disease, or cancer.^60^

## Current Clinical Practice

The prevalence of vitamin D deficiency screening by primary care clinicians in the United States is not known; however, evidence from other countries suggests increasing incidence of screening over the past several decades.^61–63^ Table 1 summarizes the recommendations of professional organizations related to screening for vitamin D deficiency in adults or vitamin D supplementation. Two organizations (Endocrine Society, American Association of Clinical Endocrinologists) recommend screening serum vitamin D levels in individuals at risk for deficiency, and one organization (American Society for Clinical Pathology) recommends against population-based laboratory screening. The rest of the organizations listed in Table 1 have recommendations related to vitamin D intake but are not specific to laboratory screening for deficiency.

Table 1 Summary of Recommendations for Screening for Vitamin D Deficiency in Adults^*^

Organization (Year); Title | Recommendations
American Academy of Family Physicians (2014)^136^; Clinical preventive service recommendation. Vitamin D deficiency: screening. | There is insufficient evidence to recommend screening the general population for vitamin D deficiency. Treating asymptomatic individuals with identified deficiency has not been shown to improve health.; Routine vitamin D supplementation in community-dwelling adults is not recommended.
American Association of Clinical Endocrinologists (2016)^137^; Clinical Practice Guidelines for the Diagnosis and Treatment of Postmenopausal Osteoporosis | Measure serum 25-hydroxyvitamin D (25[OH]D) in patients who are at risk for vitamin D insufficiency, particularly those with osteoporosis.
American Congress of Obstetricians and Gynecologists (2011)^138^; Practice Bulletin No. 129. Osteoporosis | - Recommend testing for vitamin D as part of evaluation of secondary causes of osteoporosis.
American Geriatric Society (2014)^139^; American Geriatrics Society Consensus Statement on vitamin D for Prevention of Falls and Their Consequences | - Statement 1a: Clinicians are strongly advised to recommend vitamin D supplementation of at least 1,000 IU per day, as well as calcium supplementation, to community-dwelling older adults (>65 years of age) to reduce the risk of fractures and falls.; - Statement 3: Clinicians should review older adults’ vitamin D intake from all sources (diet, supplements, sunlight) and discuss strategies to achieve a total vitamin D input associated with fall and fracture prevention (30 ng/ml). A total daily intake of 4,000 IU across all sources is recommended.; - Statement 4a: Routine laboratory testing for 25(OH)D serum concentrations before supplementation begins is not necessary.
American Society for Clinical Pathology (2014)^140^; Choosing Wisely campaign | Do not perform population-based screening for vitamin D deficiency.
Endocrine Society (2011)^8^; Evaluation, treatment, and prevention of vitamin D deficiency: an Endocrine Society clinical practice guideline. | - Recommend screening for vitamin D deficiency in individuals at risk for deficiency. Factors increasing risk for vitamin D deficiency include obesity, pregnancy, lactation, darker skin tone, use of sunscreen, use of anticonvulsant medications, glucocorticoids, antifungals, or other medications for AIDS as well as chronic granuloma-forming disorders, some lymphomas, and primary hyperparathyroidism.; - Do not recommend population screening for vitamin D deficiency in individuals who are not at risk (strong recommendation, high-quality evidence).; - Recommend using the serum circulating 25-hydroxyvitamin D [25(OH)D] level, measured by a reliable assay, to evaluate vitamin D status in patients who are at risk for vitamin D deficiency.; - Recommend treatment and prevention for patients who are vitamin D deficient using either vitamin D_2_ or vitamin D_3_:; All adults, treatment with 50,000 IU of vitamin D_2_ or vitamin D_3_ once a week for 8 weeks or its equivalent of 6,000 IU of vitamin D_2_ or vitamin D_3_ daily to achieve a blood level of 25(OH)D above 30 ng/ml, followed by maintenance therapy of 1,500–2,000 IU/day (weak recommendation, high-quality evidence).
National Academy of Medicine (formerly Institute of Medicine) (2011)^7^; The 2011 report on dietary reference intakes for calcium and vitamin D from the Institute of Medicine: what clinicians need to know. | No recommendations specific to screening.; Recommendations specific to vitamin D intake:; 600 IU/day for individuals 1 to 70 years of age; 800 IU/day for individuals >70 years of age
National Osteoporosis Foundation (2018)^141^; Calcium and Vitamin D | No recommendations specific to screening.; Recommendations specific to vitamin D intake:; Adults <50 years of age need a total of 400 to 800 IU of vitamin D every day.; Adults ≥50 years of age need a total of 800 to 1,000 IU of vitamin D every day.

* We searched for both stand-alone guidelines related to vitamin D screening, but also looked for screening recommendations that may have been embedded in related clinical practice guidelines, such as those related to general bone health or osteoporosis.

Abbreviations: 25OH(D)=vitamin D; IU=international units.