# Appendix F Additional Results

Appendix F Figure 1 Effect of Vitamin D Treatment on Mortality by Baseline Vitamin D Level (Community-Dwelling Participants)

Figure Notes: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points)

Abbreviations: CI=confidence interval; Cntl=control; RD=absolute risk difference; RR=relative risk; Tx=treatment; Vit=vitamin; wk=weeks; yr=years.

Appendix F Figure 1 is titled “Effects of Vitamin D vs. Control on Mortality by Vitamin D Level, Community-dwelling Participants.” The figure displays a forest plot reporting the absolute risk difference of mortality for 8 studies stratified by their serum vitamin D level defined as deficiency. Four studies defined deficiency as less than 30 ng/mL (Grimnes, 2011; Hin, 2016; Hansen, 2015; Karkkainen, 2010) and 4 studies defined deficiency as less than 20 ng/mL (Brazier, 2005; Gallagher, 2012; Gallagher, 2014; Lips, 2010). Of those defining deficiency as less than 30 ng/mL 1 included calcium in the active arm (Karkkainen, 2010) and 3 did not include calcium (Grimnes, 2011; Hin, 2016; Hansen, 2015). The pooled absolute risk difference for all of these 4 studies was −0.3% (95% CI, −2.0% to 1.3%, , I2=47.1%). Of the 4 studies that defined deficiency as less than 20 ng/mL, 3 included calcium in both arms (Gallagher, 2012; Gallagher, 2014; Lips, 2010) and one included calcium in only the active arm (Brazier, 2005). The pooled risk difference for studies defining deficiency as less than 20 ng/mL was 0.6 percent (95% CI, −0.9% to 2.0%, I2=0%). The pool risk difference of all eight studies was 0.3 percent (−0.6% to 1.1%, I2=0%) No individual studies reported a significant difference between active treatment and control.

Appendix F Figure 2 Effect of Vitamin D Treatment on Mortality by Calcium Use (Community-Dwelling Participants)

Figure Notes: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points).

Abbreviations: CI=confidence interval; Cntl=control; RD=absolute risk difference; RR=relative risk; Vit=vitamin; Tx=treatment; wk=weeks; yr=years.

Appendix F Figure 2 is titled “Effects of Vitamin D vs. Control on Mortality by Calcium Use. This figure displays forest plots reporting the absolute risk difference of eight studies stratified by calcium use. Three studies did not use calcium (Grimnes, 2011; Hin, 2016; Hansen, 2015), 2 studies included calcium only in the active arm (Brazier, 2005; Karkkainen, 2010), and 3 studies included calcium in both arms (Gallagher, 2012; Gallagher, 2014; Lips, 2010). The pooled risk difference for those that did not use calcium was −1.3 percent (95% CI, −4.2 to 1.5, I2=52.1%). The pooled risk difference for those that included calcium only in the active arm was 0.8 percent (95% CI, −0.4 to 2.1, I2=0%). The pooled risk difference for those that included calcium in both arms was 0.4 percent (95% CI, −1.2 to 1.9, I2=0%). The overall pooled risk difference of all eight studies was 0.3 percent (95% CI, −0.6 to 1.1, I2=0%). No individual studies reported a significant difference between active treatment and control.

Appendix F Figure 3 Effect of Vitamin D Treatment on Fractures by Baseline Vitamin D Status (Community-Dwelling Participants)

Figure Notes: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage point).

Abbreviations: CI=confidence interval; Cntl=control; Fx=fracture; RD=absolute risk difference; RR=relative risk; Tx=treatment; Vit=vitamin; wk=weeks; yr=years.

Appendix F Figure 3 is titled “Effects of Vitamin D vs. Control on Fractures by Vitamin D Level, Community-dwelling Participants.” This figure displays a forest plot that reports absolute risk difference stratified by the vitamin D level used to defined deficiency. Three studies defined deficiency as less than 20 ng/mL (Bislev, 2018; Scragg, 2017; Pfeifer, 2000) and 3 studies define deficiency as less than 30 ng/mL (Hin, 2016; Hansen, 2015; Pfeifer, 2009). The pooled absolute risk difference for studies defining deficiency as less than 20 ng/mL was −0.5 (95% CI, −2.6% to 1.7%, I2=0%). The pooled absolute risk difference for studies defining deficiency as less than 30 ng/mL was −0.1 percent (95% CI, −6.0 to 4.0, , I2=63.4%). The overall pooled absolute risk difference of all 6 studies combined was −0.3 percent (95% CI, −2.1% to 1.6%, I2­=13.0%). No individual studies reported a significant difference between active treatment and control.

Appendix F Figure 4 Effect of Vitamin D Treatment on Fractures by Calcium Use (Community-Dwelling Participants)

Figure Notes: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points).

Abbreviations: CI=confidence interval; Cntl=control; Fx=fracture; RD=absolute risk difference; RR=relative risk; Tx=treatment; Vit=vitamin; wk=weeks; yr=years.

Appendix F Figure 4 is titled “Effects of Vitamin D vs. Control on Fractures by Calcium Use, Community-dwelling Participants.” This figure displays forest plots reporting the absolute risk difference of 6 studies stratified by calcium use. Four studies did not include calcium (Bislev, 2018; Hin, 2016; Hansen, 2015; Scragg, 2017) and 2 studies included calcium in both arms (Pfeifer, 2000; Pfeifer, 2009). The absolute risk difference for the studies that did not include calcium was 0.3 percent (95% CI, −1.4 % to 2.1%, I2­=0.0%). The pooled absolute risk difference for the studies that include calcium in both arms was −4.4 percent (95% CI, −9.7% to 0.8%, I2­=0.0%). The overall pooled risk difference of all six studies was −0.3 (95% CI −2.1% to 1.6%, I2­=13.0%). No individual studies reported a significant difference between active treatment and control.

Appendix F Figure 5 Effect of Vitamin D Treatment on Falls by Vitamin D Level (Community-Dwelling Participants)

Figure Notes: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points).

Abbreviations: CI=confidence interval; Cntl=control; RD=absolute risk difference; RR=relative risk; Tx=treatment; Vit=vitamin; wk=weeks; yr=years.

Appendix F Figure 5 is titled “Effects of Vitamin D vs. Control on Falls by Vitamin D Level, Community-dwelling Participants.” This figure displays a forest plot reporting absolute risk differences for 6 studies stratified by the serum vitamin D level used to defined deficiency. Three studies defined deficiency as less than 20 ng/mL (Scragg, 2017; Shea, 2019; Pfeifer, 2000) and 3 studies defined deficiency as less than 30 ng/mL (Hin, 2016; Karkkainen, 2010; Pfeifer, 2009). The pooled absolute risk difference for the studies that defined deficiency as less than 20 ng/mL was −1.5 percent (95% CI, −1.1% to 8.3%, I2­=52.7%). The pooled absolute risk difference for the studies that defined deficiency as less than 30 ng/mL was −7.0 percent (95% CI, −19.3% to 5.3%, I2­=81.1%). Pooled absolute risk difference for all 6 studies was −4.3 percent (95% CI, −1.7% to 2.9%, 70.1%).

Appendix F Figure 6 Effect of Vitamin D Treatment on Falls by Calcium Use (Community-Dwelling Participants)

Figure Notes: To calculate the absolute risk difference in percentage points, multiply value by 100 (e.g., 0.009 multiplied by 100=0.9 percentage points).

Abbreviations: CI=confidence interval; Cntl=control; RD=absolute risk difference; RR=relative risk; Tx=treatment; Vit=vitamin; wk=weeks; yr=years.

Appendix F Figure 6 is titled “Effects of Vitamin D vs. Control on Incidence of Fall by Calcium Use, Community-dwelling Participants.” This figure displays forest plots reporting the absolute risk difference of six studies stratified by calcium use. Three studies do not include calcium (Scragg, 2017; Hin, 2016; Shea, 2019), 1 studies includes calcium only in the active arm (Karkkainen, 2010) and 2 studies include calcium in both arms (Pfeifer, 2000; Pfeifer, 2009). The pooled absolute risk difference for studies not including calcium was 2.7 percent (95% CI, −1.7% to 7.2%, I2­=0.0%). The pooled absolute risk difference for the study including calcium only in the active arm was −4.6 percent (95% CI, −12.3% to 3.1%). The pooled absolute risk difference for studies including calcium in both arms was −17.6% (95% CI, −26.7% to −8.4%, I2­=0.0%). The overall pooled absolute risk difference for all six studies was −4.3 percent (95% CI, −11.6% to 29%, I2­=70.1%).

Appendix F Table 1 Sensitivity Analysis for Pooled Estimates of Mortality Incidence—Part 1

| Main (Stata) | Sensitivity Analysis 1 (Stata) | Sensitivity Analysis 2 (Stata) | Sensitivity Analysis 3 (Stata) | Sensitivity Analysis 4 (Stata) | Sensitivity Analysis 5 (Stata) | Sensitivity Analysis 6 (Stata)
| - Random effects model using the method of DerSimonian & Laird; - Studies with zero events in both treatment and control groups were included with a continuity correction for zero event cells as described by Battaggia et al (2015)^211^ | Same as main analysis except studies with zero events in both treatment groups were excluded from pooling (all were in community-dwelling strata) | Same as main except a manual continuity correction of 0.5 was added to all zero event cells | Fixed effects model using M-H pooling; studies with zero events in both treatment groups were excluded | Fixed effects model using Peto method for pooling odds ratio; studies with zero events in both treatment groups were excluded | Fixed effects model using Peto method for pooling odds ratio, continuity correction for zero event cells as described by Battaggia et al (2015)^211^ | Fixed effects model using Peto method for pooling odds ratio, 0.5 manual continuity correction added to all zero event cells
Effect Estimate (95% CI)
RD Overall | −0.6% (−2.2% to 1.1%) | −1.0% (−3.5% to 1.4%) | −0.8% (−2.5% to 0.8%) | −1.9% (−3.6% to −0.1%) | NA | NA | NA
RD Community-Dwelling | 0.3% (−0.6% to 1.1%) | 0.2% (−1.3% to 1.7%) | 0.1% (−0.8% to 1.0%) | 0% (−1.0% to 1.0%) | NA | NA | NA
RD Institutionalized | −2.8% (−5.5% to −0.2%) | Same as main | Same as main | Same as main | NA | NA | NA
RR Overall | 0.86 (0.75 to 0.99) | Same as main | Same as main | Same as main | 0.83 (0.70 to 0.99) | Same as SA2 | 0.83 (0.70 to 0.98)
RR Community-Dwelling | 1.13 (0.39 to 3.28) | 1.09 (0.25 to 4.84) | 0.91 (0.31 to 2.64) | 0.97 (0.39 to 2.38) | 1.02 (0.34 to 3.08) | 1.01 (0.40 to 2.59) | 0.86 (0.32 to 2.29)
RR Institutionalized | 0.86 (0.74 to 0.99) | Same as main | Same as main | Same as main | 0.83 (0.69 to 0.98) | Same as SA2 | Same as SA4

Abbreviations: CI=confidence interval; M-H=Mantel-Haenszel; RD=absolute risk difference; RR=relative risk.

Appendix F Table 2 Sensitivity Analysis for Pooled Estimates of Mortality Incidence—Part 2

| Main (Stata) | Sensitivity Analysis 7 (Meta Package in R) | Sensitivity Analysis 8 (Meta Package in R) | Sensitivity Analysis 9 (Meta Package in R) | Sensitivity Analysis 10 (Meta Package in R)
| - Random effects model using the method of DerSimonian & Laird; - Studies with zero events in both treatment and control groups included with continuity correction for zero cell counts as described by Battaggia et al (2015)^211^ | Random effects model using maximum likelihood estimator with 0.5 continuity correction for zero event cells | Random effects model using maximum likelihood estimator, studies with zero events in both treatment groups excluded | Random effects model using DerSimonian & Laird Estimator with 0.5 continuity correction for zero cell counts | Random effects using restricted maximum likelihood estimator with 0.5 continuity correction for zero cell counts
Effect Estimate (95% CI)
RD Overall | −0.6% (−2.2% to 1.1%) | 0% (−0.8% to 0.8%) | Same as SA4 | −0.6% (−2.4% to 1.1%) | −0.1% (−1.1% to 0.8%)
RD Community Dwelling | 0.3% (−0.6% to 1.1%) | 0.3% (−0.6% to 1.2%) | Same as SA4 | 0.3% (−0.6% to 1.2%) | 0.3% (−0.6% to 1.2%)
RD Institutionalized | −2.8% (−5.5% to −0.2%) | Same as main | Same as main | Same as main | −2.8% (−5.5% to −0.2%)
RR Overall | 0.86 (0.75 to 0.99) | Same as main | Same as main | Same as main | Same as main
RR Community Dwelling | 1.13 (0.39 to 3.28) | 0.86 (0.29 to 2.56) | 1.17 (0.33 to 4.16) | 0.87 (0.29 to 2.56) | 0.82 (0.25 to 2.63)
RR Institutionalized | 0.86 (0.74 to 0.99) | Same as main | Same as main | Same as main | Same as main

Abbreviations: CI=confidence interval; RD=absolute risk difference; RR=relative risk.