# Appendix E Assessment of Study Quality

Appendix E Table 1 Quality Ratings for Randomized, Controlled Trials, Part 1

Author (Year) | Overall Quality Rating | Overall Rationale for Quality Rating | 1. Was method of randomi-zation adequate? | 2. Was allocation concealment adequate? | 3. Were group characteris-tics balanced at baseline? | 4. Were the eligibility criteria prespecified? | 5. Were there any inappropriate post-randomization exclusions? | 6. Were outcome assessors blinded?
Aloia (2005)^107^ | Fair | Information related to allocation concealment, blinding, crossover, prespecification of harms, and attrition was unclear. | Yes | Unclear | Yes | Yes | No | Unclear
Aloia (2018)^111^ | Fair | Moderate attrition with some lack of clarity in the numbers included in the ITT analysis. Lack of specificity in eligibility criteria. No mention of how adverse events were specified or monitored. | Yes | Yes | Yes | Yes | Unclear | Unclear
Arvold (2009)^83^ | Fair | Differential attrition between groups (higher in placebo group) and unclear about both randomization methods and whether crossover occurred. | Unclear | Yes | Yes | Yes | No | Yes
Berlin (1986)^208^ | Poor | Multiple deficiencies related to randomization, allocation concealment, blinding, and unknown rates of attrition or post-randomization exclusions. | No | No | Unclear | Yes | Unclear | No
Bischoff (2003)^90^ | Fair | There was high overall attrition; only 73% of patients completed the study, and of those, almost a third were missing data on musculoskeletal outcomes. | Unclear | Yes | Yes | Yes | No | Yes
Bislev (2018)^71^ | Good | Good for KQ 3 outcomes; fair for KQ 4 outcomes because it is unclear how adverse events were specified or monitored. | Unclear | Yes | Yes | Yes | No | Unclear
Borgi (2016)^112^ | Good | NA | Yes | Yes | Yes | Yes | Unclear | Yes
Brazier (2005)^89^ | Fair | Details related to allocation concealment and blinding are unclear, though the study is described as a double-blind trial. The percentage of patients classified as withdrawn from the study is >20%; however, a large percentage of those patients withdrew after experiencing adverse events. | Yes | Unclear | Yes | Yes | Unclear | Unclear
Chapuy (2002)^88^ | Fair | Methods related to randomization and allocation concealment are unclear and there is high overall attrition. | Unclear | Unclear | Yes | Yes | No
Gagnon (2014)^113^ | Fair | Some imbalances in baseline characteristics suggesting a failure of adequate randomization, borderline differential attrition (15% difference between groups). | Yes | Yes | No | Yes | No | Yes
Gallagher (2012)^50^ | Good | NA | Yes | Yes | Yes | Yes | No | Yes
Gallagher (2014)^82^ | Fair | High attrition | Yes | Unclear | Yes | Yes | Unclear | Yes
Grimnes (2011)^95^ | Fair | Unclear if harms were prespecified. Some differential attrition (11% difference between the groups). | Yes | Yes | Yes | Yes | No | Yes
Hansen (2013)^70^ | Good | NA | Unclear | Yes | Yes | Yes | No | Yes
Harris (1999)^104^ | Poor | Very small sample size, unclear if harms outcomes were prespecified, lack of blinding, unclear randomization and allocation concealment methods. | Unclear | Unclear | Yes | Yes | Yes | No
Hin (2016)^74^ | Good | NA | Yes | Yes | Yes | Yes | No | Yes
Honkanen (1990)^104^ | Fair | Lack of information related to randomization and treatment allocation methods. Study personnel and patients were not blind to treatment since the control group received none. Attrition was likely reasonable, but it is unclear at what point in screening/recruitment randomization occurred. | Unclear | Unclear | Yes | Yes | Unclear | No
Janssen (2010)^91^ | Fair | High attrition, unclear if crossover occurred or if harms were prespecified. | Yes | Yes | Yes | Yes | No | Yes
Jorde (2016)^75^ & Jorde et al (2016)^144^ | Fair | Subgroup analysis did not appear to be prespecified, also possible selective outcome reporting. Study also evaluated respiratory infections but did not report findings for that subgroup. | Yes | Yes | Yes | Yes | Unclear | Yes
Jorde (2018)^78^ | Fair | Lack of information related to randomization methods, adverse events outcomes were not prespecified, analysis of depression scores appears to be a post hoc analysis, not included in the primary trial. | Unclear (probably adequate but not described) | Yes | Yes (except sig difference in baseline vitamin D levels, which was not likely clinically significant) | Yes | No | Yes
Kärkkäinen (2010)^93^ | Fair | Open-label design (i.e., no blinding), unclear randomization and allocation methods, attrition between randomization and receiving treatment, and unclear whether harms were prespecified. | Unclear | Unclear | Yes | Yes | No | No
Kearns (2015)^114^ | Fair | Method of randomization and allocation concealment NR, unclear whether outcome assessors were blinded, harms not prespecified as outcomes and only monitoring of serum calcium for safety was described. | Unclear | Unclear | Yes | Yes | No | Unclear
Kjaergaard (2012)^81^ | Good | NA | Yes | Yes | Yes | Yes | Yes | Yes
Knutsen (2014)^108^ | Fair | Harms were not prespecified in the article and very little information is provided. | Yes | Yes | Yes | Yes | No | Yes
Krieg (1999)^92^ | Fair | Attrition was high (but similar) in both groups and there was a lack of blinding, which may have affected outcomes. Information on randomization, allocation concealment, and crossover between groups was unclear. | Unclear | Unclear | Yes | Yes | No | No
Lehmann (2013)^47^ | Fair | Lack of information regarding crossover and prespecification of harms outcomes. | Yes | Yes | Yes | Yes | No | Yes
Lerchbaum (2017)^115^ | Fair | Harm outcomes were not prespecified and no description of how they were ascertained. | Yes | Yes | Yes | Yes | No | Yes
Lips (1996)^87^ | Fair | Loss to followup was low (<1%) but 18% of randomized participants did not complete treatment. An additional 73 participants were noted as using vitamin D outside of the study protocol, but it is not clear whether they were excluded from the study after randomization. | Yes | Yes | Yes | Yes | No | Unclear
Lips (2010)^84^ | Fair | Some study methods were unclear. | Unclear | Unclear | Yes | Yes | Unclear | Yes
Manson (2019)^72^ | Good | Most reporting was for the whole study population, unclear whether completely applicable to the population that was vitamin D deficient, but this subgroup was prespecified. | Yes | Unclear | Yes | Yes | No | Yes
Martineau (2007)^109^ | Fair | High attrition and unclear information related to crossover and prespecification of harms/adverse events outcomes. | Yes | Yes | Yes | Yes | Yes | Yes
Mason (2014)^116^ | Fair | Modest attrition | Yes | Yes | Yes | Yes | No | Yes
Moreira-Lucas (2017)^117^ | Fair | Method of randomization and allocation concealment not specified and some differences in baseline characteristics, modest attrition, no mention of how adverse events were specified or monitored. | Unclear | Unclear | No | Yes | No | Yes
Ng (2014)^118^ | Good | NA | Yes | Unclear | Yes | Yes | No | Yes
Nowak (2016)^119^ | Good | NA | Yes | Yes | Yes | Yes | No | Unclear
Oliveri (2015)^209^ | Poor | Eligibility criteria not specified, no information about allocation concealment, baseline imbalances, single blind. Harms outcomes not prespecified. This was primarily designed as a pharmacokinetic study, not an intervention study. | Yes | Unclear | No | Unclear | Unclear | No
Osmancevic (2016)^210^ | Poor | No information on randomization method or allocation concealment and baseline characteristics of treatment groups not provided, very high attrition. | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Pfeifer (2000)^86^ | Fair | Methods related to randomization and blinding were unclear. | Unclear | Unclear | Yes | Yes | No | Unclear
Pfeifer (2009)^85^ | Fair | Unclear randomization and blinding methods. | Unclear | Unclear | Yes | Yes | No | Unclear
Pilz (2015)^120^ | Fair | No mention of how adverse events were specified or monitored. | Yes | Yes | Yes | Yes | No | Yes
Pittas (2019)^77^ | Fair | Methods related to randomization, allocation concealment, and blinding are minimally described, if at all. | Yes | Unclear | Yes | Yes | No | Yes
Raed (2017)^121^ | Fair | No mention of how adverse events were specified or monitored. | Yes | Yes | Yes | Yes | No | Yes
Scragg (2017)^99^ & Khaw (2017)^73^ | Good | Subgroup analysis was prespecified. | Yes | Yes | Yes | Yes | No | Yes
Shea (2019)^79^ | Good | NA | Yes | Yes | Yes | Yes | No | Unclear
Tran (2014)^122^ | Good | Harm/safety outcomes are rated as good. Antibiotic use outcomes are rated as poor because these were defined for a post hoc analysis with serious risk of measurement bias. Further antibiotic use is a very indirect measure for incidence of infections. | Yes | Unclear | Yes | Yes | No | Yes
Wamberg (2013)^110^ | Fair | Moderate attrition and unclear information about crossover. | Yes | Yes | Yes | Yes | No | Yes
Witham (2013)^105^ | Fair | Baseline imbalances in BMI between groups, no specification of harms or description of harm ascertainment. | Yes | Yes | No | Yes | No | Yes
Wood (2012)^94^ | Fair | Unclear whether harms were prespecified or if there was any crossover. | Yes | Yes | Yes | Yes | No | Yes

Abbreviations: BMI=body mass index; ITT=intent to treat; KQ=key question; NA=not applicable; NR=not reported.

Appendix E Table 2 Quality Ratings for Randomized, Controlled Trials, Part 2

Author (Year) | 7. Were care providers blinded? | 8. Were participants blinded? | 9. Was there acceptable attrition and no differential attrition? | 10. Was there fidelity to the assigned intervention? | 11. Was there crossover between groups? | 12. Were participants analyzed in the groups in which they were randomized? | 13. Were the outcomes prespecified? | 14. Were the subgroup analyses prespecified?
Aloia (2005)^107^ | Yes | Yes | Yes | Yes | Unclear | Yes | Unclear | NA
Aloia (2018)^111^ | Yes | Yes | Unclear | Yes | No | Yes | Unclear | NA
Arvold (2009)^83^ | Yes | Yes | No | Yes | Unclear | Yes | Yes | NA
Berlin (1986)^208^ | No | No | Not reported | Yes | Unclear | Yes | Yes | NA
Bischoff (2003)^90^ | Yes | Yes | No | Yes | Unclear | Yes | Yes | NA
Bislev (2018)^71^ | Yes | Yes | Yes | Yes | No | Yes | Unclear | NA
Borgi (2016)^112^ | Yes | Yes | Yes | Yes | No | Yes | Yes | NA
Brazier (2005)^89^ | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Yes | NA
Chapuy (2002)^88^ | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | NA
Gagnon (2014)^113^ | Yes | Yes | No | Yes | No | Yes | Yes | NA
Gallagher (2012)^50^ | Yes | Yes | Yes | Yes | No | Yes | Yes | NA
Gallagher (2014)^82^ | Yes | Yes | No | Yes | No | Yes | Yes | Unclear
Grimnes (2011)^95^ | Yes | Yes | Yes | Yes | Unclear | Yes | Unclear | NA
Hansen (2013)^70^ | Yes | Yes | Yes | Yes | No | Yes | Yes | NA
Harris (1999)^104^ | No | No | Yes | Unclear | Unclear | Yes | Unclear | Yes
Hin (2016)^74^ | Yes | Yes | Yes | Yes | No | Yes | Yes | NA
Honkanen (1990)^104^ | No | No | Unclear | Yes | Unclear | Yes | Yes | Yes
Janssen (2010)^91^ | Yes | Yes | No | Yes | Unclear | Yes | Unclear | NA
Jorde (2016)^75^ & Jorde et al (2016)^144^ | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | No
Jorde (2018)^78^ | Yes | Yes | Yes | Yes | No | Yes | No (power calc was ad hoc) | NA
Kärkkäinen (2010)^93^ | No | No | Yes | Yes | Unclear | Yes | Unclear | Yes
Kearns (2015)^114^ | Yes | Yes | Yes | Yes | No | Yes | Unclear | NA
Kjaergaard, 2012)^81^ | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | NA
Knutsen (2014)^108^ | Yes | Yes | Yes | Yes | Unclear | Yes | Unclear | Unclear
Krieg (1999)^92^ | No | No | No | Yes | Unclear | Yes | No | NA
Lehmann (2013)^47^ | Yes | Yes | Yes | Yes | Unclear | Yes | Unclear | NA
Lerchbaum (2017)^115^ | Yes | Yes | Yes | Unclear | No | Yes | Unclear | No
Lips (1996)^87^ | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes
Lips (2010)^84^ | Yes | Unclear | Yes | Yes | Unclear | Yes | Yes | NA
Manson (2019)^72^ | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes
Martineau (2007)^109^ | Yes | Yes | No | Yes | Unclear | Yes | Unclear | NA
Mason (2014)^116^ | Yes | Yes | Yes | Yes | No | Yes | Yes | NA
Moreira-Lucas (2017)^117^ | Yes | Yes | Yes | Yes | No | Yes | Unclear | Unclear
Ng (2014)^118^ | Yes | Yes | Yes | Yes | No | Yes | Yes | NA
Nowak (2016)^119^ | Yes | Yes | Yes | Yes | No | Yes | Yes | NA
Oliveri (2015)^209^ | No | Yes | Yes | Yes | No | Yes | Unclear | NA
Osmancevic (2016)^210^ | Yes | Yes | No | Yes | No | Yes | Yes | NA
Pfeifer (2000)^86^ | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | NA
Pfeifer (2009)^85^ | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | NA
Pilz (2015)^120^ | Yes | Yes | Yes | Yes | No | Yes | Unclear | NA
Pittas (201)9^77^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No
Raed (2017)^121^ | Yes | Yes | Yes | Yes | No | Yes | Unclear | NA
Scragg (2017)^99^ & Khaw (2017)^73^ | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes
Shea (2019)^79^ | Yes | Yes | Yes | Yes | No | Yes | Yes | NA
Tran (2014)^122^ | Yes | Yes | Yes | Yes | No | Yes | Unclear | NA
Wamberg (2013)^110^ | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | NA
Witham (2013)^105^ | Yes | Yes | Yes | Yes | No | Yes | Unclear | NA
Wood (2012)^94^ | Yes | Yes | Yes | Yes | Unclear | Yes | Unclear | NA

Abbreviation: NA=not applicable.

Appendix E Table 3 Quality Ratings for the Women’s Health Initiative Nested Case-Control Study

Study | Can we be confident in the assessment of exposure? | Can we be confident that cases had developed the outcome of interest and the controls had not? | Can we be confident in the assessment of variable evaluated through interaction effect? | Were the cases (those who were exposed and developed the outcome of interest) properly selected? | Were the controls (those who were exposed and did not develop the outcome of interest) properly selected? | Were cases and controls matched according to important prognostic variables or was statistical adjustment carried out for those variables? | Overall Rating | Comments
Women’s Health Initiative Nested Case Control Study^80,^ ^96,^ ^98,^ ^101,^ ^102^ | Definitely yes | Definitely yes for mortality, fracture, colorectal cancer, and breast cancer. Probably yes for diabetes | Probably no | Definitely yes | Definitely yes | Definitely yes | Fair | Variability in vitamin D assay has potential to misclassify exposure among the various subgroups evaluated, but this is likely small. Diabetes not ascertained as rigorously as the other outcomes. Only modest adherence to study medication (59% at study end), and participants were allowed to take personal calcium and vitamin D supplements outside of the study protocol.