# Appendix D Evidence Tables

Appendix D Table 1 Detailed Study Characteristics of Included RCTs

Appendix D Table 2 Population Characteristics of Included RCTs

Appendix D Table 3 Intervention and Comparator Characteristics of Included RCTs

Appendix D Table 4 Benefit Outcomes From Included RCTs (KQ 3)—Mortality

Appendix D Table 5 Benefit Outcomes From Included RCTs (KQ 3)—Fractures

Appendix D Table 6 Benefit Outcomes From Included RCTs (KQ 3)—Falls

Appendix D Table 7 Benefit Outcomes From Included RCTs (KQ 3)—Other Morbidity

Appendix D Table 8 Harm Outcomes From Included RCTs (KQ 4)—Total Adverse Events

Appendix D Table 9 Harm Outcomes From Included RCTs (KQ 4)—Serious Adverse Events

Appendix D Table 10 Harm Outcomes From Included RCTs (KQ 4)—Discontinuations Because of Adverse Events

Appendix D Table 11 Harms Outcomes From Included RCTs (KQ 4)—Kidney Stones

Appendix D Table 12 Harm Outcomes From Included RCTs (KQ 4)—Other Harms

Appendix D Table 13 Study and Population Characteristics of the Women’s Health Initiative Calcium with Vitamin D Trial

Appendix D Table 14 Findings From the Women’s Health Initiative Calcium With Vitamin D Trial