# Appendix C Excluded Studies

List of Exclusion Codes:

- X1: Systematic review for hand search
- X2: Ineligible publication type
- X3: Ineligible country
- X4: Ineligible population
- X5: Ineligible intervention
- X6: Ineligible comparator
- X7: Ineligible outcome
- X8: Ineligible study design
- X9: Duplicate or superseded
- X10: Study protocol or in progress
- X11: Abstract only
- X12: Non-English full text
- X13: Other
- X14: Poor quality

1 Effect of omega-3 and vitamin D on women with pre- diabetes and hypo vitaminosis D. Cochrane Central Register of Controlled Trials (CENTRAL). 2019 PMID: CN-01949034. Exclusion Code: X10.
2 To study effect of Vitamin D supplementation on atherosclerotic risk factors (endothelial dysfunction) in post-renal transplant patients. Cochrane Central Register of Controlled Trials (CENTRAL). 2019 PMID: CN-01970623. Exclusion Code: X7.
3 Acibucu F, Dokmetas HS, Acibucu DO, . Effect of vitamin D treatment on serum sclerostin level. Exp Clin Endocrinol Diabetes. 2017 Oct;125(9):634–7. doi: 10.1055/s-0035-1559790. PMID: 28938476. Exclusion Code: X3.26824280
4 Adebayo FA, Itkonen ST, Ohman T, . Vitamin D intake, serum 25-hydroxyvitamin D status and response to moderate vitamin D3 supplementation: a randomised controlled trial in East African and Finnish women. Br J Nutr. 2018;119(4):431–41. doi: 10.1017/S000711451700397X. PMID: CN-01464054. Exclusion Code: X7.29498350
5 Akyuz G, Sanal-Toprak C, Yagci I, . The effect of vitamin D supplementation on pain, quality of life, and nerve conduction studies in women with chronic widespread pain. Int J Rehabil Res. 2017 Mar;40(1):76–83. doi: 10.1097/mrr.0000000000000211. PMID: 28005440. Exclusion Code: X3.28030514
6 Aloia JF, Dhaliwal R, Shieh A, . Calcium and vitamin d supplementation in postmenopausal women. J Clin Endocrinol Metab. 2013 Nov;98(11):E1702–9. doi: 10.1210/jc.2013-2121. PMID: 23595003. Exclusion Code: X4.24064695
7 Aloia JF, Patel M, Dimaano R, . Vitamin D intake to attain a desired serum 25-hydroxyvitamin D concentration. Am J Clin Nutr. 2008;87(6):1952–8. Exclusion Code: X7.18541590
8 Ammann EM, Drake MT, Haraldsson B, . Incidence of hematologic malignancy and cause-specific mortality in the Women’s Health Initiative randomized controlled trial of calcium and vitamin D supplementation. Cancer. 2017 Nov 1;123(21):4168–77. doi: 10.1002/cncr.30858. PMID: 27049526. Exclusion Code: X7.28654155
9 Aoki K, Sakuma M, Endo N. The impact of exercise and vitamin D supplementation on physical function in community-dwelling elderly individuals: A randomized trial. J Orthop Sci. 2018 Jul;23(4):682–7. doi: 10.1016/j.jos.2018.03.011. PMID: 30087216. Exclusion Code: X4.29705177
10 Barengolts E, Manickam B, Eisenberg Y, . Effect of high-dose vitamin D repletion on glycemic control in African-American males with prediabetes and hypovitaminosis D. Endocr Pract. 2015 Jun;21(6):604–12. doi: 10.4158/ep14548.Or. PMID: 25899914. Exclusion Code: X6.25716637
11 Beilfuss J, Jorde R, Kamycheva E. High-sensitivity CRP is associated with serum 25-hydroxyvitamin D levels, but is not affected by 5-year supplementation with cholecalciferol. J Nutrition Health Food Sci. 2017;5(5):1–8. Exclusion Code: X4.
12 Berlin T, Emtestam L, Björkhem I. Studies on the relationship between vitamin D3 status and urinary excretion of calcium in healthy subjects: effects of increased levels of 25-hydroxyvitamin D3. Scand J Clin Lab Invest. 1986;46(8):723–9. Exclusion Code: X14.3026026
13 Bischoff-Ferrari HA, Dawson-Hughes B, John Orav E, . Monthly high-dose Vitamin D treatment for the prevention of functional decline a randomized clinical trial. JAMA Internal Medicine. 2016;176(2):175–83. doi: 10.1001/jamainternmed.2015.7148. Exclusion Code: X4.26747333
14 Bislev LS, Langagergaard Rodbro L, Bech JN, . The effect of vitamin D3 supplementation on markers of cardiovascular health in hyperparathyroid, vitamin D insufficient women: a randomized placebo-controlled trial. Endocrine. 2018 Oct;62(1):182–94. doi: 10.1007/s12020-018-1659-4. PMID: 29699378. Exclusion Code: X9.30043092
15 Bjelakovic G, Gluud LL, Nikolova D, . Vitamin D supplementation for prevention of mortality in adults. Cochrane Database Syst Rev. 2014;1:CD007470. doi: 10.1002/14651858.CD007470.pub3. PMID: 24414552. Exclusion Code: X1.24414552
16 Bjelakovic G, Nikolova D, Bjelakovic M, . Vitamin D supplementation for chronic liver diseases in adults. Cochrane Database Syst Rev. 2017 Nov 3;11:Cd011564. doi: 10.1002/14651858.CD011564.pub2. PMID: 28291696. Exclusion Code: X4.29099543
17 Blair K. Making the case for universal vitamin D supplementation. J Fam Health. 2016 Sep;26(5):14–7. PMID: 27470251. Exclusion Code: X2.27470251
18 Blann A. An update on vitamin D deficiency and at risk groups. J Fam Health. 2015 May–Jun;25(3):16–9. PMID: 25900732. Exclusion Code: X2.25900732
19 Bogdanou D, Penna-Martinez M, Filmann N, . T-lymphocyte and glycemic status after vitamin D treatment in type 1 diabetes: a randomized controlled trial with sequential crossover. Diabetes Metab Res Rev. 2017 Mar;33(3)doi: 10.1002/dmrr.2865. PMID: 27995499. Exclusion Code: X4.27995499
20 Bolland MJ, Avenell A, Grey A. Should adults take vitamin D supplements to prevent disease? BMJ. 2016 Nov 23;355:i6201. doi: 10.1136/bmj.i6201. PMID: 27402012. Exclusion Code: X2.27881372
21 Bolland MJ, Grey A, Gamble GD, . Concordance of results from randomized and observational analyses within the same study: a re-analysis of the women’s health initiative limited-access dataset. PLoS One. 2015;10(10):e0139975. doi: 10.1371/journal.pone.0139975. PMID: 26246241. Exclusion Code: X4.26440516
22 Brady SRE, Naderpoor N, de Courten MPJ, . Vitamin D supplementation may improve back pain disability in vitamin D deficient and overweight or obese adults. J Steroid Biochem Mol Biol. 2019 Jan;185:212–7. doi: 10.1016/j.jsbmb.2018.09.005. PMID: 30044160. Exclusion Code: X7.30201225
23 Brenner H, Jansen L, Saum KU, . Vitamin D supplementation trials aimed at reducing mortality have much higher power when focusing on people with low serum 25-hydroxyvitamin D concentrations. J Nutr. 2017 Jul;147(7):1325–33. doi: 10.3945/jn.117.250191. PMID: 28468770. Exclusion Code: X8.28539415
24 Bressendorff I, Brandi L, Schou M, . The effect of high dose cholecalciferol on arterial stiffness and peripheral and central blood pressure in healthy humans: a randomized controlled trial. PLoS One. 2016;11(8):e0160905. doi: 10.1371/journal.pone.0160905. PMID: 27026331. Exclusion Code: X7.27509187
25 Bubshait DA, Al-Dakheel DA, Alanii FM. Topical vitamin D3: a randomized controlled trial (RCT). Clin Nutr ESPEN. 2018 Oct;27:16–9. doi: 10.1016/j.clnesp.2018.05.009. PMID: 29288249. Exclusion Code: X7.30144887
26 Cameron ID, Dyer SM, Panagoda CE, . Interventions for preventing falls in older people in care facilities and hospitals. Cochrane Database Syst Rev. 2018(9)doi: 10.1002/14651858.CD005465.pub4. PMID: CD005465. Exclusion Code: X1.
27 Carrara D, Bruno RM, Bacca A, . Cholecalciferol treatment downregulates renin-angiotensin system and improves endothelial function in essential hypertensive patients with hypovitaminosid D. J Hypertens. 2016 Nov;34(11):2199–205. doi: 10.1097/hjh.0000000000001072. PMID: 26970588. Exclusion Code: X8.27648718
28 Castro JP, Penckofer S. The role of vitamin D in the health of Hispanic adults with diabetes. Hisp Health Care Int. 2014;12(2):90–8. doi: 10.1891/1540-4153.12.2.90. PMID: 24847674. Exclusion Code: X2.24871915
29 Castro M, King TS, Kunselman SJ, . Effect of vitamin D3 on asthma treatment failures in adults with symptomatic asthma and lower vitamin D levels: the VIDA randomized clinical trial. JAMA. 2014 May;311(20):2083–91. doi: 10.1001/jama.2014.5052. PMID: 23995795. Exclusion Code: X4.24838406
30 Cauley JA, Chlebowski RT, Wactawski-Wende J, . Calcium plus vitamin D supplementation and health outcomes five years after active intervention ended: the Women’s Health Initiative. J Womens Health (Larchmt). 2013 Nov;22(11):915–29. doi: 10.1089/jwh.2013.4270. PMID: 23883271. Exclusion Code: X7.24131320
31 Cefalo CMA, Conte C, Sorice GP, . Effect of vitamin D supplementation on obesity-induced insulin resistance: a double-blind, randomized, placebo-controlled trial. Obesity (Silver Spring). 2018 Apr;26(4):651–7. doi: 10.1002/oby.22132. PMID: 29442353. Exclusion Code: X7.29504254
32 Chacko SJ, Pauwaa S, Barengolts E, . Vitamin D attenuates left atrial volume changes in African American males with obesity and prediabetes. Echocardiography. 2016 May;33(5):681–5. doi: 10.1111/echo.13159. PMID: 26547147. Exclusion Code: X6.26711179
33 Chandler PD, Buring JE, Manson JE, . Circulating vitamin D levels and risk of colorectal cancer in women. Cancer Prev Res (Phila). 2015 Aug;8(8):675–82. doi: 10.1158/1940-6207.Capr-14-0470. PMID: 28486474. Exclusion Code: X8.25813525
34 Chaney A, Heckman MG, Diehl NN, . Effectiveness and outcomes of current practice in treating vitamin D deficiency in patients listed for liver transplantation. Endocr Pract. 2015 Jul;21(7):761–9. doi: 10.4158/ep14416.Or. PMID: 26067469. Exclusion Code: X4.25786551
35 Close GL, Russell J, Cobley JN, . Assessment of vitamin D concentration in non-supplemented professional athletes and healthy adults during the winter months in the UK: implications for skeletal muscle function. J Sports Sci. 2013;31(4):344–53. doi: 10.1080/02640414.2012.733822. PMID: 22975529. Exclusion Code: X4.23083379
36 Cutillas-Marco E, Marquina-Vila A, Grant WB, . Vitamin D and cutaneous lupus erythematosus: effect of vitamin D replacement on disease severity. Lupus. 2014 Jun;23(7):615–23. doi: 10.1177/0961203314522338. PMID: 25112048. Exclusion Code: X4.24503020
37 Dalan R, Liew H, Assam PN, . A randomised controlled trial evaluating the impact of targeted vitamin D supplementation on endothelial function in type 2 diabetes mellitus: The DIMENSION trial. Diab Vasc Dis Res. 2016 May;13(3):192–200. doi: 10.1177/1479164115621667. PMID: 26724745. Exclusion Code: X4.26818228
38 Dalbeni A, Scaturro G, Degan M, . Effects of six months of vitamin D supplementation in patients with heart failure: a randomized double-blind controlled trial. Nutr Metab Cardiovasc Dis. 2014 Aug;24(8):861–8. doi: 10.1016/j.numecd.2014.02.015. PMID: 24462294. Exclusion Code: X4.24787908
39 Daraghmeh AH, Bertoia ML, Al-Qadi MO, . Evidence for the vitamin D hypothesis: the NHANES III extended mortality follow-up. Atherosclerosis. 2016 Dec;255:96–101. doi: 10.1016/j.atherosclerosis.2016.04.007. PMID: 27733394. Exclusion Code: X8.27855294
40 Das M, Tomar N, Sreenivas V, . Effect of vitamin D supplementation on cathelicidin, IFN-gamma, IL-4 and Th1/Th2 transcription factors in young healthy females. Eur J Clin Nutr. 2014 Mar;68(3):338–43. doi: 10.1038/ejcn.2013.268. PMID: 24014012. Exclusion Code: X7.24398649
41 de Haan K, Groeneveld AB, de Geus HR, . Vitamin D deficiency as a risk factor for infection, sepsis and mortality in the critically ill: systematic review and meta-analysis. Crit Care. 2014 Dec 5;18(6):660. doi: 10.1186/s13054-014-0660-4. PMID: 25065001. Exclusion Code: X4.25475621
42 de Jongh RT, van Schoor NM, Lips P. Changes in vitamin D endocrinology during aging in adults. Mol Cell Endocrinol. 2017 Sep 15;453:144–50. doi: 10.1016/j.mce.2017.06.005. PMID: 27370643. Exclusion Code: X2.28602863
43 De Smedt J, Van Kelst S, Boecxstaens V, . Vitamin D supplementation in cutaneous malignant melanoma outcome (ViDMe): a randomized controlled trial. BMC Cancer. 2017 Aug 23;17(1):562. doi: 10.1186/s12885-017-3538-4. PMID: 25406966. Exclusion Code: X4.28835228
44 De Smedt J, Van Kelst S, Van Eecke L, . Lack of vitamin D toxicity in a longterm high dose vitamin D supplementation study for cutaneous malignant melanoma (CMM). Melanoma Res. 2016;26:e50. doi: 10.1097/CMR.0000000000000285. Exclusion Code: X4.
45 Der T, Bailey BA, Youssef D, . Vitamin D and prostate cancer survival in veterans. Mil Med. 2014 Jan;179(1):81–4. doi: 10.7205/milmed-d-12-00540. PMID: 25835235. Exclusion Code: X8.24402990
46 Deschasaux M, Souberbielle JC, Andreeva VA, . Quick and easy screening for vitamin D insufficiency in adults: a scoring system to be implemented in daily clinical practice. Medicine (Baltimore). 2016 Feb;95(7):e2783. doi: 10.1097/md.0000000000002783. PMID: 27503623. Exclusion Code: X5.26886626
47 Elkassaby S, Harrison LC, Mazzitelli N, . A randomised controlled trial of high dose vitamin D in recent-onset type 2 diabetes. Diabetes Res Clin Pract. 2014 Dec;106(3):576–82. doi: 10.1016/j.diabres.2014.08.030. PMID: 25411034. Exclusion Code: X4.25438937
48 Forouhi NG, Menon RK, Sharp SJ, . Effects of vitamin D2 or D3 supplementation on glycaemic control and cardiometabolic risk among people at risk of type 2 diabetes: results of a randomized double-blind placebo-controlled trial. Diabetes Obes Metab. 2016 Apr;18(4):392–400. doi: 10.1111/dom.12625. PMID: 27926633. Exclusion Code: X4.26700109
49 Frandsen TB, Pareek M, Hansen JP, . Vitamin D supplementation for treatment of seasonal affective symptoms in healthcare professionals: a double-blind randomised placebo-controlled trial. BMC Res Notes. 2014 Aug 14;7:528. doi: 10.1186/1756-0500-7-528. PMID: 24569127. Exclusion Code: X4.25125215
50 Gallagher JC, Smith LM, Yalamanchili V. Incidence of hypercalciuria and hypercalcemia during vitamin D and calcium supplementation in older women. Menopause. 2014 Nov;21(11):1173–80. doi: 10.1097/gme.0000000000000270. PMID: 24937025. Exclusion Code: X9.24937025
51 Gani LU, How CH. PILL Series. Vitamin D deficiency. Singapore Med J. 2015 Aug;56(8):433–6; quiz 7. doi: 10.11622/smedj.2015119. PMID: 26156733. Exclusion Code: X2.26311908
52 Gasier HG, Gaffney-Stomberg E, Young CR, . The efficacy of vitamin D supplementation during a prolonged submarine patrol. Calcif Tissue Int. 2014 Sep;95(3):229–39. doi: 10.1007/s00223-014-9886-z. PMID: 25238786. Exclusion Code: X7.25005834
53 Grant WB, Boucher BJ. A review of the potential benefits of increasing vitamin D status in Mongolian adults through food fortification and vitamin D supplementation. Nutrients. 2019 Oct 14;11(10)doi: 10.3390/nu11102452. PMID: 31344685. Exclusion Code: X8.31344685
54 Gronborg IM, Lundby IM, Molgaard C, . Association of body fat and vitamin D status and the effect of body fat on the response to vitamin D supplementation in Pakistani immigrants in Denmark. Eur J Clin Nutr. 2015 Mar;69(3):405–7. doi: 10.1038/ejcn.2014.254. PMID: 25271011. Exclusion Code: X7.25469463
55 Gupta A, Prabhakar S, Modi M, . Effect of vitamin D and calcium supplementation on ischaemic stroke outcome: a randomised controlled open-label trial. Int J Clin Pract. 2016 Sep;70(9):764–70. doi: 10.1111/ijcp.12866. PMID: 27169685. Exclusion Code: X3.27561415
56 Hagopian E, Bhasker S, Kariyawasam R, . Influence of host nutriome on immunological control of protozoal infections. Am J Trop Med Hyg. 2019;101(5):177–8. doi: 10.4269/ajtmh.abstract2019. Exclusion Code: X9.
57 Harris SS, Dawson-Hughes B, Perrone GA. Plasma 25-hydroxyvitamin D responses of younger and older men to three weeks of supplementation with 1800 IU/day of vitamin D. J Am Coll Nutr. 1999;18(5):470–4. Exclusion Code: X14.10511329
58 Herrick KA, Storandt RJ, Afful J, . Vitamin D status in the United States, 2011-2014. Am J Clin Nutr. 2019 Jul 1;110(1):150–7. doi: 10.1093/ajcn/nqz037. PMID: 31653512. Exclusion Code: X10.31076739
59 Hill TR, Aspray TJ, Francis RM. Vitamin D and bone health outcomes in older age. Proc Nutr Soc. 2013 Nov;72(4):372–80. doi: 10.1017/s0029665113002036. PMID: 23395104. Exclusion Code: X2.24020640
60 Holick MF. The vitamin D deficiency pandemic: approaches for diagnosis, treatment and prevention. Rev Endocr Metab Disord. 2017 Jun;18(2):153–65. doi: 10.1007/s11154-017-9424-1. PMID: 28516265. Exclusion Code: X2.28516265
61 Hussain S, Singh A, Akhtar M, . Vitamin D supplementation for the management of knee osteoarthritis: a systematic review of randomized controlled trials. Rheumatol Int. 2017 Sep;37(9):1489–98. doi: 10.1007/s00296-017-3719-0. PMID: 28230063. Exclusion Code: X4.28421358
62 Jalali-Chimeh F, Gholamrezaei A, Vafa M, . Effect of vitamin D therapy on sexual function in women with sexual dysfunction and vitamin D deficiency: a randomized, double-blind, placebo controlled clinical trial. J Urol. 2019 May;201(5):987–93. doi: 10.1016/j.juro.2018.10.019. PMID: 30901440. Exclusion Code: X5.30395842
63 Jamka M, Wozniewicz M, Walkowiak J, . The effect of vitamin D supplementation on selected inflammatory biomarkers in obese and overweight subjects: a systematic review with meta-analysis. Eur J Nutr. 2016 Sep;55(6):2163–76. doi: 10.1007/s00394-015-1089-5. PMID: 28481302. Exclusion Code: X1.26538075
64 Jung HC, Seo MW, Lee S, . Correcting vitamin D insufficiency improves some but not all aspects of physical performance during winter training in Taekwondo athletes. Int J Sport Nutr Exerc Metab. 2018 Nov 1;28(6):635–43. doi: 10.1123/ijsnem.2017-0412. PMID: 29963831. Exclusion Code: X7.29722590
65 Kamelian T, Saki F, Jeddi M, . Effect of cholecalciferol therapy on serum FGF23 in vitamin D deficient patients: a randomized clinical trial. J Endocrinol Invest. 2018 Mar;41(3):299–306. doi: 10.1007/s40618-017-0739-2. PMID: 28742409. Exclusion Code: X7.28795342
66 Kamenicky P. Study of the anti-FGF23 antibody, burosumab, in adults with XLH Kyowa Kirin Pharmaceutical Development Ltd. 2019. Exclusion Code: X9.
67 Krefting EA, Jorde R, Christoffersen T, . Vitamin D and intraocular pressure--results from a case-control and an intervention study. Acta Ophthalmol. 2014 Jun;92(4):345–9. doi: 10.1111/aos.12125. PMID: 24176054. Exclusion Code: X7.23575211
68 Krysiak R, Szwajkosz A, Marek B, . The effect of vitamin D supplementation on sexual functioning and depressive symptoms in young women with low vitamin D status. Endokrynol Pol. 2018;69(2):168–74. doi: 10.5603/EP.a2018.0013. PMID: 29113459. Exclusion Code: X7.29442353
69 Kumar V, Yadav AK, Singhal M, . Vascular function and cholecalciferol supplementation in CKD: a self-controlled case series. J Steroid Biochem Mol Biol. 2018 Jun;180:19–22. doi: 10.1016/j.jsbmb.2018.01.001. PMID: 29271278. Exclusion Code: X8.29309832
70 Lagari VS, Gomez-Marin O, Levis S. Study design and baseline characteristics of participants in the vitamin D in vulnerable adults at the VA (the VIVA Study). Contemp Clin Trials. 2014 Sep;39(1):66–73. doi: 10.1016/j.cct.2014.07.009. PMID: 25030223. Exclusion Code: X10.25093912
71 Lappe J, Watson P, Travers-Gustafson D, . Effect of vitamin D and calcium supplementation on cancer incidence in older women: a randomized clinical trial. JAMA. 2017 Mar 28;317(12):1234–43. doi: 10.1001/jama.2017.2115. PMID: 27515154. Exclusion Code: X4.28350929
72 Larsen AU, Grimnes G, Jorde R. The effect of high-dose vitamin D3 supplementation on bone mineral density in subjects with prediabetes. Osteoporos Int. 2018 Jan;29(1):171–80. doi: 10.1007/s00198-017-4222-x. PMID: 28921338. Exclusion Code: X13.28921338
73 Lavie CJ, Dinicolantonio JJ, Milani RV, . Vitamin D and cardiovascular health. Circulation. 2013 Nov 26;128(22):2404–6. doi: 10.1161/circulationaha.113.002902. PMID: 23628132. Exclusion Code: X2.24276875
74 LeBlanc ES, Pratley RE, Dawson-Hughes B, . Baseline characteristics of the vitamin D and type 2 diabetes (D2d) study: a contemporary prediabetes cohort that will inform diabetes prevention efforts. Diabetes Care. 2018 Aug;41(8):1590–9. doi: 10.2337/dc18-0240. PMID: 26404953. Exclusion Code: X10.29941495
75 Lemieux P, Weisnagel SJ, Caron AZ, . Effects of 6-month vitamin D supplementation on insulin sensitivity and secretion: a randomised, placebo-controlled trial. Eur J Endocrinol. 2019 Sep;181(3):287–99. doi: 10.1530/eje-19-0156. PMID: 31583252. Exclusion Code: X1.31344685
76 Libon F, Seidel L, Cavalier E, . Vitamin D supplementation does not improve the severity or the resolution of ultraviolet B-induced acute erythema. Dermatology. 2015;231(3):280–5. doi: 10.1159/000430983. PMID: 25599737. Exclusion Code: X4.26111868
77 Lindblad AJ, Garrison S, McCormack J. Testing vitamin D levels. Can Fam Physician. 2014 Apr;60(4):351. PMID: 24476947. Exclusion Code: X2.24733326
78 Logan VF, Gray AR, Peddie MC, . Long-term vitamin D3 supplementation is more effective than vitamin D2 in maintaining serum 25-hydroxyvitamin D status over the winter months. Br J Nutr. 2013 Mar 28;109(6):1082–8. doi: 10.1017/s0007114512002851. PMID: 23168244. Exclusion Code: X4.23168298
79 Loudyi FM, Kassouati J, Kabiri M, . Vitamin D status in Moroccan pregnant women and newborns: reports of 102 cases. Pan Afr Med J. 2016;24:170. doi: 10.11604/pamj.2016.24.170.4782. PMID: 27147120. Exclusion Code: X3.27795767
80 Madar AA, Stene LC, Meyer HE, . Effect of vitamin D3 supplementation on iron status: a randomized, double-blind, placebo-controlled trial among ethnic minorities living in Norway. Nutr J. 2016 Aug 9;15(1):74. doi: 10.1186/s12937-016-0192-7. PMID: 27413130. Exclusion Code: X7.27506667
81 Mai S, Walker GE, Vietti R, . Acute vitamin D(3) supplementation in severe obesity: evaluation of multimeric adiponectin. Nutrients. 2017 May 5;9(5)doi: 10.3390/nu9050459. PMID: 28452288. Exclusion Code: X7.28452288
82 Mak JC, Klein LA, Finnegan T, . An initial loading-dose vitamin D versus placebo after hip fracture surgery: baseline characteristics of a randomized controlled trial (REVITAHIP). BMC Geriatr. 2014 Sep 9;14:101. doi: 10.1186/1471-2318-14-101. PMID: 25044176. Exclusion Code: X4.25200552
83 Mak JC, Mason RS, Klein L, . An initial loading-dose vitamin D versus placebo after hip fracture surgery: randomized trial. BMC Musculoskelet Disord. 2016 Aug 11;17:336. doi: 10.1186/s12891-016-1174-9. PMID: 29057843. Exclusion Code: X4.27515154
84 Malihi Z, Lawes CMM, Wu Z, . Monthly high-dose vitamin D supplementation does not increase kidney stone risk or serum calcium: results from a randomized controlled trial. Am J Clin Nutr. 2019 Jun 1;109(6):1578–87. doi: 10.1093/ajcn/nqy378. Exclusion Code: X3.31005969
85 Mann MC, Exner DV, Hemmelgarn BR, . Vitamin D supplementation is associated with improved modulation of cardiac autonomic tone in healthy humans. Int J Cardiol. 2014 Mar 15;172(2):506–8. doi: 10.1016/j.ijcard.2014.01.058. PMID: 24394724. Exclusion Code: X4.24502876
86 Martineau A, Jolliffe D, Greenberg L, . Vitamin D supplementation to prevent acute respiratory infections: individual participant data meta-analysis. 2019. Exclusion Code: X1.
87 Mazahery H, Stonehouse W, von Hurst PR. The effect of monthly 50,000 IU or 100,000 IU vitamin D supplements on vitamin D status in premenopausal Middle Eastern women living in Auckland. Eur J Clin Nutr. 2015 Mar;69(3):367–72. doi: 10.1038/ejcn.2014.264. PMID: 25455721. Exclusion Code: X7.25491499
88 McCarthy M. Evidence for routine vitamin D screening is insufficient, US panel concludes. BMJ. 2014 Jun 25;348:g4277. doi: 10.1136/bmj.g4277. PMID: 24691648. Exclusion Code: X2.24965715
89 Menon RK, Rickard AP, Mannan N, . The effects of vitamin D(2) or D(3) supplementation on glycaemic control and related metabolic parameters in people at risk of type 2 diabetes: protocol of a randomised double-blind placebo-controlled trial. BMC Public Health. 2013 Oct 23;13:999. doi: 10.1186/1471-2458-13-999. PMID: 24477043. Exclusion Code: X10.24152375
90 Miller BJ, Whisner CM, Johnston CS. Vitamin D supplementation appears to increase plasma abeta40 in vitamin D insufficient older adults: a pilot randomized controlled trial. J Alzheimers Dis. 2016 Mar 31;52(3):843–7. doi: 10.3233/jad-150901. PMID: 26956166. Exclusion Code: X7.27031473
91 Mitchell DM, Leder BZ, Cagliero E, . Insulin secretion and sensitivity in healthy adults with low vitamin D are not affected by high-dose ergocalciferol administration: a randomized controlled trial. Am J Clin Nutr. 2015 Aug;102(2):385–92. doi: 10.3945/ajcn.115.111682. PMID: 26149190. Exclusion Code: X7.26156733
92 Moini A, Ebrahimi T, Shirzad N, . The effect of vitamin D on primary dysmenorrhea with vitamin D deficiency: a randomized double-blind controlled clinical trial. Gynecol Endocrinol. 2016 Jun;32(6):502–5. doi: 10.3109/09513590.2015.1136617. PMID: 27739274. Exclusion Code: X3.27147120
93 Mousa A, Naderpoor N, de Courten MP, . Vitamin D supplementation has no effect on insulin sensitivity or secretion in vitamin D-deficient, overweight or obese adults: a randomized placebo-controlled trial. Am J Clin Nutr. 2017 Jun;105(6):1372–81. doi: 10.3945/ajcn.117.152736. PMID: 28217829. Exclusion Code: X7.28490514
94 Mozaffari-Khosravi H, Loloei S, Mirjalili MR, . The effect of vitamin D supplementation on blood pressure in patients with elevated blood pressure and vitamin D deficiency: a randomized, double-blind, placebo-controlled trial. Blood Press Monit. 2015 Apr;20(2):83–91. doi: 10.1097/mbp.0000000000000091. PMID: 25664429. Exclusion Code: X3.25350782
95 Narasimhan S, Balasubramanian P. Role of vitamin D in the outcome of ischemic stroke-a randomized controlled trial. Journal of clinical and diagnostic research. 2017;11(2):CC06–CC10. doi: 10.7860/JCDR/2017/24299.9346. PMID: CN-01327568. Exclusion Code: X3.
96 Nct. Feasibility study of 2000 IU per day of vitamin D for the primary prevention of type 1 diabetes. Cochrane Central Register of Controlled Trials. 2005 PMID: CN-01477768. Exclusion Code: X4.
97 Nct. Nutritional intervention to prevent diabetes. Https://clinicaltrials.gov/show/nct00333554. 2006 PMID: CN-01482089. Exclusion Code: X4.
98 Nct. Intervention study of vitamin D supplementation to prevent cardiovascular disease. Https://clinicaltrials.gov/show/nct03339427. 2017 PMID: CN-01565715. Exclusion Code: X3.
99 Neale RE, Armstrong BK, Baxter C, . The D-Health Trial: A randomized trial of vitamin D for prevention of mortality and cancer. Contemp Clin Trials. 2016 May;48:83–90. doi: 10.1016/j.cct.2016.04.005. PMID: 28894361. Exclusion Code: X10.27086041
100 Oliveri B, Mastaglia SR, Brito GM, . Vitamin D3 seems more appropriate than D2 to sustain adequate levels of 25OHD: a pharmacokinetic approach. Eur J Clin Nutr. 2015 Jun;69(6):697–702. doi: 10.1038/ejcn.2015.16. PMID: 25987791. Exclusion Code: X14.25782422
101 Oosterwerff MM, Eekhoff EM, Van Schoor NM, . Effect of moderate-dose vitamin D supplementation on insulin sensitivity in vitamin D-deficient non-Western immigrants in the Netherlands: a randomized placebo-controlled trial. Am J Clin Nutr. 2014 Jul;100(1):152–60. doi: 10.3945/ajcn.113.069260. PMID: 22708508. Exclusion Code: X4.24898240
102 Osati S, Homayounfar R, Hajifaraji M. Metabolic effects of vitamin D supplementation in vitamin D deficient patients (a double-blind clinical trial). Diabetes Metab Syndr. 2016 Apr–Jun;10(2 Suppl 1):S7–s10. doi: 10.1016/j.dsx.2016.01.007. PMID: 26554884. Exclusion Code: X3.26554884
103 Osmancevic A, Demeke T, Gillstedt M, . Vitamin D treatment in Somali women living in Sweden-two randomized, placebo-controlled studies. Clin Endocrinol (Oxf). 2016 Oct;85(4):535–43. doi: 10.1111/cen.13097. PMID: 26696653. Exclusion Code: X14.27155232
104 Owusu JE, Islam S, Katumuluwa S, . Physical performance, osteoporosis, and vitamin d in elderly African American women-the poda trial and dementia. Endocr Rev. 2018;39(2). Exclusion Code: X11.
105 Pittas AG, Dawson-Hughes B, Sheehan PR, . Rationale and design of the Vitamin D and Type 2 Diabetes (D2d) study: a diabetes prevention trial. Diabetes Care. 2014 Dec;37(12):3227–34. doi: 10.2337/dc14-1005. PMID: 25205139. Exclusion Code: X10.25205139
106 Pommergaard HC, Burcharth J, Rosenberg J, . Aspirin, calcitriol, and calcium do not prevent adenoma recurrence in a randomized controlled trial. Gastroenterology. 2016 Jan;150(1):114–22.e4. doi: 10.1053/j.gastro.2015.09.010. PMID: 27086041. Exclusion Code: X5.26404953
107 Prietl B, Treiber G, Mader JK, . High-dose cholecalciferol supplementation significantly increases peripheral CD4(+) Tregs in healthy adults without negatively affecting the frequency of other immune cells. Eur J Nutr. 2014 Apr;53(3):751–9. doi: 10.1007/s00394-013-0579-6. PMID: 24368437. Exclusion Code: X4.23999998
108 Roosta S, Kharadmand M, Teymoori F, . Effect of vitamin D supplementation on anthropometric indices among overweight and obese women: a double blind randomized controlled clinical trial. Diabetes Metab Syndr. 2018 Jul;12(4):537–41. doi: 10.1016/j.dsx.2018.03.022. PMID: 29685792. Exclusion Code: X3.29615318
109 Rush L, McCartney G, Walsh D, . Vitamin D and subsequent all-age and premature mortality: a systematic review. BMC Public Health. 2013 Jul 24;13:679. doi: 10.1186/1471-2458-13-679. PMID: 23314982. Exclusion Code: X1.23883271
110 Saleh L, Tang J, Gawinecka J, . Impact of a single oral dose of 100,000 IU vitamin D3 on profiles of serum 25(OH)D3 and its metabolites 24,25(OH)2D3, 3-epi-25(OH)D3, and 1,25(OH)2D3 in adults with vitamin D insufficiency. Clin Chem Lab Med. 2017 Oct 26;55(12):1912–21. doi: 10.1515/cclm-2016-1129. PMID: 28976079. Exclusion Code: X7.28328526
111 Sandoughi M, Zakeri Z, Mirhosainee Z, . The effect of vitamin D on nonspecific low back pain. Int J Rheum Dis. 2015 Nov;18(8):854–8. doi: 10.1111/1756-185x.12172. PMID: 27287826. Exclusion Code: X3.24119149
112 Sanghi D, Mishra A, Sharma AC, . Does vitamin D improve osteoarthritis of the knee: a randomized controlled pilot trial. Clin Orthop Relat Res. 2013 Nov;471(11):3556–62. doi: 10.1007/s11999-013-3201-6. PMID: 23815870. Exclusion Code: X3.23904246
113 Schnatz PF, Jiang X, Aragaki AK, . Effects of calcium, vitamin D, and hormone therapy on cardiovascular disease risk factors in the Women’s Health Initiative: a randomized controlled trial. Obstet Gynecol. 2017 Jan;129(1):121–9. doi: 10.1097/aog.0000000000001774. PMID: 27926633. Exclusion Code: X7.27926633
114 Schnatz PF, Nudy M, Jiang X, . Vitamin D deficiency and cardiovascular disease in postmenopausal women: contributions from human and nonhuman primate studies. Menopause. 2015 May;22(5):554–63. doi: 10.1097/gme.0000000000000399. PMID: 25875760. Exclusion Code: X2.25563796
115 Seibert E, Lehmann U, Riedel A, . Vitamin D3 supplementation does not modify cardiovascular risk profile of adults with inadequate vitamin D status. Eur J Nutr. 2017 Mar;56(2):621–34. doi: 10.1007/s00394-015-1106-8. PMID: 27549309. Exclusion Code: X7.26621634
116 Sinha-Hikim I, Duran P, Shen R, . Effect of long term vitamin D supplementation on biomarkers of inflammation in Latino and African-American subjects with pre-diabetes and hypovitaminosis D. Horm Metab Res. 2015 Apr;47(4):280–3. doi: 10.1055/s-0034-1383652. PMID: 24794808. Exclusion Code: X7.25011019
117 Sluyter JD, Camargo CA, Waayer D, . Effect of monthly, high-dose, long-term vitamin D on lung function: a randomized controlled trial. Nutrients. 2017 Dec 13;9(12)doi: 10.3390/nu9121353. PMID: 28777983. Exclusion Code: X7.28777983
118 Sollid ST. Glucose metabolism, genetic factors, vitamin D binding protein and directly measured free 25-hydroxyvitamin D-Results from a randomized controlled trial with high-dose vitamin D supplementation in subjects with prediabetes. 2016. Exclusion Code: X9.
119 Sollid ST, Hutchinson MY, Berg V, . Effects of vitamin D binding protein phenotypes and vitamin D supplementation on serum total 25(OH)D and directly measured free 25(OH)D. Eur J Endocrinol. 2016 Apr;174(4):445–52. doi: 10.1530/eje-15-1089. PMID: 27020077. Exclusion Code: X4.26733479
120 Sollid ST, Hutchinson MY, Fuskevag OM, . No effect of high-dose vitamin D supplementation on glycemic status or cardiovascular risk factors in subjects with prediabetes. Diabetes Care. 2014 Aug;37(8):2123–31. doi: 10.2337/dc14-0218. PMID: 25033925. Exclusion Code: X4.24947792
121 Sollid ST, Hutchinson MY, Fuskevag OM, . Large individual differences in serum 25-hydroxyvitamin D response to vitamin D supplementation: effects of genetic factors, body mass index, and baseline concentration. results from a randomized controlled trial. Horm Metab Res. 2016 Jan;48(1):27–34. doi: 10.1055/s-0034-1398617. PMID: 25702786. Exclusion Code: X4.25702786
122 Tepper S, Shahar DR, Geva D, . Differences in homeostatic model assessment (HOMA) values and insulin levels after vitamin D supplementation in healthy men: a double-blind randomized controlled trial. Diabetes Obes Metab. 2016 Jun;18(6):633–7. doi: 10.1111/dom.12650. PMID: 26890669. Exclusion Code: X7.26890031
123 Todd JJ, McSorley EM, Pourshahidi LK, . Vitamin D3 supplementation using an oral spray solution resolves deficiency but has no effect on VO2 max in Gaelic footballers: results from a randomised, double-blind, placebo-controlled trial. Eur J Nutr. 2017 Jun;56(4):1577–87. doi: 10.1007/s00394-016-1202-4. PMID: 29103383. Exclusion Code: X7.27015912
124 Urashima M, Ohdaira H, Akutsu T, . Effect of vitamin D supplementation on relapse-free survival among patients with digestive tract cancers: the AMATERASU Randomized Clinical Trial. JAMA. 2019 Apr 9;321(14):1361–9. doi: 10.1001/jama.2019.2210. PMID: 30964527. Exclusion Code: X4.30964526
125 Villar LM, Del Campo JA, Ranchal I, . Association between vitamin D and hepatitis C virus infection: a meta-analysis. World J Gastroenterol. 2013 Sep 21;19(35):5917–24. doi: 10.3748/wjg.v19.i35.5917. PMID: 23694999. Exclusion Code: X4.24124339
126 Wamberg L, Kampmann U, Stødkilde-Jørgensen H, . Effects of vitamin D supplementation on body fat accumulation, inflammation, and metabolic risk factors in obese adults with low vitamin D levels - results from a randomized trial. Eur J Intern Med. 2013;24(7):644–9. Exclusion Code: X9.23566943
127 Waterhouse M, English DR, Armstrong BK, . A randomized placebo-controlled trial of vitamin D supplementation for reduction of mortality and cancer: statistical analysis plan for the D-Health Trial. Contemporary Clinical Trials Communications. 2019 2019/06/01/;14:100333. doi: 10.1016/j.conctc.2019.100333. Exclusion Code: X10.30886934
128 Wei H, Jing H, Wei Q, . Associations of the risk of lung cancer with serum 25-hydroxyvitamin D level and dietary vitamin D intake: a dose-response PRISMA meta-analysis. Medicine (Baltimore). 2018 Sep;97(37):e12282. doi: 10.1097/md.0000000000012282. PMID: 30018262. Exclusion Code: X1.30212966
129 Witham MD, Adams F, McSwiggan S, . Effect of intermittent vitamin D3 on vascular function and symptoms in chronic fatigue syndrome--a randomised controlled trial. Nutr Metab Cardiovasc Dis. 2015 Mar;25(3):287–94. doi: 10.1016/j.numecd.2014.10.007. PMID: 25547950. Exclusion Code: X4.25455721
130 Wu L, Sun D. Effects of calcium plus vitamin D supplementation on blood pressure: a systematic review and meta-analysis of randomized controlled trials. J Hum Hypertens. 2017 Sep;31(9):547–54. doi: 10.1038/jhh.2017.12. PMID: 26481198. Exclusion Code: X1.28230063
131 Yeow TP, Lim SL, Hor CP, . Impact of vitamin D replacement on markers of glucose metabolism and cardio-metabolic risk in women with former gestational diabetes-a double-blind, randomized controlled trial. PLoS One. 2015;10(6)doi: 10.1371/journal.pone.0129017. PMID: CN-01086029. Exclusion Code: X3.
132 Zhao JG, Zeng XT, Wang J, . Association between calcium or vitamin D supplementation and fracture incidence in community-dwelling older adults: a systematic review and meta-analysis. JAMA. 2017 Dec 26;318(24):2466–82. doi: 10.1001/jama.2017.19344. PMID: 29279934. Exclusion Code: X1.29279934
133 Zheng Y, Zhu J, Zhou M, . Meta-analysis of long-term vitamin D supplementation on overall mortality. PLoS One. 2013;8(12):e82109. doi: 10.1371/journal.pone.0082109. PMID: 23559082. Exclusion Code: X1.24349197
134 Zheng YT, Cui QQ, Hong YM, . A meta-analysis of high dose, intermittent vitamin D supplementation among older adults. PLoS One. 2015;10(1):e0115850. doi: 10.1371/journal.pone.0115850. PMID: 25664999. Exclusion Code: X1.25602255
135 Zuk A, Fitzpatrick T, Rosella LC. Effect of vitamin D3 supplementation on inflammatory markers and glycemic measures among overweight or obese adults: a systematic review of randomized controlled trials. PLoS One. 2016;11(4):e0154215. doi: 10.1371/journal.pone.0154215. PMID: 27094871. Exclusion Code: X7.27116227
136 Zwart SR, Parsons H, Kimlin M, . A 250 mug/week dose of vitamin D was as effective as a 50 mug/d dose in healthy adults, but a regimen of four weekly followed by monthly doses of 1250 mug raised the risk of hypercalciuria. Br J Nutr. 2013 Nov;110(10):1866–72. doi: 10.1017/s000711451300113x. PMID: 23314982. Exclusion Code: X4.23595003