# Appendix B Additional Methods Information

## Appendix B1 Search Strategy

### PubMed Search Strategy

Appendix B Table B1 Combined KQs PubMed (January 1, 2013 through March 12, 2020)

Screening and Treatment

#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Vitamin D”[Mesh] OR “Vitamin D Deficiency”[Mesh] Sort by: Best Match
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Mass Screening”[Mesh]) OR “Diagnostic Tests, Routine”[Mesh] Sort by: Best Match
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) Sort by: Best Match
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) Sort by: Best Match Filters: Publication date from 2013/01/01; Humans; English; Adult: 19+ years
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Administration, Oral”[Mesh]) OR “Parenteral Nutrition”[Mesh]) OR “Prescriptions”[Mesh]) OR “Diet”[Mesh] Sort by: Best Match
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Vitamin D/administration and dosage”[Mesh] OR “Vitamin D/adverse effects”[Mesh] OR “Vitamin D/contraindications”[Mesh] OR “Vitamin D/poisoning”[Mesh] OR “Vitamin D/therapeutic use”[Mesh] OR “Vitamin D/toxicity”[Mesh] ) Sort by: Best Match
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 OR #9) Sort by: Best Match
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Vitamin D Deficiency”[Mesh] Sort by: Best Match
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match Filters: Publication date from 2013/01/01; Humans; English; Adult: 19+ years
#41 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 OR #19) Sort by: Best Match

Harms

#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Vitamin D”[Mesh] OR “Vitamin D Deficiency”[Mesh] Sort by: Best Match
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Mass Screening”[Mesh]) OR “Diagnostic Tests, Routine”[Mesh] Sort by: Best Match
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) Sort by: Best Match
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) Sort by: Best Match Filters: Humans
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) Sort by: Best Match Filters: Humans; English
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) Sort by: Best Match Filters: Humans; English; Adult: 19+ years
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) Sort by: Best Match Filters: Publication date from 2013/01/01; Humans; English; Adult: 19+ years
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((“Risk”[Mesh]) OR “Morbidity”[Mesh]) OR “Comorbidity”[Mesh]) OR “adverse effects” [Subheading]) OR ( “Mortality”[Mesh] OR “mortality” [Subheading] ) OR harms[tw]) Sort by: Best Match
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #8) Sort by: Best Match
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 OR #9) Sort by: Best Match
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Epidemiologic Studies”[Mesh]) OR “Outcome and Process Assessment (Health Care)”[Mesh]) OR “Vital Statistics”[Mesh] Sort by: Best Match
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match Filters: Controlled Clinical Trial; Guideline
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match Filters: Controlled Clinical Trial; Guideline; Meta-Analysis
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match Filters: Controlled Clinical Trial; Guideline; Meta-Analysis; Randomized Controlled Trial
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match Filters: Controlled Clinical Trial; Guideline; Meta-Analysis; Randomized Controlled Trial; Systematic Reviews
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match Filters: Controlled Clinical Trial; Guideline; Meta-Analysis; Randomized Controlled Trial; Systematic Reviews; Humans
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match Filters: Controlled Clinical Trial; Guideline; Meta-Analysis; Randomized Controlled Trial; Systematic Reviews; Humans; English
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match Filters: Controlled Clinical Trial; Guideline; Meta-Analysis; Randomized Controlled Trial; Systematic Reviews; Humans; English; Adult: 19+ years
#20 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Sort by: Best Match Filters: Controlled Clinical Trial; Guideline; Meta-Analysis; Randomized Controlled Trial; Systematic Reviews; Publication date from 2013/01/01; Humans; English; Adult: 19+ years

Combined PubMed=1,395 (three were included in prior report and not considered as having been identified through the electronic search)

### Other Data Sources

- Cochrane Reviews=21 total, 1 unique
- Cochrane Controlled Clinical Trials Registry=143 total, 78 unique
- Embase=167 total, 127 unique
- ClinicalTrials.gov=24 total,18 unique
- Health Services Research Projects in Process (HSRProj)=8 total, 4 unique
- World Health Organization International Clinical Trials Registry Platform=7 total, 4 unique

## Appendix B2 Study Selection Criteria

| Include | Exclude
Population | KQs 1, 2: Nonpregnant adults age ≥18 years without known vitamin D deficiency; KQs 3, 4: Nonpregnant adults enrolled in studies based on a vitamin D level <30 ng/mL; studies in which at least 90% of the study population have serum vitamin D levels below this threshold will also be included | - Pregnant women; - Persons with clinical signs of vitamin D deficiency; - Studies in which participants are selected for a condition (e.g., osteoporosis, malabsorption, chronic kidney disease) that is associated with altered vitamin D levels or bone metabolism; - Studies in which participants are selected for a specific clinical condition (e.g., depression, diabetes, infertility, multiple sclerosis) to assess the benefit of adding vitamin D to existing treatment
Intervention | KQs 1, 2: Screening with serum 25-hydroxyvitamin D assay; KQs 3, 4: Treatment with oral or injectable vitamin D_2_ or D_3_, with or without calcium | KQs 1, 2: Vitamin D−binding protein; 1,25-dihydroxycholecalciferol assay; KQs 3, 4: Food-based interventions; vitamin D analogs, multivitamins with a vitamin D component, sun, or ultraviolet exposure
Comparison | KQs 1, 2: No screening; KQs 3, 4: Placebo or no treatment, or usual care | KQs 1, 2: Head-to-head comparisons of different serum vitamin D assays; KQs 3, 4: Head-to-head comparisons of different vitamin D doses or formulations
Outcomes | KQs 1, 3:; - All-cause mortality; - Incidence of falls; - Incidence of fractures; - Incidence of other health outcomes, such as diabetes, cardiovascular disease, cancer, dementia, autoimmune disease, and infections; - Quality of life, as measured by a validated instrument; - Self-reported physical functioning, as measured by a validated instrument; KQ 2: Anxiety and labeling; KQ 4: Toxicity, renal harms (e.g., nephrolithiasis), and other adverse events | KQs 1, 3: Changes in serum vitamin D levels, intermediate physiologic outcomes (bone mineral density, osteoporosis, blood pressure, cholesterol, glucose, muscle mass), behavioral outcomes (changes in diet or physical activity), or physical fitness/muscle strength measures (e.g., grip strength, timed up and go test, distance walked test, step test, balance test); KQs 2, 4: None
Timing | KQ 1: Outcomes measured at 8 weeks or longer after screening; KQ 3: Treatment intervention lasting at least 8 weeks; outcomes measured at 8 weeks or longer after start of treatment; KQs 2, 4: Any duration and any timing of measurement | KQ 1: Outcomes measured at less than 8 weeks after screening; KQ 3: Treatment intervention lasting less than 8 weeks or outcomes measured at less than 8 weeks after start of treatment; KQs 2, 4: None
Settings | Countries categorized as “very high” on the 2016 Human Development Index (as defined by the United Nations Development Programme);^64^ primary care settings and settings generalizable to primary care institutional settings (e.g., nursing homes) | Countries categorized as less than “very high” on the Human Development Index
Study design | KQs 1, 3: CCTs, RCTs, and nested case-control studies within RCTs; systematic reviews of CCTs or RCTs with a similar scope to this review; KQs 2, 4: CCTs, RCTs, cohort studies, case-control studies, and systematic reviews with a similar scope to this review | Editorials, narrative reviews, letters to the editor, and study designs not listed as specifically included (e.g., case reports, case series, studies without a comparison group)
Language | English language | Languages other than English
Study quality | Good- and fair-quality studies (i.e., studies with low risk of bias or some concerns for bias) | Poor-quality studies (i.e., studies with high risk of bias)

Abbreviations: CCT=controlled clinical trial; KQ=key question; RCT=randomized, controlled trial.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: Equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

### Definition of Ratings Based on Above Criteria

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.
Poor:: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

Good:: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
Fair:: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor:: Has a fatal flaw, such as using inappropriate reference standard, improperly administering screening test, using biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

Sources: Harris et al, 2001^207^ and U.S. Preventive Services Task Force, Procedure Manual, Appendix VI Criteria for Assessing Internal Validity of Individual Studies. Available at https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes