# Appendix A Contextual Questions

Contextual Questions (CQs) 1, 2, and 3 were designed to provide the USPSTF with additional information about vitamin D assays and the relationship between vitamin D deficiency and selected outcomes. CQ 1 was designed to provide the USPSTF with the historical context surrounding vitamin D assays. CQ 2 was designed to provide the USPSTF information about the association between vitamin D and health outcomes from observational studies, building on a previous 2014 AHRQ Effective Health Care (EHC) review.^22^ Finally, CQ 3 was designed to provide the USPSTF with information about the effect of vitamin D treatment on selected intermediate outcomes, again building on the previous 2014 AHRQ EHC review.

## CQ 1 What Are the Various Assays for Measuring Serum Vitamin D, Including Total 25(OH)D, Free 25(OH)D, and 1,25 (OH)2D, and What Is Known About Intermethod and Interlaboratory Variability of the Various Assays?

Key Points:

- Historically, it has been difficult to measure 25(OH)D accurately, which has resulted in assay variability and bias with likely misclassification of vitamin D status, especially for levels close to a threshold, in both research studies and clinical practice.
- LC-MS/MS is considered the gold-standard assay. But it is complex to perform and can still be subject to variation and error.
- Since the establishment of the VDSP in 2010, great strides have been made toward standardizing vitamin D assays. However, there are limited data on how quickly this standardization is being adopted by small and large commercial laboratories and as part of previous and ongoing research studies.
- Although several vitamin D metabolites are under active investigation as markers of vitamin D status, their association with clinical outcomes is much less studied than 25(OH)D, and the research suffers from the same assay standardization issues that have plagued 25(OH)D research until the recent development of the VDSP standardization program.

### Assays for Measuring Total 25 Hydroxyvitamin D (25(OH)D)

25(OH)D is currently considered the best marker of vitamin D status.^34^ 25(OH)D is defined as the sum of 25 (OH)_2_ and 25(OH)_3._ Total 25(OH)D is measured by both binding and chemical assays. Binding assays include competitive protein binding assays, radioimmunoassays, and chemiluminescence immunoassays. Automated immunoassays are popular in clinical laboratories because they are available in kit form and can be automated to process hundreds of samples per hour.^161^ Chemical assays include HPLC (LC with UV detection), LC-MS, and LC-MS/MS. Traditionally, chemical assays have been more technically involved requiring more expertise. Although traditionally a much smaller number of samples could be run at a time using chemical assays, advancing technology is allowing an increasing number of samples to be processed per day with these types of assays.^161^

Serum total 25(OH)D is difficult to measure accurately because of several issues.^34^ First, total 25(OH)D assays need to recognize both 25(OH)_2_ and 25(OH)_3_. In immunoassays, the antibodies used to measure 25(OH)D can have a low affinity for 25(OH)_2_, leading to low estimates of total 25(OH)D. Conversely, some 25(OH)D assays measure vitamin D metabolites, leading to an overestimation of 25(OH)D. For example, some immunoassays cross-react with 24,25(OH)_2_D, which can account for up to 20% of the measured total vitamin D. 25(OH)D is also a very hydrophobic molecule that circulates bound to vitamin D binding protein (DBP), albumin, and lipoproteins; it is therefore mandatory that 25(OH)D is completely dissociated from its carriers prior to measurement. The dissociation step is complicated because 25(OH)_2_ and 25(OH)_3_ have different affinities for the carriers. Also, immunoassays use different sample preparations, resulting in variable release of DBP and other binding proteins from 25(OH)D, leading to discrepant results, especially in those with high or low DBP concentrations.^34^ All of these issues can lead to misclassification of vitamin D status, especially if levels are close to the thresholds for defining vitamin D status.

LC methods offer the advantage of being able to individually quantify 25(OH)2 and 25(OH)3 and remove interfering substances.^162^ Adding MS and particularly, tandem mass spectrometry (MS/MS) can account for protein binding and provide structure-specific information on the molecules. As a result, LC-MS/MS is considered the gold-standard assay. Despite its benefits, LC-MS/MS is still subject to variation and error, including interference from other chemical compounds (such as the 3-epimers of 25(OH)D).^34^ In addition, performing LC-MS/MS is complex, requiring extensive experience and training and extensive validation of both the LC-MS/MS and sample preparation methods.

### Reliability of Measurement

Given these assay issues, the Vitamin D External Quality Assessment Scheme (DEQAS) was established in 1989 with the objective of ensuring the reliability of measurements of serum total 25(OH)D. DEQAS distributes human serum samples for analysis of 25(OH)D to participating laboratories in multiple countries. As of January 2017, DEQAS was distributing five human serum samples quarterly to approximately 1,000 laboratories in 56 countries that were using 30 different assay methods. The participating laboratories receive summary reports about their laboratory’s results (both overall and by individual method used). Until late 2012, these reports compared each laboratory’s result to a consensus value based on the all-laboratory trimmed mean (ALTM) of the results of the participating laboratories. However, use of the ALTM rather than a “true” value limited the ability of the DEQAS program to evaluate the true performance of laboratory assays because the results were influenced by the dominance of the most popular assays, the changing mix of assays, and biases of the assays.

In 2010, the U.S. National Institutes of Health (NIH) Office of Dietary Supplements (ODS) initiated the VDSP in collaboration with CDC, the U.S. National Institute of Standards and Technology (NIST), Ghent University (Belgium), national nutrition survey laboratories in eight countries, and vitamin D researchers worldwide.^163,^ ^164^ The primary goal of the VDSP has been to promote the standardized measurement of 25(OH)D to enhance patient care and facilitate the research study of vitamin D. A key part of the VDSP has been the establishment of a reference measurement system, including reference measurement procedures developed by multiple collaborators including NIST, Ghent University, and CDC. These reference measurement systems were developed to provide a true value of 25(OH)D that could be used as the gold standard for comparison to vitamin D results obtained from routine assays in research and clinical care. The NIST reference measurement procedures are based on isotope dilution LC-MS/MS, which is considered the most accurate and precise method to determine 25(OH)_2_ and 25(OH)_3_.^165^

VDSP and its collaborators (CDC, NIST) have developed cost-effective tools and methods to standardize 25(OH)D measurement prospectively in current and future vitamin D research as well as retrospectively from past studies with banked samples.^166^ The development of the VDSP and reference measurement procedures have therefore allowed the first unbiased evaluation of 25(OH) assay variation.^34^ As part of the VDSP, all DEQAS samples have been analyzed (since late fall 2012) using the NIST reference measurement procedures in addition to the consensus value based on ALTM. When the results of using the NIST-assigned target were compared with the ALTM, there was evidence that significant bias occurred when the ALTM value was used as the reference point. There was a great deal of sample-to-sample variation within laboratories using the same assay and also between different assay platforms.^34^ For example, in a recent study coordinated by the VDSP group,^167^ a set of 50 samples from healthy individuals was analyzed by 16 different laboratories to provide results for total 25(OH)D using both immunoassays and LC-MS/MS methods. The results were compared with those obtained by two reference methods: NIST and a similar reference method from the Ghent University.^168^ Results showed that only 50 percent of immunoassays achieved the VDSP criteria of performance (namely coefficient of variation ≤10% and mean bias ≤5%); however, 80 percent of LC-MS/MS assays met the VDSP criteria.^167^ Results would likely have been even worse if samples from patients with chronic kidney disease or other health conditions, pregnant women, or different ethnic groups were used.^169^

Researchers have been retrospectively rerunning previously banked samples using the standardized methods developed as part of the VDSP and comparing updated results with previously reported data measured using unstandardized methods. Standardization of these databases have resulted in both upward and downward reporting of 25(OH)D levels,^34,^ ^170,^ ^171^ indicating that standardization may lead to an increase or decrease in observed 25(OH)D levels depending on the original assay that was used. In NHANES data, standardization of serum total 25(OH)D values has led to a narrower range of 25(OH)D values,^172^ resulting in a dramatic difference in the prevalence of low vitamin D status in samples analyzed by unstandardized and standardized methods.^171^ For example, although NHANES originally reported that 25(OH)D levels in the U.S. population had declined, after rerunning the samples using standardized methods, there was no change in vitamin D levels between 1988 and 2006.^12^ In another reanalysis of NHANES data, a previously noted reverse J-shaped association between 25(OH)D concentration and risk of death was no longer present; using standardized procedures to measure vitamin D status, only 25(OH)D concentrations <16 ng/ml were associated with an increased risk of death.^172^

CDC, in collaboration with the VDSP, has also developed the Vitamin D Standardization-Certification Program (VDSCP), a program to standardize commercial assay systems and large commercial or research laboratories. The certification program is conducted over a 1-year period and requires laboratories to develop a reference system, establish metrological traceability, and verify “end user” test performance.^161^ When participants pass four consecutive surveys, they are awarded certification for 1 year. Renewal is annual, which means that maintenance of certification requires continuous participation in the program. Laboratories that are certified by this program are listed on the CDC website. As of November 2019, 19 certificates had been issued in the previous 12 months (26% to research laboratories, 32% to clinical laboratories, and 42% to assay/kit manufacturers) and 57 in the previous 36 months (27% research, 20% clinical, and 53% assay/kit manufacturers).^173^

### Other Measurements of Vitamin D Status

Other vitamin D metabolites are under active investigation to determine if they can help inform a person’s vitamin D status. Potential markers include free 25(OH)D, DBP, 1-alpha 25(OH)_2_D, 24, 25(OH)_2_D_3_, and PTH. There are no standardization programs for these metabolites, so research of these metabolites is at risk of bias from assay variation, similar to research using unstandardized 25(OH)D assays.^34^ Each metabolite is described briefly below.

#### Free 25(OH)D

It is hypothesized that the unbound fraction (<1%) of vitamin D, free 25(OH)D, drives many of vitamin D’s effects. Free 25(OH)D can be measured directly or can be calculated. There is no certified reference material for directly measuring free 25(OH)D, and development of a certified reference material for directly measuring free 25(OH)D will be very difficult because the concentration of free 25(OH)D is at the limit of current LC-MS/MS technology.^34^

#### DBP

Because vitamin D is transported primarily by DBP and albumin, it can also be calculated using total 25(OH)D, DBP, and albumin levels. However, DBP and albumin concentrations vary in different clinical conditions and according to the assay used. For example, persons with particular DBP genotypes have lower measured concentrations of DBP when measured by monoclonal assays compared with LC-MS/MS or polyclonal assays.^174^ This assay variation likely explains the varying findings regarding levels of DBP in black versus white patients.^175^ NIST has recently developed an assay for DBP that may eventually lead to the development of reference measurement procedures and eventual standardization of DBP. Such standardization could lead to improvements in calculation of “free” 25(OH)D.

#### 1-alpha 25(OH)_2_D

This compound is the active, hormone form of vitamin D. It has a relatively short half-life and is tightly controlled by PTH, calcium, and phosphate, so is not considered a useful measurement of vitamin D status. It should only be measured in association with other vitamin D metabolites. DEQAS does run a program for 1-alpha 25(OH)_2_D, but there are no reference measurement procedures, limiting the ability of this program to lead to improved 1-alpha 25(OH)_2_D assay accuracy.

#### 24,25(OH)_2_D_3_

This compound results from the degradation of 25(OH)D, and its expression has been shown to be increased when there is increased binding and activation of the vitamin D receptor (VDR) in response to 1-alpha 25(OH)_2_D.^176^ 24,25(OH)_2_D_3_ concentration may therefore reflect VDR activity. As a result, there is growing interest in measuring 24,25(OH)_2_D_3_ and calculating the 25(OH)D/24,25(OH)_2_D_3_ ratio, which is known as the Vitamin D Metabolism Ratio (VMR).^177^ Studies have reported that VMR predicts vitamin D_3_ supplementation^34^ and that lower 24,25(OH)_2_D_3_ concentration and lower VMR are associated with increased hip fracture risk in community-living older people. Of particular interest given the paradox that more blacks carry a diagnosis of vitamin D deficiency than whites yet do not have a higher risk for fractures than whites, VMR was shown to be similar in black and white Americans, unlike 25(OH)D levels, which were lower among blacks.^178^ NIST has developed a reference measurement procedure for 24,25(OH)_2_D_3_, which could lead to improved standardization of 24,25(OH)_2_D_3_ measurements.^34^

#### PTH

The tight connection between calcium, 1-alpha 25(OH)D, and PTH makes PTH another possible marker of vitamin D status. However, the threshold at which PTH rises when 25(OH)D levels are physiologically low is inconsistent across individuals.^34^ Other barriers to using PTH include differences in standardization of the PTH assays and other analytical issues.

## CQ 2 In Observational Studies, What Is the Association Between Vitamin D Use or Serum Vitamin D Levels and the Incidence of Selected Health Outcomes (i.e., Mortality, Fractures, Falls, Cardiovascular Disease, Cancer, Diabetes, Dementia, Autoimmune Disease, or Infections)?

Though KQ 3 and CQ 2 in this review are both focused on the relationship between vitamin D and health outcomes, it is important to note three important differences between them. First, evidence synthesized in KQ 3 comes from trials, while evidence described in CQ 2 comes from observational studies. Second, KQ 3 is focused on vitamin D–deficient adult populations; the data in support of CQ 2 come from studies that are not limited to vitamin D–deficient populations (and include people with all levels of vitamin D). Finally, all the trials included in KQ 3 evaluate treatment with vitamin D, while almost all the observational studies in CQ 2 assess the relationship between serum vitamin D levels (usually measured at the study baseline) and health outcomes. It is important to note the numerous limitations of the evidence from observational studies that should be considered when evaluating the potential relationships between vitamin D and health outcomes: observational studies are meant to generate hypotheses about potential associations and do not reflect causal relationships; residual confounding remains an issue; time between serum vitamin D levels at study entry and incidence of diagnosis may or may not make sense biologically; and potential outcome misclassification due to self-reported outcome measures are problematic in the observational body of evidence regarding vitamin D.

To describe the evidence from observational studies on the association between vitamin D levels and health outcomes published before 2014, we relied primarily on the 2014 AHRQ evidence report/health technology assessment titled “Vitamin D and Calcium: A Systematic Review of Health Outcomes (Update),” which was sponsored by the NIH Office of Dietary Supplements to support the updating of the IOM’s Dietary Reference Intakes.^22^ Observational studies of the association between vitamin D and health outcomes (e.g., bone health, all-cause mortality, cardiovascular mortality, cancer) were eligible for this 2014 report. The authors of the evidence report concluded that results from observational studies, if consistent with each other, were not consistent with the results from RCTs, and no firm conclusions could be drawn from the combined RCT and observational body of evidence. Additionally, we identified 21 primary observational studies and 14 systematic reviews or meta-analyses from our systematic literature search, published since the 2014 AHRQ review,^22^ that could further address this question.

Overall, the findings are:

Lower serum vitamin D levels may be associated with a higher incidence of mortality, cardiovascular disease and deaths, diabetes, and dementia; the evidence, however, is somewhat inconsistent both among the observational studies and is inconsistent with the evidence from trials.

Conclusions about an association between serum vitamin D levels and the incidence of cancer, fractures, falls, autoimmune disease, and infections cannot be determined because of mixed or sparse evidence.

Details of the findings from the 2014 AHRQ review and results from studies published since then are in Table A1 (noncancer health outcomes) and Table A2 (cancer health outcomes).

## CQ 3 What Is the Relationship Between Vitamin D Use and Selected Intermediate Outcomes (i.e., Bone Mineral Density, Blood Pressure, or Measures of Physical or Muscle Strength)?

To address this question, we relied on the 2014 AHRQ evidence report/health technology assessment titled “Vitamin D and Calcium: A Systematic Review of Health Outcomes (Update)” sponsored by the NIH Office of Dietary Supplements to support the updating of the IOM’s Dietary Reference Intakes.^22^ We note that this report was not restricted to included studies among vitamin D–deficient populations. To identify relevant studies published since 2014 that could further address this question in vitamin D–deficient populations, we identified 29 RCTs included for either KQ 3 or KQ 4 in our current update that also reported intermediate outcomes. In addition to these 29 studies, we identified seven additional RCTs reporting intermediate outcomes that were excluded from the KQ portion of this update because “hard” health outcomes were not reported by these studies. Thus, a total of 36 new RCTs were used to supplement the findings from the 2014 AHRQ review regarding the relationship between treatment with vitamin D and intermediate outcomes.

Overall, treatment with vitamin D (with or without calcium) appears to have no effect on any intermediate outcomes. A summary of findings organized by outcomes is provided in Appendix A Table A3.

Table A1 Summary of Relationship Between Serum Vitamin D Levels and Selected Health Outcomes Among Observational Studies

Health Outcome | Results From 2014 AHRQ Systematic Review^22,*^ | Results From Studies Published Since 2014 Review^22^ | Conclusion About the Vitamin D–Health Outcome Relationship
Mortality | 29 observational studies; - 10 studies reported no association; - 17 studies reported an inverse association (i.e., lower serum levels are associated with higher mortality); - 2 studies reported a U-shaped association | 8 observational studies; - 1 IPD MA of 8 observational studies in a Northern European consortium reported a significant inverse association between vitamin D levels and mortality over a median followup of 10.5 years; participants with vitamin D concentrations of <30 nmol/L had an adjusted HR of 1.67 (95% CI, 1.44 to 1.89) for all-cause mortality compared with participants with levels of 75 to 99.9 nmol/L.^179^; - 1 IPD MA of 8 European and U.S.-based prospective cohort studies in the CHANCES consortium (plus NHANES III) reported a significant inverse association between vitamin D levels and all-cause mortality (RR, 1.57 [95% CI, 1.36 to 1.81]) when comparing the bottom to the top quartile of vitamin D levels.^180^; - 1 SR of 9 studies (24,297 participants) reported a significant inverse association between vitamin D levels and all-cause mortality; the association was stronger among older adults (pooled HR, 1.25 [95% CI, 1.14 to 1.36]) than younger participants (pooled HR, 1.12 [95% CI, 1.01 to 1.24]).^181^; - 3 cohort studies (ESTHER, NHANES III, NESDO) reported inverse associations between vitamin D levels and all-cause mortality;^182^ association was only significant among vitamin D–insufficient or –deficient participants^183^ and may be modified by vitamin A supplementation.^184^; - The Whitehall study among older men reported an HR of 0.78 (95% CI, 0.72 to 0.85) for all-cause mortality associated with a 2-fold higher measured vitamin D level^185^; ○ Significant inverse association was replicated in an MA of 18 studies performed by the same authors; individuals in the top quarter of serum vitamin D levels had 28% lower all-cause mortality (95% CI, 24% to 32%) compared with individuals in the bottom quarter | Possible inverse association, but the evidence is not entirely consistent.
Fractures | 23 observational studies; - Hip: 3 studies showed mixed results and 1 study reported an inverse association; - Nonvertebral: 2 studies showed no association and 1 study reported an association; - Total fragility: 2 studies showed mixed results; - Fractures, not otherwise defined: 10 studies reported an inverse association | 1 observational study; - 1 case-cohort analysis of men enrolled in the MrOS reported mixed results:^186^; ○ No association with nonvertebral fractures; ○ Significant increase in risk of hip fracture when comparing the lowest quartile of serum vitamin D levels to the rest of the participants; the significant protective effect of higher vitamin D levels was, however, restricted to the second quartile (20.91 to 25.90 ng/mL) | Cannot be determined
Falls | 5 observational studies; - 2 cohort studies reported an inverse association; - 2 cohort studies and 1 case-control study reported mixed results or no association | 1 observational study; - 1 MA of 18 observational studies (10 cross-sectional and 8 cohort studies) reported an inverse association between serum vitamin D levels and risk of falls (summary OR, 0.97 [95% CI, 0.96 to 0.99]); the association between falls and vitamin D deficiency varied depending on the threshold used for deficiency^187^ | Cannot be determined
Cardiovascular disease | 28 observational studies 1 good-quality SR of 17 prospective studies,^†^ 2 cohort studies, and 1 nested case-control study reported an inverse association; - 2 cohort studies and 1 nested case-control study reported mixed effects; - 3 cohort studies and 2 nested-case control studies reported no association | 6 observational studies; - 1 SR of 27 studies reported an inverse association between vitamin D and total CVD events (pooled RR per 10 ng/mL increase in vitamin D, 0.90 [ 95% CI, 0.86 to 0.94])^188^; - 1 cohort study (MrOS) reported no association between vitamin D levels and all CVD or CHD events combined, and a significant increased risk of cerebrovascular events among vitamin D–deficient men after excluding supplement users (HR, 1.70 [95% CI, 1.02 to 2.83])^189^; - The Copenhagen City Heart Study reported a stepwise increased risk of ischemic stroke with stepwise decreased vitamin D levels; the HR for ischemic stroke was 1.36 (95% CI, 1.09 to 1.70) for vitamin D–deficient participants (<10 ng/mL) compared with vitamin D–optimized participants (≥30 ng/mL). There was no association with hemorrhagic stroke.^190^; ○ Authors of the Copenhagen City Heart Study also performed an MA of 10 prospective studies and reported an HR of 1.46 (95% CI, 1.35 to 1.58) for the lowest versus highest quartile of vitamin D levels^190^; - Over a median followup of 21 years, there was no association between vitamin D levels and incident atrial fibrillation in the ARIC study except for among younger participants (HR, 1.35 [ 95% CI, 1.05 to 1.73]) when comparing deficient (<20 ng/mL) to optimal levels (≥30 ng/mL) of vitamin D.^191^; ○ Authors of the ARIC study also performed an MA of 5 prospective studies and reported no association | Possible inverse association, but the evidence is not entirely consistent.
Cardiovascular disease deaths | 18 observational studies; - 7 cohort studies and 1 nested case-control study reported mixed results; - 10 cohort studies reported no association | 4 observational studies; - 1 SR of 27 studies reported an inverse association between vitamin D and CVD mortality (pooled RR per 10 ng/mL increase in vitamin D, 0.88 [95% CI, 0.80 to 0.96])^188^; - 2 IPD MA of prospective studies in Europe and the United States reported significant inverse associations between vitamin D levels and cardiovascular mortality^179,^ ^180^; - 1 cohort study (NHANES III: 1988-1994) reported an inverse association between vitamin D and CHD death,^ǂ^ but it was only significant when comparing the lowest to the highest quartile in adjusted models^192^ | Possible inverse association but the evidence is not entirely consistent.
Diabetes | Not included in 2014 SR | 3 observational studies; - The Copenhagen City Heart Study (9,841 participants, 29 years of followup) reported a significant increased risk of type 2 diabetes when comparing the lowest to the highest quartile of 25(OH)D levels (HR, 1.35 [95% CI, 1.09 to 1.66])^193^; ○ Authors of the Copenhagen City Heart Study also performed an MA of 16 cohort and nested case-control studies (including theirs) and reported the same association (OR, 1.50 [95% CI, 1.33 to 1.70] for bottom compared with top quartile)^193^; - The ESTHER cohort study in Germany reported a significant inverse association between serum vitamin D levels and incident type 2 diabetes among women but not men^194^ | Possible inverse association
Dementia | Not included in 2014 SR | 5 observational studies; - 1 MA of 26 observational studies reported significantly poorer cognition among participants with low vitamin D status (OR, 1.24 [95% CI, 1.14 to 1.35]); the effect was stronger among cross-sectional than longitudinal studies^195^; - 3 cohort studies, 2 among the general population and 1 among elderly men, reported mixed results depending on domains of cognitive performance^196,^ ^197^ or no association^198^; - 1 cohort of Swedish men (mean age 71 years) reported no association between baseline vitamin D status and long-term (i.e., 18 year period of time) risk of dementia or cognitive impairment^199^ | Possible inverse association, but the evidence is not entirely consistent.
Autoimmune disease | 2 observational studies; - 1 nested case-control study reported mixed results for type 1 diabetes mellitus; - 1 nested case-control study reported mixed results for multiple sclerosis | 2 observational studies; - 1 MA of 27 case-control studies reported that Crohn’s disease patients had significantly lower levels of serum vitamin D (pooled mean difference-3.99 [95% CI, −5.91 to −2.08]) than healthy controls; there was substantial heterogeneity of effects.^200^; - 1 analysis of the Hospital Episode Statistics database in England from 1999 to 2011 reported significantly higher rates of autoimmune disease (e.g., Crohn’s disease, rheumatoid arthritis, celiac disease) among people admitted for vitamin D deficiency^201^ | Possible inverse association specifically for Crohn’s disease, evidence inconclusive or not available for other conditions.
Infections | 4 observational studies; - 1 cohort study reported an inverse association with acute respiratory illness; - 1 cohort study reported no association with respiratory mortality; - 1 cohort study reported no association with infectious disease mortality; - 1 cohort study reported an inverse association with pneumonia; only the comparison between the 1^st^ and 3^rd^ tertile was significant. | 1 observational study; - 1 cohort of over 6,000 middle-aged and elderly participants in the Norwegian Tromsø Study reported no association between baseline serum vitamin D levels and presence or duration of self-reported symptoms of respiratory tract infection within 28 days of baseline^202^ | Cannot be determined

* Results from the 2014 AHRQ review include all results reported in the 2006 and 2009 AHRQ reviews and results from eligible studies published since the 2009 AHRQ review.

† The SR included 16 prospective studies that were included in either the original AHRQ report or the 2014 update^22^ and one prospective study that was excluded from the 2014 update.^22^

ǂ Underlying causes of CHD death included acute myocardial infarction, other acute ischemic heart diseases, atherosclerotic cardiovascular disease, and all other forms of chronic ischemic heart diseases.

Abbreviations: 25(OH)D=vitamin D; AHRQ=Agency for Healthcare Quality and Research; ARIC=Atherosclerosis Risk in Communities; CHANCES=Consortium on Health and Aging: Network of Cohorts in Europe and the United States; CHD=coronary heart disease; CI=confidence interval; CVD=cardiovascular disease; ESTHER=German Epidemiologische Studie zu Chancen der Verhütung, Früherkennung und optimierten Therapie chronischer Erkrankungen in der älteren Bevölkerung; HR=hazard ratio; IPD=individual patient data; MA=meta-analysis; MrOS=Osteoporotic Fractures in Men Study; NESDO=Netherlands Study on Depression in Older Adults; NHANES=National Health and Nutrition Examination Survey; OR=odds ratio; RR=relative risk; SR=systematic review.

Table A2 Summary of Relationship Between Serum Vitamin D Levels and Cancer Outcomes Among Observational Studies

Cancer Outcome | Results From 2014 Systematic Review Update^22^ | Results From Studies Published Since 2014 Review^22^ | Conclusion About the Vitamin D–Health Outcome Relationship
All cancer | 3 observational studies; - 1 cohort study reported an inverse association; - 1 cohort study reported mixed results; - 1 cohort study reported no association | No additional studies identified by our search | Cannot be determined
Cancer mortality | 11 observational studies; - 2 cohort studies reported inverse association; - 1 cohort study reported U-shaped association; - 3 cohort studies and 1 nested case-control study reported mixed results; - 4 cohort studies reported no association | No additional studies identified by our search | Cannot be determined
Prostate cancer | 19 observational studies; - 1 cohort study reported no association; - 1 nested case-control study reported an increased risk of prostate cancer with increased vitamin D levels while 1 nested case-control study reported an inverse association; - 5 nested case-control studies reported mixed results or a U-shaped association; - 11 nested case-control studies reported no association | 2 observational studies; - 1 nested case-control study reported an inverse association between serum vitamin D levels and risk of prostate cancer (OR, 0.30 [95% CI, 0.12 to 0.77] for highest versus lowest quartile; p trend 0.007)^203^; - 1 nested case-control study from the Prostate Cancer Prevention Trial reported mixed results by stage of cancer; authors concluded that higher vitamin D levels may increase risk of lower stage prostate cancer and may decrease risk of higher stage prostate cancer^204^ | Cannot be determined
Colorectal cancer | 9 observational studies; - 2 nested case-control studies reported inverse association; - Among women, 3 nested case-control studies reported inverse association and 1 nested case-control study reported no association; - Among men, 4 nested case-control studies reported no association | 1 observational study; - 1 case-control study, nested within the Women’s Health Study, reported that mean prediagnostic levels of vitamin D were significantly lower in cases (21.9 ng/mL) than controls (23.9 ng/mL) and that there was a significant inverse association between vitamin D and both incident colorectal cancer and colorectal cancer-related mortality^205^ | Cannot be determined
Breast cancer | 11 observational studies; - 2 cohort studies reported no association; - 2 nested case-control studies reported inverse association; - 7 case-control studies reported no association | 1 observational study; - 1 nested case-control study reported mixed results that were mediated by BMI status and alcohol intake^206^ | Cannot be determined
Pancreatic cancer | 3 observational studies; - 1 pooled case-control study based on 8 cohort studies reported increased risk when comparing 6th to 1st sextile of vitamin D levels; - 1 nested case-control study reported increased risk when comparing 5th to 1st quintile; - 1 nested case-control study reported mixed results based on UVB exposure status | No additional studies identified by our search | Cannot be determined

Abbreviations: BMI=body mass index; CI=confidence interval; OR=odds ratio; UVB=type B ultraviolet.

Table A3 Summary of Relationship Between Treatment With Vitamin D and Intermediate Outcomes

Intermediate Outcome | Results From 2014 Systematic Review | Results From Studies Published Since 2014 Review Among Vitamin D–Deficient Populations | Impression About the Vitamin D–Intermediate Outcome Relationship
Bone mineral density | 10 RCTs of vitamin D supplementation in adults, 9 showed no effect and 1 showed reduced loss of BMD at hip but not at spine in postmenopausal women.; 7 RCTs of vitamin D and calcium supplementation, 2 showed positive effects and 4 showed mixed effects in postmenopausal women, 1 showed no effect in men. | 9 RCTs of vitamin D with or without calcium, one reported mixed effects depending on method of measurement (broadband ultrasound attenuation vs. speed of sound); the rest measured BMD using DXA at the hip or spine and reported no differences between active treatment and control groups. | No relationship
Muscle/-physical strength | 2 RCTs of vitamin D supplementation, both showed positive effect but only one of the RCTs was conducted in participants with low vitamin D levels; 4 cohort studies, 3 showed inverse association between vitamin D levels and muscle strength; 2 RCTs of vitamin D and calcium supplementation, no effects reported. | 11 RCTs reporting on various measures of muscle/physical strength including timed up and go test, balance tests, chair rise tests, 3-meter walk, jump height, handgrip strength, with the exception of one RCT, no differences between active treatment and control group was observed. | Probably no relationship
Hypertension/blood pressure | No RCTs of vitamin D supplementation; 4 observational studies; 3 show an inverse relationship between vitamin D levels and risk of hypertension (i.e., lower levels means high risk), 1 shows a J-shaped association.; 1 RCT of vitamin D and calcium supplementation, no effects reported. | None identified. | No relationship
Blood pressure | 13 RCTs of vitamin D supplementation, 7 reported no effect, inconsistent findings (increases or decreases in diastolic or systolic blood pressure) in the other 6.; 2 RCTs of vitamin D and calcium supplementation, no effects reported. | 12 RCTs reporting systolic and diastolic blood pressure, no differences between active treatment and control groups. | No relationship
Cancer intermediate outcomes (colorectal adenoma, aberrant cryptic, breast mammographic density) | No RCTs. 1 nested case-control study found no association between vitamin D levels and risk of polyps. | Not evaluated as part of this contextual questions. | Cannot be determined
Weight and BMI | Not assessed in the 2014 update, previous versions of the review identified 3 RCTs of vitamin D with or without calcium, no difference in weight change was reported. | 6 RCTs reporting weight and 9 RCTs reporting BMI all reporting no differences between active treatment and control groups. | No relationship
Fasting glucose and HgbA1C | Not reported | 7 RCTs reporting on fasting glucose and 2 RCTs reporting on HgbA1C, no differences between active treatment and control groups | No relationship
Cholesterol | Not reported | 11 RCTs reporting on total cholesterol, 10 RCTs reporting on LDL cholesterol, 12 RCTs reporting on HDL cholesterol. No differences between active treatment and control groups for total, LDL, or HDL cholesterol. | No relationship

Abbreviations: BMD=bone mineral density; BMI=body mass index; DXA=dual energy x-ray absorptiometry; HDL=high-density lipoprotein; HbA1C=hemoglobin A1c; LDL=low-density lipoprotein; RCT=randomized, controlled trial.