# References

1 Yueh B, Shapiro N, MacLean CH, . Screening and management of adult hearing loss in primary care: scientific review. JAMA. 2003 Apr 16;289(15):1976–85. doi: 10.1001/jama.289.15.1976. PMID: 12697801.12697801
2 Bagai A, Thavendiranathan P, Detsky AS. Does this patient have hearing impairment? JAMA. 2006 Jan 25;295(4):416–28. doi: 10.1001/jama.295.4.416. PMID: 16434632.16434632
3 Ventry IM, Weinstein BE. Identification of elderly people with hearing problems. ASHA. 1983 Jul;25(7):37–42. PMID: 6626295.6626295
4 Gates GA, Cooper JC, Jr., Kannel WB, . Hearing in the elderly: the Framingham cohort, 1983-1985. Part I. Basic audiometric test results. Ear Hear. 1990 Aug;11(4):247–56. PMID: 2210098.2210098
5 Chou R, Dana T, Bougatsos C, . Screening adults aged 50 years or older for hearing loss: a review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2011 Mar 1;154(5):347–55. doi: 10.7326/0003-4819-154-5-201103010-00009. PMID: 21357912.21357912
6 Clark JG. Uses and abuses of hearing loss classification. ASHA. 1981 Jul;23(7):493–500. PMID: 7052898.7052898
7 Goldstein DP. Hearing impairment, hearing aids and audiology. ASHA. 1984 Sep;26(9):24–35, 8. PMID: 6487402.6487402
8 Mathers C, Smith, A., Concha, M. Global burden of hearing loss in the year 2000. World Health Organization. Geneva, Switzerland: 2003. https://www.who.int/healthinfo/statistics/bod_hearingloss.pdf
9 Uy J, Forciea MA. In the clinic. Hearing loss. Ann Intern Med. 2013 Apr 2;158(7):ITC4–1; quiz ITC4-16. doi: 10.7326/0003-4819-158-7-201304020-01004. PMID: 23546583.23546583
10 Mulrow CD, Lichtenstein MJ. Screening for hearing impairment in the elderly: rationale and strategy. J Gen Intern Med. 1991 May–Jun;6(3):249–58. PMID: 2066832.2066832
11 Cruickshanks KJ, Wiley TL, Tweed TS, . Prevalence of hearing loss in older adults in Beaver Dam, Wisconsin. The Epidemiology of Hearing Loss Study. Am J Epidemiol. 1998 Nov 1;148(9):879–86. PMID: 9801018.9801018
12 Gates GA, Mills JH. Presbycusis. Lancet. 2005 Sep 24–30;366(9491):1111–20. doi: 10.1016/s0140-6736(05)67423-5. PMID: 16182900.16182900
13 Kvestad E, Czajkowski N, Krog NH, . Heritability of hearing loss. Epidemiology. 2012 Mar;23(2):328–31. doi: 10.1097/EDE.0b013e318245996e. PMID: 22249243.22249243
14 Hendrickx JJ, Huyghe JR, Topsakal V, . Familial aggregation of pure tone hearing thresholds in an aging European population. Otol Neurotol. 2013 Jul;34(5):838–44. doi: 10.1097/MAO.0b013e318288646a. PMID: 23739559.23739559
15 Raynor LA, Pankow JS, Miller MB, . Familial aggregation of age-related hearing loss in an epidemiological study of older adults. Am J Audiol. 2009 Dec;18(2):114–8. doi: 10.1044/1059-0889(2009/08-0035). PMID: 19474454.19474454
16 Lee FS, Matthews LJ, Dubno JR, . Longitudinal study of pure-tone thresholds in older persons. Ear Hear. 2005 Feb;26(1):1–11. doi: 10.1097/00003446-200502000-00001. PMID: 15692300.15692300
17 Brant LJ, Fozard JL. Age changes in pure-tone hearing thresholds in a longitudinal study of normal human aging. J Acoust Soc Am. 1990 Aug;88(2):813–20. doi: 10.1121/1.399731. PMID: 2212307.2212307
18 Chen DS, Betz J, Yaffe K, . Association of hearing impairment with declines in physical functioning and the risk of disability in older adults. J Gerontol A Biol Sci Med Sci. 2015 May;70(5):654–61. doi: 10.1093/gerona/glu207. PMID: 25975360.25477427
19 Cruickshanks KJ, Tweed TS, Wiley TL, . The 5-year incidence and progression of hearing loss: the epidemiology of hearing loss study. Arch Otolaryngol Head Neck Surg. 2003 Oct;129(10):1041–6. doi: 10.1001/archotol.129.10.1041. PMID: 14568784.14568784
20 Agrawal Y, Platz EA, Niparko JK. Prevalence of hearing loss and differences by demographic characteristics among US adults: data from the National Health and Nutrition Examination Survey, 1999-2004. Arch Intern Med. 2008 Jul 28;168(14):1522–30. doi: 10.1001/archinte.168.14.1522. PMID: 18663164.18663164
21 McMahon CM, Kifley A, Rochtchina E, . The contribution of family history to hearing loss in an older population. Ear Hear. 2008 Aug;29(4):578–84. doi: 10.1097/AUD.0b013e31817349d6. PMID: 18469720.18469720
22 Gopinath B, Flood VM, McMahon CM, . The effects of smoking and alcohol consumption on age-related hearing loss: the Blue Mountains Hearing Study. Ear Hear. 2010 Apr;31(2):277–82. doi: 10.1097/AUD.0b013e3181c8e902. PMID: 20054277.20054277
23 Cruickshanks KJ, Nondahl DM, Dalton DS, . Smoking, central adiposity, and poor glycemic control increase risk of hearing impairment. J Am Geriatr Soc. 2015 May;63(5):918–24. doi: 10.1111/jgs.13401. PMID: 25953199.25953199
24 Mitchell P, Gopinath B, McMahon CM, . Relationship of Type 2 diabetes to the prevalence, incidence and progression of age-related hearing loss. Diabet Med. 2009 May;26(5):483–8. doi: 10.1111/j.1464-5491.2009.02710.x. PMID: 19646187.19646187
25 Wells TS, Seelig AD, Ryan MA, . Hearing loss associated with US military combat deployment. Noise Health. 2015 Jan–Feb;17(74):34–42. doi: 10.4103/1463-1741.149574. PMID: 25599756.25599756
26 Hoffman HJ, Dobie RA, Losonczy KG, . Declining prevalence of hearing loss in US adults aged 20 to 69 years. JAMA Otolaryngol Head Neck Surg. 2017 Mar 1;143(3):274–85. doi: 10.1001/jamaoto.2016.3527. PMID: 27978564.27978564
27 QuickStats: percentage of adults aged ≥18 years with any hearing loss,* by state - National Health Interview Survey,† 2014-2016. MMWR Morb Mortal Wkly Rep. 2017 Dec 22;66(50):1389. doi: 10.15585/mmwr.mm6650a7. PMID: 29267261.29267261
28 Zelaya CE, Lucas JW, Hoffman HJ. Self-reported hearing trouble in adults aged 18 and over: United States, 2014. NCHS Data Brief. 2015 Sep(214):1–8. PMID: 26462204.26462204
29 Wilson BS, Tucci DL, Merson MH, . Global hearing health care: new findings and perspectives. Lancet. 2017 Dec 2;390(10111):2503–15. doi: 10.1016/s0140-6736(17)31073-5. PMID: 28705460.28705460
30 Fieo RA, Austin EJ, Starr JM, . Calibrating ADL-IADL scales to improve measurement accuracy and to extend the disability construct into the preclinical range: a systematic review. BMC Geriatr. 2011 Aug 16;11:42. doi: 10.1186/1471-2318-11-42. PMID: 21846335.21846335
31 Dalton DS, Cruickshanks KJ, Klein BE, . The impact of hearing loss on quality of life in older adults. Gerontologist. 2003 Oct;43(5):661–8. PMID: 14570962.14570962
32 Mick P, Kawachi I, Lin FR. The association between hearing loss and social isolation in older adults. Otolaryngol Head Neck Surg. 2014 Mar;150(3):378–84. doi: 10.1177/0194599813518021. PMID: 24384545.24384545
33 Loughrey DG, Kelly ME, Kelley GA, . Association of age-related hearing loss with cognitive function, cognitive impairment, and dementia: a systematic review and meta-analysis. JAMA Otolaryngol Head Neck Surg. 2018 Feb 1;144(2):115–26. doi: 10.1001/jamaoto.2017.2513. PMID: 29222544.29222544
34 Lisan Q, van Sloten TT, Lemogne C, . Association of Hearing Impairment with Incident Depressive Symptoms: A Community-Based Prospective Study. Am J Med. 2019 Dec;132(12):1441–9.e4. doi: 10.1016/j.amjmed.2019.05.039. PMID: 31247178.31247178
35 Genther DJ, Frick KD, Chen D, . Association of hearing loss with hospitalization and burden of disease in older adults. JAMA. 2013 Jun 12;309(22):2322–4. doi: 10.1001/jama.2013.5912. PMID: 23757078.23757078
36 Genther DJ, Betz J, Pratt S, . Association between hearing impairment and risk of hospitalization in older adults. J Am Geriatr Soc. 2015 Jun;63(6):1146–52. doi: 10.1111/jgs.13456. PMID: 26096388.26096388
37 Genther DJ, Betz J, Pratt S, . Association of hearing impairment and mortality in older adults. J Gerontol A Biol Sci Med Sci. 2015 Jan;70(1):85–90. doi: 10.1093/gerona/glu094. PMID: 25024235.25024235
38 Schubert CR, Fischer ME, Pinto AA, . Sensory Impairments and Risk of Mortality in Older Adults. (1758-535X (Electronic)).
39 Huddle MG, Goman AM, Kernizan FC, . The economic impact of adult hearing loss: a systematic review. JAMA Otolaryngol Head Neck Surg. 2017 Oct 1;143(10):1040–8. doi: 10.1001/jamaoto.2017.1243. PMID: 28796850.28796850
40 World Health Organization. Global costs of unaddressed hearing loss and cost-effectiveness of interventions: A WHO report, 2017. 2017.
41 Walling AD, Dickson GM. Hearing loss in older adults. Am Fam Physician. 2012 Jun 15;85(12):1150–6. PMID: 22962895.22962895
42 Eekhof JA, de Bock GH, de Laat JA, . The whispered voice: the best test for screening for hearing impairment in general practice? Br J Gen Pract. 1996 Aug;46(409):473–4. PMID: 8949327.8949327
43 Hong O, Ronis DL, Antonakos CL. Validity of self-rated hearing compared with audiometric measurement among construction workers. Nurs Res. 2011 Sep–Oct;60(5):326–32. doi: 10.1097/NNR.0b013e3182281ca0. PMID: 21873915.21873915
44 Lichtenstein MJ, Bess FH, Logan SA. Validation of screening tools for identifying hearing-impaired elderly in primary care. JAMA. 1988 May 20;259(19):2875–8. PMID: 3285039.3285039
45 Department of Veterans Affairs. Prescribing hearing aids and eyeglasses. VHA Directive 2008-070. Washington, DC: October 28, 2008. https://www.va.gov/optometry/docs/VHA_Directive_2008-070_Prescribing_Hearing_Aids_Eyeglasses.pdf
46 Hearing loss in adults: assessment and management; 2018. https://www.nice.org.uk/guidance/ng98/chapter/Recommendations. Accessed on.
47 Schilder AG, Chong LY, Ftouh S, . Bilateral versus unilateral hearing aids for bilateral hearing impairment in adults. Cochrane Database Syst Rev. 2017 Dec 19;12:Cd012665. doi: 10.1002/14651858.CD012665.pub2. PMID: 29256573.29256573
48 Cox RM, Schwartz KS, Noe CM, . Preference for one or two hearing AIDS among adult patients. Ear Hear. 2011 Mar–Apr;32(2):181–97. doi: 10.1097/AUD.0b013e3181f8bf6c. PMID: 20890203.20890203
49 Warren E. The Over-the-Counter Hearing Aid Act of 2017. Washington, DC: Elizabeth Warren: United States Senator for Massachusetts; 2017. https://www.warren.senate.gov/files/documents/3_21_17_Hearing_Aids_One_Pager.pdf. Accessed on January 2, 2019.
50 Mamo SK, Reed NS, Nieman CL, . Personal Sound Amplifiers for Adults with Hearing Loss. The American journal of medicine. 2016;129(3):245–50. doi: 10.1016/j.amjmed.2015.09.014. PMID: 26498713.26498713
51 Boothroyd A. Adult aural rehabilitation: what is it and does it work? Trends Amplif. 2007 Jun;11(2):63–71. doi: 10.1177/1084713807301073. PMID: 17494873.17494873
52 American Academy of Family Physicians. Clinical preventive service recommendation: hearing. 2012. https://www.aafp.org/patient-care/clinical-recommendations/all/hearing.html. Accessed on August 16, 2018.
53 UK National Screening Committee. UK NSC hearing loss in adults recommendation. Crown Copyright; 2016. https://legacyscreening.phe.org.uk/hearing-adult
54 Royal Australian College of General Practitioners. Guidelines for preventive activities in general practice. East Melbourne, Victoria, Australia: Royal Australian College of General Practitioners; 2016.
55 American Speech-Language-Hearing Association. Preferred practice patterns for the profession of audiology [preferred practice patterns]. Rockville, MD: ASHA National Office; 2006. www.asha.org/policy. Accessed on August 16, 2018.
56 Johnson CE, Danhauer JL, Koch LL, . Hearing and balance screening and referrals for Medicare patients: a national survey of primary care physicians. J Am Acad Audiol. 2008 Feb;19(2):171–90. PMID: 18669130.18669130
57 Danhauer JL, Celani KE, Johnson CE. Use of a hearing and balance screening survey with local primary care physicians. Am J Audiol. 2008 Jun;17(1):3–13. doi: 10.1044/1059-0889(2008/002). PMID: 18519575.18519575
58 Cohen SM, Labadie RF, Haynes DS. Primary care approach to hearing loss: the hidden disability. Ear Nose Throat J. 2005 Jan;84(1):26, 9–31, 44. PMID: 15742769.15742769
59 Contrera KJ, Wallhagen MI, Mamo SK, . Hearing loss health care for older adults. J Am Board Fam Med. 2016 May–Jun;29(3):394–403. doi: 10.3122/jabfm.2016.03.150235. PMID: 27170797.27170797
60 Everett A, Wong A, Piper R, . Sensitivity and Specificity of Pure-Tone and Subjective Hearing Screenings Using Spanish-Language Questions. Am J Audiol. 2020 Mar 5;29(1):35–49. doi: 10.1044/2019_aja-19-00053. PMID: 32073298.32073298
61 Kam ACS, Fu CHT. Screening for hearing loss in the Hong Kong Cantonese-speaking elderly using tablet-based pure-tone and word-in-noise test. Int J Audiol. 2020 Apr;59(4):301–9. doi: 10.1080/14992027.2019.1696992. PMID: 31794272.31794272
62 United Nations Development Programme. Human development index. New York City, NY: United Nations Development Programme; 2016. http://hdr.undp.org/en/composite/HDI. Accessed on August 20, 2018.
63 Veritas Health Innovation. Covidence systematic review software. Melbourne, Australia: Level 10; n.d. www.covidence.org. Accessed on December 17, 2019.
64 Sterne JAC, Savovic J, Page MJ, . RoB 2: a revised tool for assessing risk of bias in randomised trials. BMJ. 2019 Aug 28;366:l4898. doi: 10.1136/bmj.l4898. PMID: 31462531.31462531
65 Higgins JPT, Sterne JAC, Savović J, . A revised tool for assessing risk of bias in randomized trials. In: Chandler J, McKenzie J, Boutron I, Welch V, eds. Cochrane Methods. Vol. 10. Cochrane Database of Systematic Reviews; 2016.
66 Sterne JA, Hernán MA, Reeves BC, . ROBINS-I: a tool for assessing risk of bias in non-randomised studies of interventions. BMJ. 2016 Oct 12;355:i4919. doi: 10.1136/bmj.i4919. PMID: 27733354.27733354
67 Whiting PF, Rutjes AW, Westwood ME, . QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011 Oct 18;155(8):529–36. doi: 10.7326/0003-4819-155-8-201110180-00009. PMID: 22007046.22007046
68 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force procedure manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed on December 17, 2019.
69 West SL, Gartlehner G, Mansfield AJ, . Comparative effectiveness review methods: clinical heterogeneity. Report No.: 10-EHC070-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2010.
70 StataCorp. Stata statistical software: release 14.0. College Station, TX: StataCorp LP; 2015.
71 Yueh B, Collins MP, Souza PE, . Long-term effectiveness of screening for hearing loss: the screening for auditory impairment--which hearing assessment test (SAI-WHAT) randomized trial. J Am Geriatr Soc. 2010 Mar;58(3):427–34. doi: 10.1111/j.1532-5415.2010.02738.x. PMID: 20398111.20398111
72 Yueh B, Collins MP, Souza PE, . Screening for Auditory Impairment-Which Hearing Assessment Test (SAI-WHAT): RCT design and baseline characteristics. Contemp Clin Trials. 2007 May;28(3):303–15. doi: 10.1016/j.cct.2006.08.008. PMID: 17030153.17030153
73 Boatman DF, Miglioretti DL, Eberwein C, . How accurate are bedside hearing tests? Neurology. 2007 Apr 17;68(16):1311–4. doi: 10.1212/01.wnl.0000259524.08148.16. PMID: 17438223.17438223
74 Swanepoel de W, Eikelboom RH, Hunter ML, . Self-reported hearing loss in baby boomers from the Busselton Healthy Ageing Study: audiometric correspondence and predictive value. J Am Acad Audiol. 2013 Jun;24(6):514–21; quiz 29. doi: 10.3766/jaaa.24.6.7. PMID: 26924571.23886428
75 Sindhusake D, Mitchell P, Smith W, . Validation of self-reported hearing loss. The Blue Mountains Hearing Study. Int J Epidemiol. 2001 Dec;30(6):1371–8. PMID: 11821349.11821349
76 Clark K, Sowers M, Wallace RB, . The accuracy of self-reported hearing loss in women aged 60-85 years. Am J Epidemiol. 1991 Oct 1;134(7):704–8. PMID: 1951276.1951276
77 Hannula S, Bloigu R, Majamaa K, . Self-reported hearing problems among older adults: prevalence and comparison to measured hearing impairment. J Am Acad Audiol. 2011 Sep;22(8):550–9. doi: 10.3766/jaaa.22.8.7. PMID: 21828156.22031679
78 Nondahl DM, Cruickshanks KJ, Wiley TL, . Accuracy of self-reported hearing loss. Audiology. 1998 Sep–Oct;37(5):295–301. PMID: 9776206.9776206
79 Rawool VW, Keihl JM. Perception of hearing status, communication, and hearing aids among socially active older individuals. J Otolaryngol Head Neck Surg. 2008 Feb;37(1):27–42. PMID: 18479626.18479626
80 Torre P, Moyer CJ, Haro NR. The accuracy of self-reported hearing loss in older Latino-American adults. Int J Audiol. 2006 Oct;45(10):559–62. doi: 10.1080/14992020600860935. PMID: 17062497.17062497
81 Voeks SK, Gallagher CM, Langer EH, . Self-reported hearing difficulty and audiometric thresholds in nursing home residents. J Fam Pract. 1993 Jan;36(1):54–8. PMID: 8419504.8419504
82 Oosterloo BC, Homans NC, Baatenburg de Jong RJ, . Assessing hearing loss in older adults with a single question and person characteristics; Comparison with pure tone audiometry in the Rotterdam Study. PLoS One. 2020;15(1):e0228349–e. doi: 10.1371/journal.pone.0228349. PMID: 31986178.31986178
83 Gates GA, Murphy M, Rees TS, . Screening for handicapping hearing loss in the elderly. J Fam Pract. 2003 Jan;52(1):56–62. PMID: 12540314.12540314
84 Lee AT, Tong MC, Yuen KC, . Hearing impairment and depressive symptoms in an older chinese population. J Otolaryngol Head Neck Surg. 2010 Oct;39(5):498–503. PMID: 20673695.20828511
85 McBride WS, Mulrow CD, Aguilar C, . Methods for screening for hearing loss in older adults. Am J Med Sci. 1994 Jan;307(1):40–2. PMID: 8291505.8291505
86 Tomioka K, Ikeda H, Hanaie K, . The Hearing Handicap Inventory for Elderly-Screening (HHIE-S) versus a single question: reliability, validity, and relations with quality of life measures in the elderly community, Japan. Qual Life Res. 2013;22(5):1151–9. doi: 10.1007/s11136-012-0235-2.22833152
87 Macphee GJ, Crowther JA, McAlpine CH. A simple screening test for hearing impairment in elderly patients. Age Ageing. 1988 Sep;17(5):347–51. PMID: 3068972.3068972
88 McShefferty D, Whitmer WM, Swan IRC, . The effect of experience on the sensitivity and specificity of the whispered voice test: a diagnostic accuracy study. BMJ Open. 2013;3(4). doi: 10.1136/bmjopen-2012-002394.
89 Swan IR, Browning GG. The whispered voice as a screening test for hearing impairment. J R Coll Gen Pract. 1985 Apr;35(273):197. PMID: 3989786.3989786
90 Lycke M, Boterberg T, Martens E, . Implementation of uHear--an iOS-based application to screen for hearing loss--in older patients with cancer undergoing a comprehensive geriatric assessment. J Geriatr Oncol. 2016 Mar;7(2):126–33. doi: 10.1016/j.jgo.2016.01.008. PMID: 22628261.26924571
91 Bienvenue GR, Michael PL, Chaffinch JC, . The AudioScope: a clinical tool for otoscopic and audiometric examination. Ear Hear. 1985 Sep–Oct;6(5):251–4. PMID: 4054439.4054439
92 Ciurlia-Guy E, Cashman M, Lewsen B. Identifying hearing loss and hearing handicap among chronic care elderly people. Gerontologist. 1993 Oct;33(5):644–9. PMID: 8225009.8225009
93 Saliba J, Al-Reefi M, Carriere JS, . Accuracy of mobile-based audiometry in the evaluation of hearing loss in quiet and noisy environments. Otolaryngol Head Neck Surg. 2017 Apr;156(4):706–11. doi: 10.1177/0194599816683663. PMID: 27140227.28025906
94 Sever JC, Jr., Harry DA, Rittenhouse TS. Using a self-assessment questionnaire to identify probable hearing loss among older adults. Percept Mot Skills. 1989 Oct;69(2):511–4. doi: 10.2466/pms.1989.69.2.511. PMID: 2813000.2813000
95 Bonetti L, Simunjak B, Franic J. Validation of self-reported hearing loss among adult Croatians: the performance of the Hearing Self-Assessment Questionnaire against audiometric evaluation. Int J Audiol. 2018 Jan;57(1):1–9. doi: 10.1080/14992027.2017.1355073. PMID: 29946686.28749193
96 Frank T, Petersen DR. Accuracy of a 40 dB HL audioscope and audiometer screening for adults. Ear Hear. 1987 Jun;8(3):180–3. PMID: 3609515.3609515
97 Koike KJ, Hurst MK, Wetmore SJ. Correlation between the American Academy of Otolaryngology-Head and Neck Surgery five-minute hearing test and standard audiologic data. Otolaryngol Head Neck Surg. 1994 Nov;111(5):625–32. doi: 10.1177/019459989411100514. PMID: 7970802.7970802
98 Koole A, Nagtegaal AP, Homans NC, . Using the digits-in-noise test to estimate age-related hearing loss. Ear Hear. 2016 Sep–Oct;37(5):508–13. doi: 10.1097/aud.0000000000000282. PMID: 28555600.26871876
99 Lycke M, Debruyne PR, Lefebvre T, . The use of uHear to screen for hearing loss in older patients with cancer as part of a comprehensive geriatric assessment. Acta Clin Belg. 2018 Apr;73(2):132–8. doi: 10.1080/17843286.2017.1392070. PMID: 29063810.29063810
100 Wiley TL, Cruickshanks KJ, Nondahl DM, . Self-reported hearing handicap and audiometric measures in older adults. J Am Acad Audiol. 2000 Feb;11(2):67–75. PMID: 10685672.10685672
101 Watson CS, Kidd GR, Miller JD, . Telephone screening tests for functionally impaired hearing: current use in seven countries and development of a US version. J Am Acad Audiol. 2012 Nov–Dec;23(10):757–67. doi: 10.3766/jaaa.23.10.2. PMID: 22337493.23169193
102 Williams-Sanchez V, McArdle RA, Wilson RH, . Validation of a screening test of auditory function using the telephone. J Am Acad Audiol. 2014 Nov–Dec;25(10):937–51. doi: 10.3766/jaaa.25.10.3. PMID: 25459311.25514447
103 Kelly EA, Stadler ME, Nelson S, . Tablet-based Screening for Hearing Loss: Feasibility of Testing in Nonspecialty Locations. Otol Neurotol. 2018 Apr;39(4):410–6. doi: 10.1097/mao.0000000000001752. PMID: 30452748.29494473
104 López-Torres Hidalgo J, Boix Gras C, Téllez Lapeira J, . Functional status of elderly people with hearing loss. Arch Gerontol Geriatr. 2009 Jul–Aug;49(1):88–92. doi: 10.1016/j.archger.2008.05.006. PMID: 18603314.18603314
105 Mulrow CD, Aguilar C, Endicott JE, . Quality-of-life changes and hearing impairment. A randomized trial. Ann Intern Med. 1990 Aug 1;113(3):188–94. PMID: 2197909.2197909
106 Mulrow CD, Tuley MR, Aguilar C. Sustained benefits of hearing aids. J Speech Hear Res. 1992 Dec;35(6):1402–5. doi: 10.1044/jshr.3506.1402. PMID: 1494282.1494282
107 Yueh B, Souza PE, McDowell JA, . Randomized trial of amplification strategies. Arch Otolaryngol Head Neck Surg. 2001 Oct;127(10):1197–204. PMID: 11587599.11587599
108 McArdle R, Chisolm TH, Abrams HB, . The WHO-DAS II: measuring outcomes of hearing aid intervention for adults. Trends in amplification. 2005;9(3):127–43.16244759
109 Chisolm TH, Abrams HB, McArdle R, . The WHO-DAS II: psychometric properties in the measurement of functional health status in adults with acquired hearing loss. Trends Amplif. 2005;9(3):111–26. doi: 10.1177/108471380500900303. PMID: 16244758.16244758
110 Jerger J, Chmiel R, Florin E, . Comparison of conventional amplification and an assistive listening device in elderly persons. Ear Hear. 1996 Dec;17(6):490–504. PMID: 8979037.8979037
111 Nieman CL, Marrone N, Mamo SK, . The Baltimore HEARS Pilot study: an affordable, accessible, community-delivered hearing care intervention. Gerontologist. 2017 Nov 10;57(6):1173–86. doi: 10.1093/geront/gnw153. PMID: 27927734.27927734
112 Humes LE, Rogers SE, Quigley TM, . The effects of service-delivery model and purchase price on hearing-aid outcomes in older adults: a randomized double-blind placebo-controlled clinical trial. Am J Audiol. 2017 Mar 1;26(1):53–79. doi: 10.1044/2017_aja-16-0111. PMID: 28122108.28252160
113 Weinstein BE, Spitzer JB, Ventry IM. Test-retest reliability of the Hearing Handicap Inventory for the Elderly. Ear Hear. 1986 Oct;7(5):295–9. doi: 10.1097/00003446-198610000-00002. PMID: 3770324.3770324
114 Ventry IM, Weinstein BE. The hearing handicap inventory for the elderly: a new tool. Ear Hear. 1982 May–Jun;3(3):128–34. doi: 10.1097/00003446-198205000-00006. PMID: 7095321.7095321
115 Newman CW, Jacobson GP, Hug GA, . Practical method for quantifying hearing aid benefit in older adults. J Am Acad Audiol. 1991 Apr;2(2):70–5. PMID: 1768876.1768876
116 Zazove P, Plegue MA, McKee MM, . Effective Hearing Loss Screening in Primary Care: The Early Auditory Referral-Primary Care Study. Ann Fam Med. 2020 Nov;18(6):520–7. doi: 10.1370/afm.2590. PMID: 33168680.33168680
117 Ferguson MA, Kitterick PT, Chong LY, . Hearing aids for mild to moderate hearing loss in adults. Cochrane Database Syst Rev. 2017 Sep 25;9:Cd012023. doi: 10.1002/14651858.CD012023.pub2. PMID: 28944461.28944461
118 Kim TY, Park DW, Lee YJ, . Comparison of inner ear contrast enhancement among patients with unilateral inner ear symptoms in MR images obtained 10 minutes and 4 hours after gadolinium injection. AJNR Am J Neuroradiol. 2015 Dec;36(12):2367–72. doi: 10.3174/ajnr.A4439. PMID: 25689850.26316569
119 Cox RM, Gilmore C. Development of the profile of hearing aid performance (PHAP). J Speech Hear Res. 1990 Jun;33(2):343–57. doi: 10.1044/jshr.3302.343. PMID: 2359275.2359275