# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Justin Mills, MD, AHRQ Medical Officer; Tracy Wolff, MD, MPH, Scientific Director, USPSTF Division, AHRQ; and current and former members of the U.S. Preventative Services Task Force; Patricia Johnson, AuD, Assistant Clinical Professor, Division of Speech and Hearing Sciences at UNC Chapel Hill for her expert input and her review of the draft research plan; expert reviewers Karen Cruickshanks, PhD, University of Wisconsin-Madison; Rachel McArdle, PhD, MA, CCC-A, Bay Pines U.S. Veterans Administration Healthcare System; Teresa Chisolm, PhD, University of South Florida; Meg Wallhagen, RN, PhD, University of California, San Francisco; and Jennifer A. Deal, PhD, Johns Hopkins University; federal partners from the Centers for Disease Control and Prevention and the National Institutes of Health; Lynn Whitener, MSLS, DrPH, research librarian; Sharon Barrell, MA, editor; Loraine Monroe, publications specialist; and Carol Woodell, EPC Program Manager.