# Chapter 4 Discussion

## Summary of Evidence

Table 7 provides a summary of the main findings in this evidence review organized by KQ along with a description of consistency, precision, quality, limitations, strength of evidence, and applicability.

Table 7 Summary of Evidence for Screening for Hearing Loss in Older Adults

Key Question and Topic | No. of Studies; No. of Participants (n) | Summary of Findings | Consistency and Precision | Study Quality | Limitations (Including Reporting Bias) | Overall Strength of Evidence | Applicability
KQ 1. Benefits of screening | 1 RCT (2,305) | One RCT found that screening with HHIE-S, AudioScope, or both was not associated with any differences in hearing-related QOL compared with no screening. | Unknown; imprecise | Fair | High overall attrition (23% for hearing-related function); not designed to assess differences in hearing-related QOL. | Insufficient | Participants recruited from a VA setting with high prevalence of HL (74% reported perceived HL at baseline) and all patients were eligible to receive free hearing aids; results may not be applicable to lower-prevalence settings in which the cost or access of hearing aids is a barrier
KQ 2. Accuracy of screening tests for detecting mild (>20 to 25 dB) HL (by test) | Single question:; 10 (12,637) | Pooled:; Sn: 66 (58 to 73); Sp: 76 (68 to 83) | Mostly consistent^*^; imprecise (more imprecise for Sn than Sp) | 2 Good; 8 Fair | Only one study specified how equivocal screening test responses were handled; HL definitions varied in frequencies measured and ears affected | Moderate for adequate accuracy | Most studies were conducted in specialty or other high-prevalence settings
| HHIE-S score >8; 4 (7,194) | Sn: range 34 to 58 across studies; Sp: range 76 to 95 across studies | Mostly consistent (more consistent for Sp than Sn); imprecise | 1 Good; 3 Fair | HL definitions varied in frequencies measured and ears affected | Low for adequate accuracy | Most studies were conducted in specialty or other high-prevalence settings
| WVT:; 5 (669) | Pooled:; Sn: 94 (31 to 100); Sp: 87 (82 to 90) | Inconsistent; imprecise (more imprecise for Sn than Sp)^†^ | 5 Fair | HL definitions varied in thresholds (>25, >29 and >30 dB) and number of frequencies measured; one study found inconsistent results based on experience level of whisperer^88^ | Low for adequate accuracy | Most studies were conducted in specialty or other high-prevalence settings where screening was delivered by hearing specialists
| AudioScope:; 2 (215) | Sn: range 71 to 93 across studies; Sp: range 70 to 91 across studies | Inconsistent; imprecise | 1 Good; 1 Fair | Studies used different criteria to determine positive screening test based on AudioScope (number of frequencies, and specific frequencies included) | Insufficient | Both studies were conducted in specialty settings
| DIN:; 2 (3,417) | Sn: range 79 to 80 across studies; Sp: range 76 to 83 across studies | Consistent; imprecise (more imprecise for Sp than Sn) | 2 Fair | Methods of administering screening test varied across studies | Low for adequate accuracy | Screening tests were administered by audiologists
KQ 2. Accuracy of screening tests for detecting moderate (>35 to 40 dB) HL | Single question:; 6 (8,774) | Pooled; Sn: 80 (68 to 88); Sp: 74 (59 to 85) | Inconsistent^ǂ^; precise (more precise for Sn than Sp) | 2 Good; 4 Fair | Only one study specified how equivocal screening test responses were handled; HL definitions varied in frequencies measured and ears affected | Moderate for adequate accuracy | Most studies were conducted in specialty or other high-prevalence settings
| HHIE-S score>8:; 5 (2,820) | Pooled:; Sn: 68 (52 to 81); Sp: 66 (55 to 79) | Mostly consistent; imprecise^§^ | 1 Good; 4 Fair | HL definitions varied in frequencies measured and ears affected | Moderate for adequate accuracy | Most studies were conducted in specialty or other high-prevalence settings
| WVT:; 3 (296) | Sn: range 30 to 100 across studies; Sp: range: 79 to 100 across studies | Inconsistent; imprecise (more imprecise for Sn) | 3 Fair | HL definitions varied in terms of frequencies measured and ears affected; one study found inconsistent results based on experience level of whisperer^88^ | Low for inadequate accuracy | Studies were conducted in specialty or other high-prevalence settings where screening was delivered by hearing specialists
| AudioScope:; 4 (411) | Sn: range 94 to 100 across studies; Sp: range 41 to 80 across studies | Mostly consistent (more consistent for Sn than Sp); precise (more precise for Sn than Sp) | 1 Good; 3 Fair | Studies used different criteria to define a positive screening test based on AudioScope; HL definitions varied in frequencies measured | Moderate for adequate accuracy | Studies were conducted in specialty settings or other high-prevalence settings
| uHear^TM^ app; 2 (78) | Sn: range 68 to 100 across studies; Sp: range 87 to 89 across studies | Inconsistent (more for Sn than Sp); imprecise (more imprecise for Sn than Sp) | 2 Fair | Sensitivity varied within studies based on positive screening test definition, and between studies using the same screening test definition | Insufficient | Both studies enrolled older adults with cancer undergoing a comprehensive geriatric assessment
KQ 3. Harms of screening | k=0; 0 | No eligible studies | NA | NA | NA | Insufficient | NA
KQ 4. Benefits of interventions for screen-detected HL | k=6 RCTs (8 publications), 3,188 participants | In 5 trials (3,173 participants) reporting on the HHIE, 4 found significant benefit in favor of hearing aids vs. no amplification over 6 weeks to 4 months and one crossover trial found no significant difference between groups over 6 weeks. Few studies reported on other hearing-related outcomes. | Consistent, imprecise | Fair | Most studies were unblinded; follow-up duration was relatively short (6 weeks to 4 months); only one study enrolled participants identified by screening in primary care | Low | Three of four studies showing benefit enrolled populations from VA settings with baseline HHIE scores indicating moderate HL handicap (46 to 51) and who were eligible to receive free hearing aids
KQ 5. Harms of interventions for screen-detected HL | k=0; 0 | No eligible studies | NA | NA | NA | Insufficient | NA

* Based on Appendix F Figure 1, the 95 percent prediction region indicates the results are reasonably consistent; based on the 95 percent confidence interval, estimates are imprecise.

† Based on Appendix F Figure 4, the 95 percent prediction region indicates the results are moderately inconsistent; based on the 95 percent confidence region, estimates are imprecise (more imprecise for sensitivity than specificity).

ǂ Based on Appendix F Figure 2, the 95 percent prediction region indicates the results are moderately inconsistent; based on the 95 percent confidence region, estimates are imprecise.

§ Based on Appendix F Figure 3, the 95 percent prediction region is relatively large, covering approximately a third of the ROC space; the 95 percent confidence region is relatively precise (more precise for sensitivity than specificity).

Abbreviations: DIN=digits in noise; HHIE(-S)=Hearing Handicap Inventory for the Elderly(-Screening version); HL=hearing loss; k=number of studies; KQ=key question; n=number of participants; NA=not applicable; QOL=quality of life; RCT=randomized, controlled trial; ROC=receiver operating characteristics; Sn=sensitivity; Sp=specificity; VA=Veterans Affairs; WVT=whispered voice test.

## Evidence for Benefit and Harms of Screening

For benefits of screening, the SAI-WHAT trial (2,305 participants) included in the prior USPSTF review found that screening with the HHIE-S, the AudioScope, or both was not associated with any statistically significant difference in hearing-related QOL compared with no screening at 1 year. Although the trial did not find a difference between groups for health outcomes, it reported that screening with the AudioScope or combined screening with the AudioScope and HHIE-S was associated with greater hearing aid use (its primary outcome) at 1 year compared with no screening.^71,^ ^72^ Effects of screening on hearing aid use appeared to be limited to patients with perceived hearing loss at baseline. Of note, hearing aid use at 1 year was less than 10 percent in all arms, and the trial was not powered to assess improvements in hearing-related function; over one third of patients (screened or unscreened) in SAI-WHAT experienced a clinically significant improvement in hearing-related function, suggesting that factors other than hearing aid use may affect functional outcomes. Results may not be applicable to populations with a lower prevalence of perceived hearing loss. The SAI-WHAT trial enrolled only veterans eligible for free hearing aids, and 74 percent reported perceived hearing loss at baseline (based on the single question “Do you think you have a hearing-loss?”). As noted above, hearing aid use at 1 year was relatively low despite the high prevalence of perceived hearing loss at baseline. Although no new studies directly evaluating screening were identified, findings from a recent uncontrolled intervention study (n=14,411) of an electronic alert to encourage primary care clinicians to screen for hearing loss using a single question (“Do you have difficulty with your hearing?”) are consistent with the SAI-WHAT trial in showing an increase in referrals associated with screening (from 2.2% at baseline to 10.7% during the study period).^116^ Among those referred (n=1,660), 43 percent were evaluated by an audiologist, and 59 percent (n=421) were considered candidates for hearing aids. Rates of hearing aid use or changes in health outcomes were not reported, but a subset of participants who agreed to a 3-month followup (n=557) indicated only 50 percent of those who had hearing aids recommended planned to get them, primarily because of cost.^116^ Multiple factors that may explain low uptake of hearing aids among those with perceived and/or confirmed hearing impairment, including a perception that symptoms are not severe enough, concerns about cost or stigma, and (for those who receive hearing aids) concerns about comfort and maintenance (e.g., difficulty replacing batteries, cost of repairs) may affect hearing aid use. Appendix A Contextual Question 3 provides a detailed overview of potential barriers to obtaining hearing aids and reasons for low uptake.

We did not find direct evidence on harms of screening. Potential harms include false-positive results that lead to unnecessary testing and/or treatment, labeling, and anxiety. Based on our pooled analyses of HHIE-S for detecting moderate hearing loss (5 studies; 2,820 participants), the expected rate of false-positives tests would be 22 percent (Table 3). Similarly, in five studies assessing the AudioScope for detecting moderate hearing loss (reporting specificities ranging from 52 to 80), the rate of false positives was 20 to 58 percent. Other harms of screening are likely to be minimal because screening is noninvasive, and the reference standard (audiometric testing) is also noninvasive.

## Diagnostic Test Accuracy

Screening tools are available for clinical practice that may reasonably identify asymptomatic older adults with hearing loss. The 33 included studies assessed the accuracy of various clinical tests, a single question, questionnaires (primarily the HHIE-S), and a handheld or mobile screening audiometric device compared with heterogeneous definitions of hearing loss based on PTA. A major limitation in interpreting studies of diagnostic accuracy is that studies used different thresholds and criteria to define hearing loss. Several studies found inconsistent screening test accuracy results when comparing the same screening test (and cut point) with different definitions for mild or moderate hearing loss (i.e., measured at different frequencies or defined by hearing thresholds in the better vs. worse ear). This limited our ability to make stronger conclusions about the accuracy of available screening tests to detect mild or moderate hearing loss.

The clinical relevance of detection of mild (25 to 40 dB) hearing loss as it pertains to effectiveness of screening is also uncertain because the only trial showing benefits of hearing aids enrolled patients with screening-detected >40 dB hearing loss.^71^

Screening tests evaluated in the included studies differ in factors such as cost, complexity/time, and convenience. Relatively simple tests, such as a single question regarding perceived hearing loss, appear to be nearly as accurate as a more detailed hearing loss questionnaire or a handheld audiometric device for detecting hearing loss. For the whisper test, an important consideration is the need for clinicians to administer the test in a standardized and consistent fashion (such as the method described in published studies of diagnostic accuracy). One study of whispered voice test accuracy found that estimates differed based on practitioner experience in administering the whispered voice; older experienced whisperers were 8 to 10 dB greater than inexperienced whisperers, which resulted in lower sensitivity (63% vs. 80%) and higher specificity (93% vs. 80%) for detecting moderate hearing loss in the same population.^88^

Some studies of screening test accuracy were limited by unclear applicability (14 of 33 studies enrolled participants from audiology clinics or other hearing-related specialty). The estimates of screening test accuracy were derived from populations with a prevalence of hearing loss (based on PTA) of approximately 14 to 63 percent for mild (>25 dB) and 11 to 69 percent for moderate (>40 dB) hearing loss.

## Benefits of Interventions for Screen-Detected or Recently Diagnosed Hearing Loss

Six RCTs (reported in 8 articles) evaluated benefits of amplification compared with no amplification among populations with screen-detected or recently detected, untreated age-related hearing loss.^105–112^ Of these, three were included in the 2011 review for the USPSTF, and three were newly identified. No new studies enrolling screen-detected populations from primary care settings were identified, and our overall conclusions are consistent with the prior report. We were not able to pool studies assessing benefit of interventions (KQ 4) because of limited reporting of outcome measures (HHIE) or too few studies reporting on similar outcomes (e.g., general measure of QOL or function). Three RCTs and one nonrandomized trial found significant reductions on the HHIE among groups receiving hearing aids compared with no amplification; of these, three trials enrolled veterans^105,^ ^107,^ ^108^ and one enrolled community volunteers.^112^ Only the three trials enrolling veterans found a difference between groups in HHIE scores considered to represent a minimal important difference (18.7 points). Evidence on the efficacy of treatments for screen-detected hearing loss in primary care settings is limited. One fair-quality RCT found that hearing aids resulted in near normalization of hearing-related QOL and function (measured by the HHIE) among veterans identified by screening, based on >40 dB hearing loss using a handheld audiometric device.^105,^ ^106^ Because this trial was conducted in a VA center and almost exclusively enrolled white males eligible for free hearing aids, its generalizability to other settings may be limited.

Our conclusions regarding treatment benefit associated with hearing aids are similar to those from a 2017 Cochrane review (k=5 RCTs; 825 participants) despite differences in eligible populations and study designs. Authors concluded that hearing aids significantly improve hearing-specific health-related QoL measured by the HHIE compared with the unaided/placebo condition (mean difference −26.47 [95% CI −42.16 to −10.77]; 722 participants; 3 studies).^117^ We did not find direct evidence on harms of treatment with amplification. However, harms of treatment are likely to be minimal because treatment with hearing aids is not known to be associated with serious adverse events.

## Limitations

The limitations of the included studies are discussed above in Results and Summary of Evidence. Here we focus on limitations of this review. First, we excluded studies of persons with symptomatic hearing loss and head-to-head comparisons of different amplification interventions because the scope was designed to provide evidence on benefits of treatments compared with no treatment rather than assess the comparative effectiveness of amplification devices or other interventions. Second, for studies related to benefits of screening and interventions for screen-detected populations, we limited the review to study designs that included a control group and those that reported on health outcomes. Intermediate outcomes, including increased rates of audiology referrals associated with screening, may not indicate that people identified by routine screening have better long-term health outcomes than those who are identified and referred for treatment in the context of routine primary care. Finally, we excluded studies focused on adults younger than age 50 years and studies focused on other causes of hearing loss (e.g., prevention of noise-induced hearing loss) because this review is intended to inform screening for age-related hearing loss in primary care settings.

## Future Research Needs

Screening trials of sufficient sample size that focus on health outcomes (e.g., hearing-related function and QOL) and enroll asymptomatic older adults from a general primary care population are needed, as are studies on potential harms of screening such as labeling, harms from false-positive results, burden, inconvenience, and unnecessary testing and treatment. The existing screening trial has uncertain applicability to U.S. populations enrolled from non-VA settings where prevalence of hearing loss may be lower. Accuracy studies enrolling asymptomatic adults from primary care settings that use consistent definitions of hearing loss would improve certainty about the accuracy of primary-care relevant screening tests. In addition, trials of screening and treatment for hearing loss are needed that reflect currently available technology, including OTC options for those identified with mild hearing loss and fitting of hearing aids that reflect current treatment standards.

## Conclusion

One trial of screening for hearing loss did not find a benefit for hearing-related function. No eligible study reported on potential harms of screening. Screening tools are available for clinical practice that may reasonably identify asymptomatic older adults with moderate hearing loss. Estimates of test accuracy vary based on hearing loss definition. Three trials show significant reductions in HHIE among groups receiving hearing aids compared with no amplification that meet the difference considered minimally important; all enrolled veterans. No studies of interventions reported on potential harms.