# Chapter 3 Results

## Literature Search

This review identified 4,681 unique records and assessed 281 full-text articles for eligibility (Figure 2). The review excluded 236 studies for various reasons, detailed in Appendix C, and included 41 unique studies (described in 45 publications). Of the included studies, one RCT reported some eligible outcomes for KQ 1, 34 studies (described in 35 publications) evaluated the accuracy of one or more screening tests for hearing loss (KQ 2), and no studies met eligibility criteria for KQ 3 (harms of screening). Six RCTs (described in 8 publications) addressed the benefits (KQ 4) of amplification compared with no amplification for treatment of screen-detected hearing loss, and no studies assessed harms of amplification (KQ 5). Details of quality assessments of included studies and studies excluded because of poor quality are in Appendix D Tables 1-16.

Figure 2 Summary of Evidence Search and Selection

Figure 2 is titled “Summary of Evidence Search and Selection”. The figure is a flow chart that summarizes the search and selection of articles. A total of 4,641 records were identified through database searching, including 4,166 records by searching PubMed, 168 records by searching the Cochrane Library, and 307 records by searching Embase. A total of 223 additional records were identified through other sources including 50 records by searching ClinicalTrials.gov, 45 by handsearching, 27 records from the prior report, and 101 records from reviewer suggestions. After removal of duplicates, 4,681 titles and abstracts were screened for potential inclusion. Of these, 281 were deemed appropriate for full-text review to determine eligibility. After full-text review, 236 were excluded: 2 for wrong language/non-English, 102 for wrong population, 35 for wrong screening test/intervention, 34 for wrong or no comparator, 31 for wrong or no outcome, 1 for wrong setting, 8 for wrong study design, 12 for wrong publication type, 8 for wrong country, and 3 for poor quality. Forty-five articles representing 41 studies were included in the systematic review. Two articles representing 1 study were included for KQ1, 35 articles representing 34 studies were included for KQ2, no studies were included for KQ3, 8 articles representing 6 studies were included for KQ4, and no studies were included for KQ5.

## Results by Key Question

### KQ 1a Does Screening for Hearing Loss in Asymptomatic Adults Age 50 Years or Older Improve Health Outcomes?

#### Summary

One randomized trial (included in the prior USPSTF review) found that screening with the HHIE-S, the AudioScope, or both was not associated with any statistically significant difference in hearing-related QOL compared with no screening at 1 year. Although the trial did not find a difference between groups for health outcomes, it reported that screening was associated with greater hearing aid use (its primary outcome) at 1 year compared with no screening.^71,^ ^72^ Effects of screening on hearing aid use appeared to be limited to patients with perceived hearing loss at baseline. Because 74 percent of patients enrolled in the trial reported perceived hearing loss at baseline and all patients were eligible to receive free hearing aids, results are likely to be most applicable to high-prevalence settings in which the cost of hearing aids is not a barrier.

#### Detailed Evidence

The review identified one randomized trial of screening for hearing loss (n=2,305), the Screening for Auditory Impairment—Which Hearing Assessment Test (SAI-WHAT) trial (Table 1).^71,^ ^72^ The trial compared three different screening strategies with a nonscreened control group: the AudioScope (Welch Allyn, Skaneateles Falls, New York), based on inability to hear a 40-dB tone at 2,000 Hz in either ear; the HHIE-S (based on a score >10, range 0 to 40); or the AudioScope plus the HHIE-S. Included participants were predominantly male (94%), age 50 years or older (mean 61 years), and recruited from a VA Medical Center. All participants were eligible to receive free, VA-issued hearing aids. Most participants (74%) reported perceived hearing loss at enrollment (based on a “yes” or “maybe” response to the question “Do you think you have hearing loss?”). The SAI-WHAT trial was rated as fair quality, primarily because of concerns about potential deviation from intended interventions and high overall attrition for hearing-related function (23%). The study aims to compare screening with usual care; however, baseline assessment (prior to randomization) includes an assessment of self-perceived hearing loss. Participants who screened positive for hearing loss in any of the screening arms were told that they might have hearing loss and were given written instructions to call the audiology clinic for an evaluation (no referral was required to schedule an appointment). The nonscreened group was provided with a number for the audiology clinic if they wanted further assessment. Although there was no differential attrition, the high overall attrition for hearing-related function is a potential source of bias because it is possible that participants with worse function were less likely to respond to the survey.

Table 1 Characteristics and Outcomes of Included RCT for KQ 1

Author, Year; Study Design (N) | Source Population (Country) | Eligibility Criteria | Baseline Characteristics | Interventions | Hearing-Related Function | Hearing Aid Use
Yueh, 2010^71^; Yueh, 2007^72^; RCT (2,305) | Outpatients seeking general medical care from the VA Puget Sound Health Care system recruited via flyers and posters advertising hearing screening study (U.S.) | Age 55-79 yrs; eligible for VA-issued HAs; MMSE>25; no prior HA experience; PTA thresholds consistent with age-related, bilateral SNHL; no hearing-related pathologies specific to ear anatomy, medication use, or medical conditions | Mean age, yrs (SD): 61 (9); % male: 94; % white: 75; % with perceived hearing loss at baseline^*^: 74 | G1: No screening (n=923); G2: Screening with tone-emitting otoscope (n=463); G3: Screening with HHIE-S (n=461); G4: Screening with both tone-emitting otoscope and HHIE-S (n=459) | % of participants who experienced an MICD (6 points) on the Inner Ear scale at 1 year (post hoc analysis):; G1: 36.0; G2: 40.4; G3: 36.1; G4: 39.7; p=0.392, no difference between any arms; No significant difference between groups when stratified by perceived hearing loss at baseline or age | HA use at 1 year (%):; G1: 3.3; G2: 6.3; G3: 4.1; G4: 7.4; p<0.01 for G1 vs. G2 and G4; p>0.40 for G1 vs. G3

* Based on answering either “yes” or “maybe” to the question “Do you think you have a hearing loss?”

Abbreviations: G=group; HA=hearing aid; HHIE-S=Hearing Handicap Inventory for Elderly(-Screening version); KQ=key question; MICD=minimally important clinical difference; MMSE=Mini-Mental State Examination; N/n=number of participants; PTA=pure-tone average; RCT=randomized, controlled trial; SD=standard deviation; SNHL=sensorineural hearing loss; U.S.=United States; VA=Veterans Affairs.

Among screened groups, the proportion who screened positive was lowest in the AudioScope arm (19%) and higher in the HHIE-S arm (59%) and combined arm (64%). Hearing aid use at 1 year, the primary outcome, was significantly higher among the AudioScope arm and combined arm than the nonscreened arm (6.3% and 7.4% vs. 3.3%, respectively; p<0.01) but not among the HHIE-S arm compared with the nonscreened arm (4.1% vs. 3.3%; p>0.40). In a post hoc subgroup analysis, hearing aid use was greater among participants with perceived hearing loss at baseline (5.7% to 9.6% in screened arms vs. 4.4% in the control arm), but among those without perceived hearing loss, hearing aid use was minimal regardless of screening status (0% to 1.6%).

There was no difference in the proportion of patients who experienced a minimum clinically important difference (>6 points of improvement on a 0 to 100 scale) on the Inner Effectiveness of Aural Rehabilitation scale (a measure of hearing-related function) at 1 year (36% to 40% in the screened arms vs. 36% in the nonscreened group; p=0.39).

### KQ 1b Does the Effectiveness of Screening for Hearing Loss Differ for Subpopulations Defined by Age, Sex, Race/Ethnicity, Risk of Past Noise Exposure, or Comorbid Condition?

The SAI-WHAT trial of screening (described above) conducted post hoc analyses of hearing-related function for subpopulations defined by age.^71,^ ^72^ There were no differences between screened and nonscreened groups in the proportion who experienced improvement on the Inner Effectiveness of Aural Rehabilitation scale when groups were stratified by age (50-64 years vs. ≥65 years) and according to whether they had perceived hearing loss at baseline, except in a subgroup that had both perceived hearing loss at baseline and was age 65 years or older (54% in the AudioScope arm, 34% in the HHIE-S arm, 40% in the combined arm, and 34% in the control arm; p=0.035).

### KQ 2 What is the accuracy of primary care–relevant screening tests for hearing loss in adults age 50 years or older?

#### Summary

Thirty-four studies (reported in 35 articles) evaluated the diagnostic accuracy of clinical tests, a single question, a questionnaire, a handheld audiometric device, or a mobile-based audiometric application for identifying mild to moderate hearing loss in older adults. For detecting mild hearing loss (>20 to 25 dB), single-question screening had a pooled sensitivity of 66 percent (95% CI, 58% to 73%) and pooled specificity of 76 percent (95% CI, 68% to 83%) (10 studies, 12,637 participants);^73–82^ for detecting moderate hearing loss (>35 to 40 dB averaged over 2 to 4 frequencies), pooled sensitivity was 80 percent (95% CI, 68% to 88%) and the pooled specificity was 74 percent (95% CI, 59% to 85%) (6 studies, 8,774 participants).^74–76,^ ^82–84^ Too few studies reported sufficient data to pool accuracy of the HHIE-S for detecting mild hearing loss (>25 dB at 2 to 4 frequencies); across 4 studies (7,194 participants) sensitivity of HHIE-S ranged from 34 to 58 percent, and specificity ranged from 76 to 95 percent.^75,^ ^78,^ ^85,^ ^86^ For detecting moderate hearing loss (>40 dB at 2 to 4 frequencies), the pooled sensitivity of HHIE-S (5 studies; 2,820 participants) was 68 percent (95% CI, 52% to 81%) and pooled specificity was 78 percent (95% CI, 67% to 86%).^3,^ ^44,^ ^75,^ ^83,^ ^85^ For detecting mild hearing loss (>25 to 30 dB), pooled sensitivity of the whispered voice test was 94 percent (95% CI, 31% to 100%) and pooled specificity was 87 percent (82% to 90%) (5 studies; 669 participants).^42,^ ^73,^ ^87–89^ Fewer studies reported on the accuracy of whispered voice to detect moderate hearing loss (>40 dB) sensitivity ranged from 30 to 60 percent and specificity ranged from 80 to 98 percent (3 studies; 296 participants).^73,^ ^88,^ ^90^ Two studies (215 participants) assessed the accuracy of the AudioScope to detect at least mild hearing loss (>25 to >30 dB); sensitivities ranged from 64 to 93 percent, and specificities ranged from 70 to 91 percent.^85,^ ^91^ For detecting moderate hearing loss (>40 dB), four studies (411 participants) found relatively high sensitivity (94% to 100%) and variable specificity (range: 24% to 80%) for the AudioScope.^42,^ ^44,^ ^85,^ ^92^

#### Detailed Evidence

Six good^74,^ ^79,^ ^82,^ ^85,^ ^93,^ ^94^ and 28 fair-quality studies (reported in 29 articles)^3,^ ^42,^ ^44,^ ^73,^ ^75–78,^ ^80,^ ^81,^ ^83,^ ^84,^ ^86–92,^ ^95–104^ assessed the accuracy of 18 different screening tools for hearing loss in older adults (Table 3). Nineteen of the included studies were in the review conducted for the USPSTF in 2011 (as noted in Table 3).^5^

Nine studies evaluated a clinical test (e.g., whispered voice, finger rub).^42,^ ^73,^ ^87–90,^ ^98,^ ^101,^ ^102^ Thirteen studies evaluated a single question (e.g., “Do you have difficulty hearing?”);^73–84,^ ^86^ 11 studies (reported in 12 articles) evaluated a hearing questionnaire (e.g., HHIE-S);^3,^ ^44,^ ^75,^ ^78,^ ^83,^ ^85,^ ^86,^ ^94,^ ^95,^ ^97,^ ^100,^ ^104^ and 10 studies evaluated a handheld or mobile-based audiometric device.^42,^ ^44,^ ^85,^ ^90–93,^ ^96,^ ^99,^ ^103^ Many studies assessed multiple screening tools.

All the studies used PTA as the reference standard, although the thresholds and the criteria used to diagnose hearing loss varied both across and within studies; specific criteria are shown in Appendix E Tables 1-4 along with the test accuracy outcomes. For instance, some studies examined accuracy in relation to mild (>25 dB) or moderate (>40 dB) levels of severity, and studies varied by the particular cut point at which a determination of mild or moderate was made. Another variation both within and across studies was whether the better ear, worse ear, or both individual ears were used to obtain hearing thresholds. Finally, studies varied on whether thresholds were speech frequency averages (i.e., 0.5, 1, 2 kHz), four-frequency averages (i.e., 0.5, 1, 2, 4 kHz), or high frequency averages (i.e., 4, 6, 8 kHz).

In terms of screening-test delivery, studies assessing a hearing questionnaire or single question involved self-administration (Table 2).^3,^ ^44,^ ^73,^ ^77,^ ^78,^ ^83–86,^ ^93–95,^ ^100,^ ^102,^ ^104^ A variety of different personnel screened participants in studies examining handheld or mobile-based audiometric devices, including audiologists, speech language pathologists, primary care clinicians, research staff, and not further described “examiners.” Clinicians (i.e., neurologists, geriatricians, otolaryngologists) and audiologists administered clinical screening tools. Five of the studies did not indicate who administered the screener.^42,^ ^76,^ ^81,^ ^82,^ ^84^

Table 2 Characteristics of Studies Assessing Screening Test Accuracy (KQ 2)

Author, Year; Quality; (New vs. Previous Review) | Screening Test or Question | Person Screening | Type of Study | Population | N Screened | Setting; Country | Age in Years, Mean (SD); Range | Sex (% Male) | Race/Ethnicity (% White)
Bienvenue, 1985^91^; Fair; Previous review | AudioScope | Examiner | Cross-sectional | Community-dwelling adults | 30 | Speech and hearing clinics; U.S. | NR; 51-81 | NR | NR
Boatman, 2007^73^; Fair; Previous review | Do you think you have difficulty hearing?; WVT at 2 feet; Watch tick at 6 inches; Finger rub at 6 inches | Single question: Self-administered; WVT, watch tick, finger rub: Neurologist | Cross-sectional | Community-dwelling adults | 107 (214 ears) | Movement disorders clinic (patients or family); U.S. | 66 (NR); 50-88 | 49 | NR
Bonetti, 2018^95^; Fair; New | Hearing Self-Assessment Questionnaire | Self-administered | Cross-sectional | Community-dwelling adults | 112 | ENT clinic; Croatia | 56 (13); 24-88 | 57 | NR
Ciurlia-Guy, 1993^92^; Fair; Previous review | AudioScope | Research assistant | Cross-sectional | Veteran residents of a chronic care facility | 104 | 5 wards of chronic care facility; Canada | 79 (10); 60-99 | 88 | NR
Clark, 1991^76^; Fair; Previous review | Would you say that you have any difficulty hearing? | NR | Cross-sectional | Community-dwelling adults | 267 | NR; U.S. | NR; 60-85 | 0 | NR
Eekhof, 1996^42^; Fair; Previous review | WVT at 2 feet;; AudioScope | NR | Cross-sectional | Community-dwelling adults | 62 (124 ears) | Otolaryngology clinic (outpatient ENT department); Netherlands | NR; ≥55 | NR | NR
Frank & Petersen, 1987^96^; Fair; Previous review | AudioScope; Pure-tone audiometer screener | Audiologist or speech-language pathologist | Cross-sectional | Community-dwelling adults and patients of a rehab center | 405 (688^*^ ears) | Speech and hearing clinic; rehab center; U.S. | NR; 50-96^†^ | NR | NR
Gates, 2003^83^; Fair; Previous review | Do you have a hearing problem now?; HHIE-S | Self-administered | Cross-sectional | Community-dwelling adults who participated in Framingham Heart Study | Single item=723; HHIE-S =546 | NR; U.S. | 78 (4)^‡^; >70 | 36^‡^ | NR
Hannula, 2011^77^; Fair; New | Do you have any difficulty with your hearing? | Self-administered | Cross-sectional | Community-dwelling adults | 850 | Audiology clinic; Finland | NR; 54-66 | 45 | NR
Kelly, 2018^103^; Fair; New | EarTrumpet app;; Audiogram Mobile app;; Hearing Test with Audiogram app | Self-administered | RCT | Community-dwelling adults | 107 | Audiology clinic (in either quiet exam room or clinic waiting area); U.S. | 61 (NR); 19-85 | 58 | NR
Koike, 1994^97^; Fair; Previous review | Revised Five Minute Hearing Test | Self-administered | Cross-sectional | Community-dwelling adults | 74 | Audiology clinic; U.S. | 72 (10); NR | 47 | NR
Koole, 2016^98^; Fair; New | DIN test | Audiologist | Prospective Cohort | Community-dwelling adults | 3,327 | ERGO health center; The Netherlands | 65 (NR); >50 | 43 | NR
Lee, 2010^84^; Fair; New | Self-reported HL | NR | Cross-sectional | Community-dwelling adults | 912 | Audiology clinic; Hong Kong | 72 (NR); ≥60 | 41 | 0
Lichtenstein, 1988^44^; Fair; Previous review | AudioScope;; HHIE-S | AudioScope: internist;; Self-administered HHIE-S | Cross-sectional | Community-dwelling adults | 178 | Six internal medicine clinics; U.S. | 74 (6); >65 | 37 | 78
Lopez-Torres, 2009^104^; Fair; New | HHIE-S | Trained health care staff | Cross-sectional | Community-dwelling adults | 1,162 | [underlined: Community health care center]; [underlined: Spain] | [underlined: 73 (59)]; [underlined: ≥65] | 44 | NR
Lycke, 2016^90^; Fair; New | uHear;; WVT; HHIE^§^ | A trained and certified audiologist | Cohort | Community-dwelling adults | 33 (66 ears) | Radiotherapy and oncology departments of a hospital; Belgium | 76 (NR); ≥70 | 70 | NR
Lycke, 2018^99^; Fair; New | Modified Handzel-uHear™ screening | A trained and certified audiologist | Cohort | Cancer patients of the uHear-BIS-trial | 45 (90 ears) | Radiotherapy and oncology departments of a hospital; Belgium | 76 (NR); ≥70 | 46 | NR
Macphee, 1988^87^; Fair; Previous review | Conversational voice at 2 ft and 6 ft; WVT at 2 ft and 6 ft | Geriatrician and otolaryngologist | Cross-sectional | Patients in rehabilitation wards | 62 (124 ears) | Four rehabilitation wards; Scotland | 81 (NR); 66-96 | 31 | NR
McBride, 1994^85^; Good; Previous review | HHIE-S;; AudioScope | HHIE: Self-administered;; AudioScope: Research associate | Cross-sectional | Community-dwelling adults | 185 | Community health clinic; VA Medical Center; U.S. | 70 (5); >60 | 69 | NR
McShefferty, 2013^88^; Fair; New | WVT^‖^ | Otolaryngologists (older experienced screeners) and young inexperienced screeners | Cross-sectional | Community-dwelling adults | 73 (112 ears) | Hearing research center; U.K. | 63 (SD); 32-73 | 58 | NR
Nondahl, 1998;^78^ Wiley, 2000^100^; Fair; Previous review | Do you feel you have hearing loss?; HHIE-S | Self-reported | Cross-sectional | Community-dwelling adults who were in Beaver Dam Eye study | Single question =3,342; HHIE-S =3,471 | Sound treated rooms; U.S. | 66 (NR); 48-92 | 44 | 99
Oosterloo, 2020^82^; Good; New | Do you have any difficulty with your hearing [without hearing aids]? | NR | Cohort | Community-dwelling adults | 4,906 | Research center (no other details reported); The Netherlands | 69.6 (9.8); NR | 43.7 | NR
Rawool, 2008^79^; Good; Previous review | Do you think you have a hearing loss? | Investigator | Cross-sectional | Community-dwelling adults | 30 | NR; U.S. | 78 (NR); ≥65 | 27 | 100
Saliba, 2017^93^; Good; New | EarTrumpet “consumer app”;; ShoeBOX “professional app” | Self-administered | Prospective | Community-dwelling adults | 33 (65 ears) | Tertiary otology referral clinic at a general hospital; Canada | 49.7 (12); 18-65 | 58 | NR
Sever, 1989^94^; Good; Previous review | HHIE-S | Self-administered | Cross-sectional | Community-dwelling adults | 59 | Sound-attenuated test room; U.S. | 69 (NR); 60-84 | NR | NR
Sindhusake, 2001^75^; Fair; Previous review | Do you feel you have hearing loss?; HHIE-S | Audiologist | Cross-sectional | Community-dwelling adults, part of Blue Mountain Hearing Study | Single question =1,931; HHIE-S =1,807 | NR; Australia | Median: 70^¶^; 55-99 | 43 | NR
Swan, 1985^89^; Fair; Previous review | WVT at 2 feet | Otolaryngologists | Cross-sectional | Patients with aural symptoms | 101 (202 ears) | Audiology clinic; Scotland | 57 (NR); 17-89 | NR | NR
Swanepoel, 2013^74^; Good; New | Do you have a hearing impairment? | Trained research nurses | Cohort | Community-dwelling adults | 1,004 | NR; Australia | 56 (5); 45-65 | 46 | NR
Tomioka, 2013^86^; Fair; New | HHIE-S;; Do you feel you have a hearing loss? | Self-administered | Cross-sectional | Community-dwelling adults | 1,731 | NR; Japan | 70^¶^; ≥60 | 45 | 0
Torre, 2006^80^; Fair; Previous review | Do you feel you have a hearing loss? (Spanish) | A Spanish-/English-speaking examiner | Cross-sectional | Community-dwelling Latino adults | 59 | Referred from physicians or medical staff at a family clinic; U.S. | 62 (NR); 42-88 | 46 | NR
Ventry & Weinstein, 1983^3^; Fair; Previous review | HHIE-S | Self-administered | Cross-sectional | Community-dwelling adults | 104 | Sound-treated test environments; U.S. | NR | NR | NR
Voeks, 1993^81^; Fair; Previous review | Do you have trouble hearing? | NR | Cross-sectional | Nursing home-dwelling veterans | 198 | Skilled nursing Facility; U.S. | NR | 82 | NR
Watson, 2012^101^; Fair; New | Telephone DIN test | Telephone-administered | Cohort | Community-dwelling adults | 90 | Small audiology office; U.S. | 54 (23); NR | NR | NR
Williams-Sanchez, 2014^102^; Fair; New | Telephone DIN test;; Words-In-Noise test | Self-administered | Cohort | Community-dwelling veterans | 693 (1,379 ears) | Three audiology clinics and homes in FL, TN, and CA,; U.S. | 65 (13); NR | 97 | NR

* Only participants >50 years included.

† For 546 participants.

‡ Study included individuals as young as 20 years of age; however, they only reported accuracy by age intervals, and we therefore included only those ages 50 to 96 years.

§ HHIE not included in outcomes.

‖ Study examines older vs. younger examiners.

¶ Computed by data abstractors.

Abbreviations: CA=California; DIN=digits in noise; FL=Florida; ENT=ears, nose, throat; ERGO=acronym not described; HHIE(-S)=Hearing Handicap Inventory for Elderly(-Screening version); HL=hearing loss; KQ=key question; N=number of patients; NR=not reported; SD=standard deviation; TN=Tennessee; U.S.=United States; WVT=whispered voice test.

Most studies included community-dwelling older adults enrolled from various outpatient clinical or community settings; four studies included adults who were in chronic care/rehabilitation facilities.^81,^ ^87,^ ^92,^ ^96^ In addition, one study included cancer outpatients.^99^ In the 27 studies that reported sex of the participants, most included both males and females. Exceptions include two studies that were predominantly male^92,^ ^102^ and one that was entirely female.^76^ Sample sizes analyzed varied from 30 to 4,906 participants, with a median of 107. Across the 28 studies that reported on the age of enrolled participants (mean, median, or range), the median age of participants was 69.3 years. Two studies^3,^ ^81^ did not report age but had inclusion criteria limiting to older adults. Several studies included a minority of participants younger than 50 (the lower age boundary specified in our inclusion criteria), but in these studies the mean was at least 50, or we only included data for those who were age 50 or older. Of the 34 studies, only five^44,^ ^78,^ ^79,^ ^84,^ ^86^ reported on race or ethnicity; the percentage of participants who were white ranged from 0 to 100. Few reported any socioeconomic variables, and those that did reported the data in different ways: one study reported occupational classes,^75^ one study reported income,^84^ and six studies reported on education,^82,^ ^84–86,^ ^95,^ ^104^ using different metrics. The majority of studies (k=17) were set in the United States.^3,^ ^44,^ ^73,^ ^76,^ ^78–81,^ ^83,^ ^85,^ ^91,^ ^94,^ ^96,^ ^97,^ ^100–103^ The remainder were in Canada,^92,^ ^93^ the United Kingdom,^87–89^ Australia,^74,^ ^75^ other European countries;^42,^ ^77,^ ^82,^ ^90,^ ^95,^ ^98,^ ^99,^ ^104^ and Asia.^84,^ ^86^ We rated six studies as good quality^74,^ ^79,^ ^82,^ ^85,^ ^93,^ ^94^ and the remainder as fair quality (Appendix D Tables 13-16). In the studies rated as fair quality, common sources of bias included unclear description of index test administration or interpretation, unclear patient selection (e.g., no description of whether a consecutive or random sampling was used, and no or unclear description of exclusion criteria related to comorbidity or symptom status).

Screening test accuracy results are organized by test category below. Many studies reported on the accuracy of screening tests to detect hearing loss defined by multiple thresholds (e.g., >25 dB, >40 dB) averaged over different frequencies; definitions of hearing loss also varied in terms of laterality (one or both ears affected). Detailed results, including all screening test cut points and hearing loss definitions based on PTA reported by included studies, are shown in Appendix E Tables 1 through 4. Table 3 summarizes results by test category and hearing loss severity.

Table 3 Summary of Accuracy for Included Screening Tests (KQ 2)

Test | HL Severity (PTA dB Range) | N Studies; (Participants) | Sensitivity (%); (95% CI) | Specificity (%); (95% CI) | PLR; (95% CI) | NLR; (95% CI)
Single question | Mild (>20 to 25) | 10^*^ (12,637)^73–78,^ ^80–82,^ ^118^ | Pooled: 66 (58 to 73) | Pooled: 76 (68 to 83) | Pooled: 2.7 (2.2 to 3.4) | Pooled: 0.45 (0.38 to 0.53)
Single question | Moderate (>35 to 40) | 6^*^ (8,774)^74–76,^ ^82–84^ | Pooled: 80 (68 to 88) | Pooled: 74 (59 to 85) | Pooled: 3.1 (2.0 to 4.7) | Pooled: 0.27 (0.18 to 0.41)
HHIE-S score >8 | Mild (>25) | 4 (7,194)^75,^ ^78,^ ^85,^ ^86^ | 58 (53 to 61)^75^; 58 (45 to 70)^85^; 44 (NR)^86^; 34 (31 to 37)^78^ | 85 (83 to 87)^75^; 76 (69 to 84)^85^; 85 (NR)^86^; 95 (94 to 96)^78^ | 3.9 (3.8 to 3.9)^75^; 2.4 (1.7 to 3.5)^85^; 2.9 (1.6 to 4.9)^86^; 5.8 (6.6 to 7.0)^78^ | 0.49 (0.49 to 0.50)^75^; 0.55 (NR)^85^; 0.7 (0.6 to 0.8)^86^; 0.69 (0.69 to 0.70)^78^
HHIE-S score >8^†^ | Moderate (>40) | 5^ǂ^ (2,820)^3,^ ^44,^ ^75,^ ^83,^ ^85^ | Pooled: 68 (52 to 81) | Pooled: 79 (69 to 86) | Pooled: 3.21 (2.4 to 4.2) | Pooled: 0.41 (0.28 to 0.59)
HSAQ score ≥15 | Mild (>25) | 1 (112)^95^ | 100 (89 to 100) | 75 (64 to 84) | 4 (2.7 to 5.9) | 0
RFMHT score ≥15 | Mild (>25) | 1 (74)^97^ | 80 (NR) | 55 (NR) | 1.8 (NR) | 0.36 (NR)
WVT | Mild (>25 to 30) | 5^§^ (669)^42,^ ^73,^ ^87–89^ | Pooled: 94 (31 to 100) | Pooled: 87 (82 to 90) | Pooled: 7.1 (5.1 to 9.7) | Pooled: 0.06 (0.00 to 1.94)
WVT | Moderate (>40) | 3 (296)^73,^ ^87,^ ^90^ | 46 (36 to 56)^73^; 30^¶^ (8 to 65)^90^; 100 (95 to 100)^87^ | 78 (68 to 86)^73^; 100^¶^ (92 to 100)^90^; 84 (70 to 81)^87^ | 2.08 (NR)^73^; NR^90^; 6.0 (4.7 to 7.7)^87^ | 0.69 (NR)^73^; 0.69^¶^ ^90^; 0.0 (NR)^87^
Watch tick | Mild (>25) | 1 (107)^73^ | 44 (35 to 53) | 100 (NR) | NR | 0.56 (NR)
Watch tick | Moderate (>40) | 1 (107)^73^ | 60 (50 to 69) | 99 (92 to 100) | 60.0 (NR) | 0.40 (NR)
Finger rub | Mild (>25) | 1 (107)^73^ | 27 (20 to 36) | 98 (85 to 100) | 13.5 (NR) | 0.74 (NR)
Finger rub | Moderate (>40) | 1 (107)^73^ | 35 (26 to 46) | 97 (90 to 99) | 11.67 (NR) | 0.67 (NR)
DIN | Mild (>20 to 25) | 3 (4,110)^98,^ ^101,^ ^102^ | 79 (77 to 81)^98^; 80 (66 to 92)^101^; 81 (79 to 84)^102^ | 76 (74 to 78)^98^; 83 (69 to 92)^101^; 65 (60 to 70)^102^ | 3.3 (3.3 to 3.3)^98^; 4.7 (3.5 to 6.3)^101^; 2.3 (2.3 to 2.4)^102^ | 0.28 (0.27 to 0.28)^98^; 0.25 (0.20 to 0.30)^101^; 0.29 (0.28 to 0.29)^102^
WIN | Mild (>25) | 1 (1,049)^102^ | 97 (96 to 98)^102^ | 46 (39 to 52)^102^ | 1.8 (1.8 to 1.8)^102^ | 0.06 (0.05 to 0.06)^98^
AudioScope | Mild (>25 to 30) | 2 (215)^85,^ ^91^ | 71 (63 to 80)^85^; 93 (NR)^91^ | 91 (84 to 97)^85^; 70 (NR)^91^ | 7.5 (3.7 to 15.4)^85^; 3.1 (NR)^91^ | 0.32 (NR)^85^; 0.10 (NR)^91^
AudioScope | Moderate (>40) | 4 (411)^42,^ ^44,^ ^85,^ ^92^ | 100 (91 to 100)^42^; 96 (90 to 100)^85^; 98 (NR)^92^; 94 (85 to 98)^44^ | 42 (32 to 57)^42^; 80 (74 to 87)^85^; 24 (NR)^92^; 72 (64 to 79)^44^ | 1.72 (NR)^42^; 4.9 (3.5 to 6.9)^85^; 1.29 (NR)^92^; 3.4 (3.2 to 3.6)^44^ | 0^42^; 0.05 (NR)^85^; 0.08 (NR)^92^; 0.08 (0.04 to 0.15)^44^
Pure-tone audiometer screener | Moderate (>40) | 1^ǁ^ (405)^96^ | 50-59 years: 94 (NR); 60-69 years: 90 (NR); 70-79 years: 90 (NR); 80-89 years: 90 (NR); 90-96 years: 88 (NR) | 50-59 years: 93 (NR); 60-69 years: 94 (NR); 70-79 years: 92 (NR); 80-89 years: 90 (NR); 90-96 years: 93 (NR) | 50-59 years: 13.4 (NR); 60-69 years: 15.6 (NR); 70-79 years: 10.6 (NR); 80-89 years: 9.2 (NR); 90-96 years: 11.8 (NR) | 50-59 years: 0.06 (NR); 60-69 years: 0.11 (NR); 70-79 years: 0.11 (NR); 80-89 years: 0.11 (NR); 90-96 years: 0.13 (NR)
uHear^TM^ app | Moderate (>40) | 2^¶^ (78)^90,^ ^99^ | 68 (45 to 86)^99^; 100 (66 to 100)^90^ | 87 (76 to 94)^99^; 89 (77 to 96)^90^ | NR | NR
EarTrumpet app | Moderate (>40 dB) | 1 (33)^93^ | 88 (64 to 97)^93^ | 96 (86 to 99)^93^ | 21.4 (7.9 to 58.3)^93^ | 0.13 (0.05 to 0.35)^93^
EarTrumpet app | Mild (>20 dB) | 1 (35)^103^ | Quiet exam room: 96.3 (NR); Clinic waiting area: 100 (NR) | Quiet exam room: 83.1 (NR); Clinic waiting area: 72 (NR) | NR | NR
ShoeBOX app | Moderate (>40 dB) | 1 (33)^93^ | 100 (81 to 100)^93^ | 96 (86 to 99)^93^ | 24.5 (9.2 to 65.3)^93^ | 0^93^
Audiogram Mobile app | Mild (>20 dB) | 1 (37)^103^ | Quiet exam room: 85.3 (NR); Clinic waiting area: 87.6 (NR) | Quiet exam room: 95.1 (NR); Clinic waiting area: 92.3 (NR) | NR | NR
Hearing Test with Audiogram app | Mild (>20 dB) | 1 (35)^103^ | Quiet exam room: 87.8 (NR); Clinic waiting area: 89 (NR) | Quiet exam room: 69.4 (NR); Clinic waiting area: 68.2 (NR) | NR | NR

* One additional study of 1,731 community-dwelling adults in Japan that did not report sufficient data to be included in pooled analyses of single-question screeners found a sensitivity of 54 percent and a specificity of 78 percent for detecting mild hearing loss, and a sensitivity 88 percent and a specificity of 67 percent for detecting moderate hearing loss.^86^

† Only 2 studies evaluated a higher cut point (>10), and accuracy estimates are shown in Appendix E Table 2.^94,^ ^104^

ǂ One additional study of 1,731 community-dwelling adults in Japan that did not report sufficient data to be included in pooled analyses of HHIE-S using a cutoff score of >8 found similar accuracy for detecting moderate hearing loss (81% sensitivity and 78% specificity).^86^

§ Of these, one study (n=62) also assessed the accuracy of conversational voice at 2 feet and reported low sensitivity (47%) and high specificity (100%) for detecting mild hearing loss.^87^

ǁ One additional study assessed the accuracy of both the AudioScope and a portable audiometer to detect moderate HL (≥45 dB) in subpopulations defined by age decades (50- to 90-year-olds). Across all age groups, AudioScope sensitivities ranged from 85 to 90 percent and specificities ranged from 89 to 94 percent. Similarly, sensitivities for the portable audiometer ranged from 88 to 94 percent, and specificities ranged from 90 to 94 percent.^96^

¶ Estimates here are based on a positive screening test definition of ≥2 consecutive hearing grades starting from the moderate-severe threshold zone ranging from 0.5 to 2.0 kHz. Using a scoring method that defined a positive screening test result based on PTA ≥40 dB at 0.5, 1.0 or 2.0 kHz, sensitivity was high in both cohorts (100%), but specificity was relatively low (38% and 36%).^90,^ ^99^

Abbreviations: app=application; CI=confidence interval; DIN=digits in noise; HHIE-S=Hearing Handicap Inventory for the Elderly-Screening version; HL=hearing loss; HSAQ=Hearing Self-Assessment Questionnaire; KQ=key question; N=number; NLR=negative likelihood ratio; NR=not reported; PLR=positive likelihood ratio; PTA=pure tone average; RFMHT=Revised Five Minute Hearing Test; WIN= words in noise; WVT=whispered voice test.

##### Single-Question Screening

Thirteen studies assessed the accuracy of single-question screening for detecting hearing loss (Appendix E Table 1).^73–84,^ ^86^ The exact wording of the question varied slightly across studies (e.g., “Do you have a hearing problem now?” vs. “Do you feel you have a hearing loss?”). All studies indicated that an affirmative or “yes” response to the question was considered a positive screen; only one study noted that both affirmative and equivocal responses were considered a positive screen.^81^

For detecting mild hearing loss (>20 to 25 dB averaged over 3 to 4 frequencies), the pooled sensitivity based on 10 studies (12,637 participants) was 66 percent (95% CI, 58% to 73%) and the pooled specificity was 76 percent (95% CI, 68% to 83%) (Table 3; Appendix F Figure 1).^73–82^ The pooled sensitivity to detect moderate hearing loss (>35 to 40 dB averaged over 2 to 4 frequencies) based on six studies (8,774 participants) was 80 percent (95% CI, 68% to 88%) and the pooled specificity was 74 percent (95% CI, 59% to 85%) (Table 3; Appendix F Figure 2).^74–76,^ ^82–84^ One additional study of 1,731 community-dwelling adults in Japan that did not report sufficient data to be included in pooled analyses found a sensitivity of 54 percent and a specificity of 78 percent for detecting mild hearing loss and a sensitivity 88 percent and a specificity of 67 percent for detecting moderate hearing loss.^86^

##### Screening Questionnaires

Eleven studies (reported in 12 articles) assessed the accuracy of screening questionnaires (Appendix E Table 2).^3,^ ^44,^ ^75,^ ^78,^ ^83,^ ^85,^ ^86,^ ^94,^ ^95,^ ^97,^ ^100^ Of these, eight studies assessed the accuracy of HHIE-S.^3,^ ^44,^ ^75,^ ^78,^ ^83,^ ^85,^ ^86,^ ^94,^ ^100^ Too few studies reported sufficient data to pool accuracy of the HHIE-S for detecting mild hearing loss (>25 dB at 2 to 4 frequencies). Across four studies (7,194 participants), sensitivity of HHIE-S using a cut point of score >8 ranged from 34 to 58 percent, and specificity ranged from 76 to 95 percent.^75,^ ^78,^ ^85,^ ^86^ For detecting moderate hearing loss (>40 dB at 2 to 4 frequencies), the pooled sensitivity of HHIE-S using a cutoff score of >8 based on five studies (2820 participants) was 68 percent (95% CI, 52% to 81%) and pooled specificity was 79 percent (95% CI, 69% to 86%) (Table 3; Appendix F Figure 3).^3,^ ^44,^ ^75,^ ^83,^ ^85^

Two additional screening questionnaires were evaluated in one study each, the Hearing Self-Assessment Questionnaire (HSAQ)^95^ and the Revised Five Minute Hearing Test (RFMHT).^97^ For detecting mild hearing loss (>25 dB at 4 frequencies), the HSAQ had a sensitivity of 89 percent (95% CI, 78% to 96%) and specificity of 84 percent (95% CI, 72% to 92%) using a cut point of ≥15; sensitivity was slightly lower (76%) and specificity was slightly higher (96%) at a cut point of ≥19.^95^ The sensitivity of the RFMHT for detecting mild hearing loss was 80 percent and specificity was 55 percent.

##### Clinical Tests

Nine studies^42,^ ^73,^ ^87–90,^ ^98,^ ^101,^ ^102^ evaluated the diagnostic accuracy of whispered voice, conversational voice, finger rub, watch tick, digits-in-noise (DIN), and WIN tests (Appendix E Table 3). Six of these studies^42,^ ^73,^ ^87–90^ assessed the accuracy of the whispered voice test at 6 inches and/or 2 feet using letters, words, or numbers, with different passing criteria, and one assessed the accuracy of the conversational voice test at 2 feet.^87^ For detecting mild hearing loss (>25 to 30 dB), pooled sensitivity of the whispered voice test was 94 percent (95% CI, 31% to 100%), and pooled specificity was 87 percent (82% to 90%) (5 studies; 669 participants) (Appendix F Figure 4).^42,^ ^73,^ ^87–89^ One study included in the pooled analysis reported on sensitivity and specificity of the whispered voice test when conducted by providers with different levels of experience and found variable results.^88^ A pooled analysis including data from experienced providers (vs. inexperienced/newly trained providers) was similar, but sensitivity was slightly higher (96%) and specificity was lower (79%). Sensitivity for detecting at least moderate hearing loss defined as >40 dB (3 studies; 296 participants) ranged from 30 to 60 percent and specificity ranged from 80 to 98 percent.^73,^ ^88,^ ^90^

Few studies assessed other clinical screening tests for hearing loss. One study (n=62) assessed the accuracy of the conversational voice test at 2 feet^87^ and reported low sensitivity (47%) and high specificity (100%) for detecting mild hearing loss. Watch tick and finger rub tests for detecting mild and moderate hearing loss were assessed in one study.^73^ Sensitivities were low for the watch tick and finger rub tests for detecting both mild (44% and 27%, respectively) and moderate hearing loss (60% and 35%, respectively); specificities were high for detecting both mild (100% and 98%, respectively) and moderate hearing loss (99% and 97%, respectively). Three studies^98,^ ^101,^ ^102^ assessed the accuracy of either DIN or WIN tests to detect mild hearing loss using different methods (Appendix E Table 3), including the U.S. National Hearing Test (a DIN telephone screening protocol developed for use within the VA)^102^ Sensitivity of the DIN or WIN ranged from 42 to 99 percent, with a median of 90 percent; specificity ranged between 24 and 98 percent, with a median of 86 percent.

##### Handheld or Mobile-Based Audiometric Devices

Ten studies evaluated the accuracy of various handheld audiometric screening devices (Appendix E Table 4).^42,^ ^44,^ ^85,^ ^90–93,^ ^96,^ ^99,^ ^103^

Five evaluated the AudioScope, a device that combines an otoscope with a portable audiometer to screen for hearing loss in the 0.5 to 4 kHz range. Two studies (215 participants) assessed the accuracy of the AudioScope to detect mild hearing loss (PTA thresholds of >25 to >30 dB); sensitivities ranged from 64 to 93 percent, and specificities ranged from 70 to 91 percent.^85,^ ^91^ For detecting moderate hearing loss (≥40 dB), evidence from four studies (411 participants) found relatively high sensitivity (range: 94% to 100%) and variable specificity (range: 24% to 80%) for the AudioScope.^42,^ ^44,^ ^85,^ ^92^ One study^96^ assessed the accuracy of both the AudioScope and a portable audiometer to detect moderate hearing loss (≥45 dB) in subpopulations defined by age decades, beginning with 50-year-olds through 90-year-olds. Across all age groups, sensitivities and specificities of both the AudioScope and portable audiometer for detecting moderate hearing loss were high (Appendix E Table 4). AudioScope sensitivities ranged from 85 to 90 percent, and specificities ranged from 89 to 94 percent. Similarly, sensitivities for the portable audiometer ranged from 88 to 94 percent, and specificities ranged from 90 to 94 percent.

Four studies assessed various tablet-based software audiogram apps designed for screening. Two studies by the same authors evaluated the accuracy of the uHear^TM^ app in two separate cohorts of older adults with cancer undergoing a comprehensive geriatric assessment (78 participants) using different scoring methods to determine a positive screen.^90,^ ^99^ Using a scoring method that defined a positive screening test result based on PTA ≥40 dB at 0.5, 1.0, or 2.0 kHz, sensitivity was high in both cohorts (100%) but specificity was relatively low (38% and 36%).^90,^ ^99^ A revised scoring method to determine a positive screen was applied to both cohorts, defined as two or more nonconsecutive hearing grades below the moderate-to-severe threshold (≥56 dB) measured at five frequencies (from 0.5 to 4.0 kHz) in at least one ear.^99^ Based on this method, sensitivity varied between the first and second cohorts (100% and 68%, respectively), and specificity was similar (89% and 87%).^99^

One study (33 participants)^93^ assessed two iOS apps, EarTrumpet and ShoeBox, and found that both had relatively high sensitivity (88% and 100%, respectively) and specificity (96% for both) for detecting moderate hearing loss.

One RCT (107 participants)^103^ assessed three different apps—EarTrumpet (n=35), Audiogram Mobile (n=37), and Hearing Test with Audiogram (n=35)—for their ability to detect mild hearing loss (≥ 20 dB hearing loss at frequencies ranging from 0.25 to 8.0 kHz) in either a clinic waiting area or a quiet exam room. Following pure-tone audiometry, patients were randomly assigned to receive only one screening app in both the waiting area and quiet exam room. The specific screening setting had a minimal effect on test accuracy. In a clinic waiting area, all three apps had relatively high sensitivity (100%, 88%, and 89%, respectively), but more variation was seen in their specificities (72%, 92%, and 68%, respectively). In a quiet exam room, sensitivity remained relatively high (96%, 85%, and 88%, respectively), and specificity remained variable (83%, 95%, and 69%, respectively).

### KQ 3a What Are the Harms of Screening for Hearing Loss in Adults Age 50 Years or Older?

### KQ 3b Do the Harms of Screening for Hearing Loss Differ for Subpopulations Defined by Age, Sex, Race/Ethnicity, Risk of Past Noise Exposure, or Comorbid Condition?

We identified no eligible studies that evaluated harms associated with screening for hearing loss in older adults.

### KQ 4a What Is the Efficacy of Interventions for Screen-Detected Hearing Loss in Improving Health Outcomes in Adults Age 50 Years or Older?

#### Summary

Six trials (reported in 8 articles) evaluated benefits of amplification compared with no amplification among populations with screen-detected or recently detected, untreated age-related hearing loss over 6 weeks to 4 months.^105–112^ In five trials reporting on the HHIE, four found statistically significant benefit in favor of hearing aids compared with no amplification, and one crossover RCT found no difference between groups.^110^ Three of the four trials that found statistically significant benefit enrolled veterans (two RCTs^105,^ ^108^ and one nonrandomized trial^107^); the difference in HHIE score changes from baseline in all three trials was greater than the 18.7-point difference considered to represent a minimal important difference.^113^ One RCT enrolling community volunteers found higher HHIE score changes from baseline among groups receiving two different hearing aid interventions (−18.2 points and −12.3 points) than placebo (−5.5 points); although comparisons were statistically significant for either intervention vs. placebo (p<0.001), differences between groups did not meet the score change considered to represent a minimal important difference. Four studies reported on general QOL or function and other non-hearing-related health outcomes;^105,^ ^107,^ ^110,^ ^111^ of these, one found significant benefit in favor of the intervention on the Short Portable Mental Status Questionnaire and Geriatric Depression Scale.^105^ No study examined the effect of interventions on the incidence of dementia or neurocognitive impairment. The results are most applicable to older male populations with improved access to screening and no-cost hearing aids, such as veterans’ groups.

#### Detailed Evidence

We identified six controlled trials comparing amplification with no amplification among older adults with screen-detected or recently detected mild to moderate hearing loss (Table 4). Three were included in the 2011 review for the USPSTF,^105,^ ^107,^ ^110^ and three are newly included.^108,^ ^111,^ ^112^ All studies were set in the United States; enrolled populations included veterans (3 studies)^105,^ ^107,^ ^108^ and community-dwelling older adults (3 studies).^110–112^ Across all studies, the mean age of enrolled populations ranged from 69 to 74 years. Five studies enrolled a majority of males (56% to 100%), and one enrolled mostly females (53%).^111^ In five studies, the baseline HHIE score ranged from 29 to 51 (indicating at least mild to moderate hearing-related handicap).^114^ Sample sizes ranged from 15 to 380 participants. Four studies reported on race; of these, two were predominantly white (95% and 98%)^105,^ ^112^ and one was 40 percent white.^111^ Interventions included ALDs (3 studies)^107,^ ^110,^ ^111^ and traditional hearing aids (5 studies).^105,^ ^108,^ ^110–112^ Studies varied in terms of the detail provided about hearing aid features and how they were fitted (Table 5). In the three studies evaluating ALDs, one did not describe the device,^107^ one assessed a devise comprising a single earbud connected to a receiver via a cord,^110^ and one evaluated two different ALDs: one with a remote microphone and headphones with dials for volume and tone control and a Bluetooth-enabled, single-ear-worn device that can be paired with a smartphone.^111^ Three studies compared multiple interventions with a no-amplification control group, including one study that assessed provision of the same hearing-aid device via two different service delivery models (one group received fitting using best-practice services from audiologists and the other group self-selected their own pre-programmed aids in a model designed to simulate OTC purchasing)^112^ and two that assessed both hearing aids and ALDs.^107,^ ^110^ Duration of followup ranged from 6 weeks to 4 months. All studies reported on at least one hearing-related QOL and/or function outcome, primarily the HHIE questionnaire; four studies also reported on non-hearing-related health outcomes.^105,^ ^107,^ ^110,^ ^111^ All studies were RCTs; one study also included a nonrandomized comparison of veterans who received two types of hearing aids (via randomized allocation) and a no-amplification control group that was randomized separately (to no-amplification vs. an assistive listening device).^107^ All studies were rated fair quality. Common sources of bias included lack of blinding (in that only one study compared amplification with a placebo device^112^), small sample sizes, and/or select study populations with limited descriptions of their baseline characteristics, raising concern for potential selection bias.

Table 4 Characteristics of Randomized, Controlled Trials of Treatment for Hearing Loss

Author, Year | Study Design | N | Setting (Country) | Source Population | Eligibility Criteria | Mean Age, Yrs (SD) | % Male | % White | Baseline HL
Humes, 2017^112^ | Double-blind RCT | 154 | Community (U.S.) | Participants recruited via ads posted in local newspapers and around the community for a trial at Indiana University, Bloomington, IN | Age 55-79 yrs; English-speaking; MMSE>25; no prior HA experience; PTA thresholds consistent with age-related, bilateral SNHL; no hearing-related pathologies either specific to ear anatomy, medication use, or medical conditions; and willingness to be randomized. | 69 (6) | 56 | 98 | Bilateral PTA (500, 1000, and 2000 Hz), mean (SD): 28.1 (8.0) dB; Bilateral high-frequency PTA (1000, 2000, and 4000 Hz): mean (SD): 38.8 (7.9) dB
Jerger, 1996^110^ | Crossover RCT | 80 | Community (U.S.) | Paid participants recruited via ads in community centers in Houston, TX | Age >60 yrs; bilateral high-frequency SNHL >15 dB in both ears; normal middle ear status; average score ≤3 on self-report physical health scale; normal MMSE score (≥24); no history of neurologic or psychiatric disorder | 74 (range, 60-96) | 63 | NR | Bilateral PTA (500, 1000, and 2000 Hz), mean: 37.4 dB
McArdle, 2005^108,^ ^109^ | Unblinded RCT | 380 | VA audiology clinic (U.S.) | Community-dwelling participants from the general audiology clinics at four VA medical centers who were eligible to receive no cost HAs | Adult-onset SNHL; no asymmetry of PTA thresholds or speech-recognition scores in quiet; no prior HA use; “passing” MMSE score; at least a mild, high-frequency BEHL ≥30 dB at 2000, 3000, and 4000 Hz; no known conductive or retrocochlear pathologies, neurologic or psychiatric disorders, and no significant comorbid diseases; and access to a telephone | 69.4 (9.0) | 98 | NR | NR
Mulrow, 1990^105^ | Unblinded RCT | 194 | VA primary care clinic (U.S.) | Participants from one VA general medicine clinic invited for hearing screening and follow-up diagnostic testing to determine eligibility; or from other VA clinics at same institution with hearing impairment referred by providers | Age >64 yrs; formal audiologic testing confirmed HL; residence <100 miles from clinic; no current HA use; and no severe disabling comorbidities^*^ | 72 (NR) | HA group: 100; Control: 99 | HA group: 98; Control: 96 | Better ear PTA (1000, 2000, and 4000 Hz), mean: 52 dB
Nieman, 2017^111^ | Unblinded RCT | 15 | Community (U.S.) | Community-dwelling adults recruited from three buildings that house low- to middle-income, predominantly African American older adults subsidized by a nonprofit in Baltimore, MD, recruited via flyers and invitations from service coordinators in each building | Aged ≥60 yrs; English-speaking; clinically significant mild or worse HL; no current HA use; had communication partner who would participate in study (18 yrs or older who spoke with participant daily) | Median (IQR): 70 (67-76) | 47 | 40 | Better ear PTA (1000, 2000 and 4000 Hz), median (IQR): 40 (32.5 to 53.3) dB
Yueh, 2001^107^ | Unblinded RCT | 30 | VA audiology clinic (U.S.) | Veterans seeking diagnostic visits or hearing aid evaluations at the audiology clinic of VA Puget Sound Health Care System | Age ≥50 yrs; diagnosed with symmetric, bilateral, mild to moderately severe sensorineural HL; no asymmetric or conductive HL; or atypical causes of SNHL; no prior HA use; good cognitive function; and normal manual dexterity | 69 (NR) | 100 | NR | Mean PTA, right ear: 32.9 dB; Mean PTA, left ear: 32.4 dB

* Terminal cancer, hepatic encephalopathy, and end-stage pulmonary disease requiring home oxygen therapy; residence >100 miles from clinic).

Abbreviations: BEHL=best ear hearing level; HA=hearing aid(s); HL=hearing loss; IN=Indiana; IQR=interquartile range; MD=Maryland; MMSE=Mini-Mental State Examination; N=number of patients; NR=not reported; PTA=pure tone average; RCT=randomized, controlled trial; SD=standard deviation; SNHL=sensorineural hearing loss; TX=Texas; U.S.=United States; VA=Veterans Administration.

Table 5 Hearing-Related Outcomes in Randomized, Controlled Trials of Treatment

Author, Year | Study Design | N | Interventions (N) | Duration | HHIE | Other Hearing-Related Outcomes
Humes, 2017^112^ | Double-blind RCT | 154 | G1: Placebo hearing aid (n=55); G2: Audiology-based HA model (digital mini-behind-the-ear open-fit devices) fitted bilaterally (n=53); G3: Consumer-driven HA model (self-selected of same HA preprogrammed to simulate OTC delivery model) (n=55) | 6 wks | Baseline HHIE (SD):; G1: 29.0 (16.4); G2: 27,7 (13.6); G3: 29.3 (17.3); Mean change from baseline (SD):; G1: −5.5 (11.5); G2: −18.2 (14.2); G3: −12.3 (14.1); p <0.001 G2 vs. G1 and G3 vs. G1 | Baseline PHAP^119^ (SD):; G1: 0.40 (0.13); G2: 0.36 (0.12); G3: 0.38 (0.13); Mean change from baseline (SD):; G1: 0.04 (0.10); G2: 0.17 (0.12); G3: 0.12 (0.12); p <0.001 for G2 vs. G1 and G3 vs. G1
Jerger, 1996^110^ | Crossover RCT | 80 | G1: No amplification (n=80); G2: Conventionally worn behind the ear HA, described as digital/analog hybrid fitted monaural (exact device varied based on audiometry results) (n=80); G3: ALD with remote microphones (Comtek receiver) (n=80); G4: Both conventionally worn behind the ear HA (G2) and ALD with remote microphone (G3) (n=80) | 6 wks | Baseline HHIE (SD):; 30.2 (NR); HHIE post-treatment:; G1: 28 (NR); G2: 25 (NR); G3: 27 (NR); G4: 26 (NR); No significant difference between G1 and any amplification (G2, G3, or G4) | HHIE (reported by significant other):; Baseline (SD): NR; Mean change from baseline (SD):; G1: −1.4 (NR); G2: −7.5 (NR); G3: −4.4 (NR); G4: −9.5 (NR)
McArdle, 2005^108^ | Unblinded RCT | 380 | G1: Delayed HA fitting (n=191); G2: HA (custom, in the ear digitally programmable, analog or fully digital), fitted in accordance with 2000 Joint Audiology Committee guidelines per authors (n=189) | 10 wks | Baseline HHIE (SD):; G1: 41.30 (21.46); G2: 41.42 (23.43); Mean change from baseline:; G1: +1.8 (NR); G2: −17.5 (NR); p<0.01 | APHAB (SD):; G1: 51.21 (15.30); G2: 47.63 (16.38); Mean change from baseline:; G1: 3.17; G2: −29.53; p<0.01; WHO-DAS II:; G1: 15.99 (13.24); G2: 15.60 (15.59); Mean change from baseline:; G1: 3.17; G2: −2.9; p<0.01
Mulrow, 1990^105^ | Unblinded RCT | 194 | G1: Wait-list control (n=99); G2: HA (at no cost) described as mostly in-the-ear devices (98%) fitted monaurally during a single 45-min HA fitting and orientation session (n=95) | 4 mos | Baseline HHIE (SD):; G1: 51.2 (29.1); G2: 48.7 (27.3); Mean change from baseline (SD):; G1: 0 (NR); G2: 34.0 (NR); Difference in mean change (95% CI):; −34.0 (−27.3 to −40.8); p<0.0001 | Baseline QDS (SD):; G1: 61.0 (25.4); G2: 58.7 (24.5); Mean change from baseline (SD):; G1: +1.2 (NR); G2: −23 (NR); Difference in mean change (95% CI):; −24.2 (−17.2 to −31.2); p<0.001
Nieman, 2017^111^ | Unblinded RCT | 15 | G1: Wait-list control (n=7); G2: One of two OTC devices (Bluetooth-enabled, single-ear worn device similar to HA paired to a smartphone or Pockettalker ALD device with remote microphone and headphones) with one-time individual training session (participant and communication partner), fitting and orientation to the OTC device, and communication education and counseling (n=8) | 3 mos | NR | Baseline HHIE-S, median (IQR):; G1: 20 (17 to 20); G2: 19 (14.5 to 27.5); HHIE-S post-treatment, median (IQR):; G1: 16 (14 to 22); G2: 10 (10 to 14.5); Mean change from baseline (SD):; G1: 0.3 (4.5); G2: −8.5 (15.4); Baseline Revised QDS, median (IQR):; G1: 16 (12.5 to 16.6); G2: 16 (14 to 20.2); Revised QDS post-treatment, median (IQR):; G1: 13 (11 to 14.5); G2: 10.5 (6 to 14.2); Mean change from baseline (SD):; G1: −2.1 (4.3); G2: −5.9 (6.8)
Yueh, 2001^107^ | Unblinded RCT; non-randomized trial | 60 | Randomized groups (veterans with non-service-connected HL):; G1: No amplification (n=15); G2: ALD (n=15); Non-randomized groups (veterans with service-connected HL) fitted with one of two half-shell in-the-ear analog HAs:; G3: Standard HA (nonprogrammable nondirectional aid) (n=14); G4: Programmable HA (with switchable directional microphone and remote control) (n=16) | 3 mos | Baseline HHIE (SD):; G1: 35.1 (31.6); G2: 28.5 (19.5); G3: 36.4 (18.5); G4: 49.8 (26.5); Mean change from baseline (SD):; G1: −2.2 (NR); G2: −4.4 (NR); G3: −17.4 (NR); G4: −31.1 (NR); p<0.001 for G3 and G4 vs. G1 | Baseline APHAB (SD):; G1: 38.5 (16.2); G2: 37.5 (14.5); G3: 43.1 (12.3); G4: 52.3 (18.4); Mean change from baseline (SD):; G1: −2.7 (NR); G2: −6.4 (NR); G3: −7.7 (NR); G4: −16.3 (NR); p=0.01 for G3 and G4 vs. G1; Revised QDS:; Baseline NR; Mean change from baseline (SD):; G1: −0.05; G2: 0.03; G3: 0.70; G4: 0.84; p=0.01 for G3 and G4 vs. G1

Abbreviations: ALD=assistive listening device(s); APHAB=Abbreviated Profile of Hearing Aid Benefit; G=group; HA=hearing aid(s); HHIE(-S)=Hearing Handicap Inventory for the Elderly(-Screening version); HL=hearing loss; IQR=interquartile ratio; N/n=number of patients in a group; NR=not reported; OTC=over the counter; QDS=Quantified Denver Scale of Communication Function; RCT=randomized, controlled trial; SD=standard deviation; vs.=versus; WHO-DAS II=World Health Organization’s Disability Assessment Scale II.

##### Hearing-Related QOL and Function

All studies reported on one or more hearing-related QOL and/or function measures (Table 5). Most (5 studies) reported on the HHIE (25-items, score range: 0 to 100); lower HHIE scores (0 to 16) indicate no hearing handicap and higher scores indicate mild to moderate (17 to 42) or significant handicap (≥43).^114^ Mean baseline HHIE scores ranged from 29 to 51 across all study arms and were slightly higher in three studies enrolling veterans eligible for free hearing aids (36 to 51) than studies enrolling community volunteers (25 to 29).^110,^ ^112^ Overall, four trials found statistically significant benefit in favor of hearing aids compared with no amplification, and one crossover RCT found no difference between groups.^110^ Three of the four trials that found statistically significant benefit enrolled veterans (two RCTs^105,^ ^108^ and one nonrandomized trial^107^); the difference in HHIE score changes from baseline in all three trials was greater than the 18.7-point difference considered to represent a minimal important difference.^113^ The two RCTs enrolling veterans (574 total participants) both found significantly larger changes in baseline HHIE scores among those receiving hearing aids than controls over followup durations of 4 months (−34 points vs. 0 points; p<0.0001^105^ and 10 weeks (−17.5 points vs. +1.8 points; p<0.01).^108^ Results from the nonrandomized trial enrolling veterans (n=60) were consistent with the two RCTs; change in mean HHIE scores from baseline was higher among those receiving either a conventional hearing aid (−17.4 points) or a programmable hearing aid (−31.1 points) than controls (−2.2 points), p<0.001 for both comparisons.^107^ However, in the same study, there was no significant difference between groups randomized to an assistive living device (−4.4 points) or control (−2.2 points) over 3 months.^107^ The one RCT set in a non-VA setting that found benefit recruited participants via community advertisements at one academic institution (n=163) who were randomized to one of three arms: audiology-based best-practice fitted hearing aid, self-selection of the same hearing aid that was preprogramed and designed to simulate OTC purchasing, or a placebo device (fitted by an audiologist).^112^ At 6 weeks, the HHIE score change from baseline was higher in the audiology-based hearing aid group (−18.2 points) and OTC hearing aid group (−12.3 points) than placebo (−5.5 points); although comparisons were statistically significant for either intervention vs. control (p<0.001), differences between groups did not meet the score change considered to represent a minimal important difference (−18.7 points).^112^ The one study that did not find significant between-group differences in HHIE scores was a crossover RCT (n=80) enrolling community volunteers; participants were allocated to each arm for 6 weeks; there were no significant between-group differences in mean changes from baseline HHIE scores associated with hearing aids (−5.2 points), assistive listening devices (−3.2 points), hearing aids combined with assistive listening devices (−4.1 points), and no amplification (−2.2 points).^110^ This study also provided HHIE score changes from baseline reported by a significant other; authors only reported mean changes from baseline that were slightly larger for hearing aids (−7.5 points), assistive listening devices (−4.4 points), and hearing aids combined with assistive listening devices (−9.5 points) than no amplification (−1.4 points).^110^ No baseline scores, measures of variance, or significance of between-group differences were reported.

For other hearing-related outcomes, few studies reported on the same measure (Table 5). Two trials reported on the revised QDS.^107,^ ^111^ One was a nonrandomized trial enrolling veterans (n=60); changes in mean score from baseline were larger among groups receiving a standard hearing aid (−0.70 points) and programmable hearing aid (−0.86 points) than controls (−0.05 point) (p=0.01), but there was no difference between the assistive listening device (+0.03 points) and no amplification controls (−0.05).^107^ The second trial (n=15) found a slightly larger change from baseline scores among the intervention group than controls (−5.9 vs. −2.1) but did not comment on whether the change was statistically significant.^111^ Two trials enrolling veterans reported on the Abbreviated Profile of Hearing Aid Benefit (APHAB), a 24-item scale used to measure self-rated communication ability.^107,^ ^108^ One RCT (n=380) found larger reductions in mean scores among the hearing aid group vs. controls at 10 weeks (mean change in baseline APHAB score: −29.5 vs. +4.2; p<0.01).^108^ Results from the nonrandomized comparison were similar, showing larger reductions in mean APHAB scores from baseline to 3 months among those receiving standard hearing aids (−7.7 points) and programmable hearing aids (−16.3 points) than controls (−2.7 points), (p=0.01); however, changes in scores were not significantly different among groups randomized to an assistive listening device vs. control (−2.7 vs. −6.4 points).^107^ One trial reported on the WHO-DAS II (n=380) and found significantly larger changes from baseline scores among the hearing aid group than controls at 10 weeks (−2.9 vs. 3.2; p<0.01).^108^ Finally, one crossover RCT (n=15) measured changes in mean HHIE-S scores (15 items, score range: 0 to 40); at 3 months, changes in baseline scores were slightly larger among those receiving the intervention vs. controls (−8.5 vs. 0.03, respectively).^111^ Authors did not provide measures of variance or comment on statistical significance; however, the magnitudes of the differences between groups (and change from baseline scores) do not meet the 10-point change considered to be a clinically meaningful difference.^115^

##### Other Health Outcomes

Four studies reported on at least one general (non-hearing-related) health outcome, including general measures of QOL, cognitive function, social isolation, and depression (Table 6).^105,^ ^107,^ ^110,^ ^111^ No outcome measure was assessed by more than one study. Three studies reported outcomes but did not provide numerical results^110^ or did not report sufficient information to determine whether differences between groups were significant.^107,^ ^111^ One RCT enrolling veterans (n=194) found statistically significant benefit among those receiving hearing aids vs. controls on measures of cognitive function (Short Portable Mental Status Questionnaire, difference between groups in change from baseline: −0.28 points [95% CI, 0.08 to 0.48]; p=0.008) and depression (Geriatric Depression Scale, difference between groups in change from baseline: −0.80 points [95% CI, 0.09 to 1.51]; p=0.03), but no significant difference between groups on a measure of general health and function (Self Evaluation of Life Function scale, difference between groups in change from baseline: −1.9 points [95% CI, −0.1 to 4.0]; p=0.07).^105^

Table 6 General Health-Related QOL and Function and Other Health Outcomes in Randomized, Controlled Trials of Treatment

Study, Year | Study Design | N | Intervention (N) | Duration | General Health-Related QOL and Function Outcomes | Other Health Outcome^*^
Jerger, 1996^110^ | Crossover RCT | 80 | G1: No amplification (n=80); G2: Conventionally worn behind-the-ear HA (n=80); G3: ALD with remote microphones (n=80); G4: Conventionally worn behind-the-ear HA (G2) and ALD with remote microphone (G3) (n=80) | 6 wks | Affect Balance Scale: no differences between interventions and control per authors (data NR; shown in figures only) | Social Activity Scale and Brief Symptom Inventory: no differences between interventions and control per authors (data NR, shown in figures only)
Mulrow, 1990^105^ | Unblinded RCT | 194 | G1: Wait-list control (n=99); G2: HA (at no cost), single 45 min HA fitting and orientation session (n=95) | 4 mos | Mean baseline SELF (SD):; G1: 95.6 (18.0); G2: 92.7 (16.5); Post-treatment mean:; G1: 96.8 (18.8); G2: 92.0 (18.2); Difference in mean change from baseline: (95% CI):; 1.9 (−1.6 to 5.4); p=0.27) | Mean baseline SPMSQ (SD):; G1: 0.18 (0.46); G2: 0.47 (0.75); Post-treatment mean (SD):; G1: 0.28 (0.66); G2: 0.29 (0.66); Difference in mean change from baseline (95% CI):; −0.28 (0.08 to 0.49); p=0.008; Mean baseline GDS (SD):; G1: 3.5 (3.56); G2: 3.1 (2.81); Post-treatment mean (SD):; G1: 3.8 (3.57); G2: 2.6 (2.79); Difference in mean change from baseline (95% CI):; 0.80 (0.09 to 1.51); p=0.03
Nieman, 2017^111^ | Unblinded RCT | 15 | G1: Wait-list control (n=7); G2: One of two OTC devices (HA or ALD) with one-time individual training session (participant and communication partner), fitting and orientation to the OTC device, and communication education and counseling (n=8) | 3 mos | Baseline SF-36 Mental component:; G1: 56.6 (49.7 to 59.3); G2: 50.9 (38.0 to 57.2); Mean change from baseline (SD):; G1: 1.7 (14); G2: 2.1 (14.7); Baseline SF-36 Physical component:; G1: 50.6 (49.7 to 59.3); G2: 41.5 (40.3 to 47.0); Mean change from baseline:; G1: −1.3 (5.4); G2: 3.6 (5.8) | Baseline Revised UCLA Loneliness Scale, median (IQR):; G1: 46 (37.5 to 55.5); G2: 46 (34.8 to 54); Mean change from baseline (SD):; G1: −4 (5.2); G2: −2.1 (10.8); Baseline PHQ-9:; G1: 8 (3 to 8.3); G2: 9.5 (4.8 to13.8); Mean change from baseline (SD):; G1: −1.0 (1.7); G2: −4.4 (6.4)
Yueh, 2001^107^ | Unblinded RCT | 30 | Randomized groups (veterans with non-service-connected HL):; G1: No amplification (n=15); G2: ALD (n=15); Non-randomized groups (veterans with service-connected HL):; G3: Standard HA (n=14); G4: Programmable HA (n=16) | 3 mos | NR | Proportion reporting less social isolation, n (%):^†^; G1: 0 (0); G2: 0 (0); G3: 2 (14); G4: 10 (52)

* Includes measures of cognitive function, depression, social isolation, and social function.

† Participants were asked to maintain a hearing diary for the duration of the study, which included the number of hours each day that they encountered hearing-related difficulties. Authors performed a qualitative analysis of open-ended comments from the diaries, organizing open-ended comments into categories of issues raised by individual participants, which included social impairment.

Abbreviations: ALD=assistive listening device(s); CI=confidence interval; G=group; GDS=Geriatric Depression Scale; HA=hearing aid; HL=hearing loss; IQR=interquartile range; N/n=number of patients in a group; NR=not reported; OTC=over the counter; PHQ-9=Patient Health Questionnaire-9; QOL=quality of life; RCT=randomized, controlled trial; SD=standard deviation; SELF=Self-Evaluation of Life Function; SF-36=36-Item Short Form Survey; SPMSQ=Short Portable Mental Status Questionnaire; UCLA=University of California-Los Angeles.

### KQ 4b Does the Efficacy of Interventions for Screen-Detected Hearing Loss Differ for Subpopulations Defined by Age, Sex, Race/Ethnicity, Risk of Past Noise Exposure, or Comorbid Condition?

No subpopulation analyses were reported by the included studies.

### KQ 5a What Are the Harms of Interventions for Screen-Detected Hearing Loss in Adults Age 50 Years or Older?

### KQ 5b Do the Harms of Interventions for Screen-Detected Hearing Loss Differ for Subpopulations Defined by Age, Sex, Race/Ethnicity, Risk of Past Noise Exposure, or Comorbid Condition?

No eligible studies reporting on harms were identified.