# Chapter 2 Methods

## Key Questions and Analytic Framework

The scope and key questions (KQs) were developed by the Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers. The analytic framework and KQs that guided the review are shown in Figure 1. Five KQs were developed for this review:

1. a. Does screening for hearing loss in asymptomatic adults age 50 years or older lead to improved health outcomes?
  b. Does the effectiveness of screening differ for subpopulations defined by age, sex, race/ethnicity, risk of past noise exposure, or comorbidity?
2. What is the accuracy of primary care–relevant screening tests for hearing loss in adults age 50 years or older?
3. a. What are the harms of screening for hearing loss in adults age 50 years or older?
  b. Do the harms of screening for hearing loss differ for subpopulations defined by age, sex, race/ethnicity, risk of past noise exposure, or comorbid condition?
4. a. What is the efficacy of interventions for screen-detected hearing loss in improving health outcomes in adults age 50 years or older?
  b. Does the efficacy of interventions for screen-detected hearing loss differ for subpopulations defined by age, sex, race/ethnicity, risk of past noise exposure, or comorbid condition?
5. a. What are the harms of interventions for screen-detected hearing loss in adults age 50 years or older?
  b. Do the harms of interventions for screen-detected hearing loss differ for subpopulations defined by age, sex, race/ethnicity, risk of past noise exposure, or comorbid condition?

Figure 1 Analytic Framework

Figure 1 is an Analytic Framework and depicts the update review’s key questions (KQs) within the context of the eligible populations, screenings/interventions, comparisons, outcomes, timing, and settings. On the left, the population of interest is specified as asymptomatic adults age 50 years or older. Moving from left to right, the figure illustrates the overarching question: Does screening for hearing loss in asymptomatic older adults improve health outcomes (i.e., improve quality of life and function or reduce depression, cognitive impairment, falls, and social isolation) (KQ1)? The figure depicts the pathway from screening to detection of hearing loss to illustrate the second KQ: What is the accuracy of primary care–relevant screening tests for identifying previously undiagnosed hearing loss in adults age 50 years or older (KQ2)? Screening for hearing loss may result in harms, which is addressed by KQ3. The figure also illustrates the fourth KQ: What are the benefits of interventions on health outcomes in asymptomatic, screen-detected older adults with hearing loss (KQ4)? Health outcomes of interest include quality of life, function, depression, cognitive impairment, falls, and social isolation. Finally, treatment may also result in harms, which is addressed by KQ5.

In addition to addressing the KQs, this review also looked for evidence related to three contextual questions that focused on whether adherence to hearing aid use improves health outcomes in adults with screen-detected hearing loss, the effect of interventions to improve hearing aid adherence on health outcomes, and potential barriers to obtaining hearing aids and reasons for low uptake in adults prescribed hearing aids. These contextual questions were not a part of our systematic review. They are intended to provide additional background information. Literature addressing these questions is summarized in Appendix A.

## Data Sources and Searches

We searched PubMed/MEDLINE, the Cochrane Library, and Embase for English-language articles published through January 17, 2020. Medical Subject Headings were used as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. Complete search terms and limits are detailed in Appendix B1. Targeted searches for unpublished literature were conducted by searching ClinicalTrials.gov. To supplement electronic searches, reference lists of pertinent articles, studies suggested by reviewers, and comments received during public commenting periods were reviewed. Studies suggested by peer reviewers or public comment respondents were also be reviewed and, if appropriate, incorporated into the final review. The same inclusion and exclusion criteria were used to determine if the new citations should be incorporated into the review. Since January 17, 2020, ongoing surveillance was conducted through article alerts and targeted searches of journals to identify major studies published in the interim that might affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on November 20, 2020, and two studies of screening test accuracy meeting eligibility criteria were identified. One evaluated the HHIE-S and single-question screening,^60^ and the second evaluated a tablet-based pure tone screening test and a words-in-noise (WIN) test.^61^ Findings were similar to those reported by other studies of similar screening tests included in this review and did not change conclusions or the strength of evidence. All literature search results were managed using EndNote^TM^ version 9.2 (Thomson Reuters, New York, NY).

## Study Selection

Inclusion and exclusion criteria for populations, interventions, comparators, outcomes, settings, and study designs were developed with input from the USPSTF (Appendix B2). For all KQs, English-language studies of adults age 50 years or older conducted in settings generalizable to primary care, including nursing homes, and in countries categorized as “very high” on the United Nations Human Development Index were included.^62^ The age criterion was chosen because of a higher prevalence of age-related hearing loss in those over age 50 (compared with younger adults) and is consistent with the prior review for the USPSTF. Studies focused on adults with comorbid dementia were excluded because hearing testing is often recommended for adults with cognitive dysfunction.

For KQs 1 and 3 (direct evidence of benefits and harms of screening), controlled clinical trials or cohort studies enrolling adults with asymptomatic or undetected hearing loss comparing screening with no screening were eligible. For KQ 2 (accuracy of hearing loss screening tests), cohort or cross-sectional studies of asymptomatic or unselected older adults comparing one or more screening tests with diagnostic pure-tone audiometry were included. For KQs 1 through 3, eligible screening tests included those used, available, or feasible for use in primary care settings (Appendix A Table 3). Studies evaluating tests not feasible for screening in primary care settings (e.g., the 25-item Hearing Handicap Inventory for the Elderly), serial screening tests, and tests primarily used to distinguish between sensorineural and conductive hearing loss (e.g., the Rinne and Weber tests) were excluded.

For KQs on benefits (KQ 4) and harms (KQ 5) of amplification, controlled clinical trials and cohort studies of adults with screen-detected or newly detected sensorineural hearing loss were included. Studies of adults with conductive hearing loss, congenital hearing loss, sudden hearing loss, hearing loss caused by recent noise, and comorbid dementia were excluded. Eligible studies compared amplification using any type of hearing aid, personal assistive listening devices, or personal sound amplification device (with or without additional education or counseling) with a no-amplification control group (no treatment, wait-list, or placebo amplification device). Studies assessing nutritional pharmaceuticals, hearing rehabilitation alone (without amplification), and cochlear implants were excluded. Eligible outcomes for KQs on the benefit of screening and treatment (KQs 1 and 4) include measures of hearing-related quality of life or function, general health–related quality of life and function, depression, cognitive impairment, falls, and social isolation.

Two investigators independently reviewed titles and abstracts; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. The full texts were then independently reviewed by two investigators to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus. Covidence systematic review software was used to assign and track literature review decisions.^63^

## Quality Assessment and Data Abstraction

Two reviewers independently assessed each study’s methodological quality. Disagreements in study quality ratings were resolved through discussion or with an independent assessment from a third senior investigator. For randomized, controlled trials (RCTs), the most recent versions of the Cochrane Risk of Bias Tool (RoB 2.0) available for parallel^64^ and crossover trials were used.^65^ It assessed the following risk-of-bias domains: bias arising from selection or randomization, bias due to missing outcome data, bias due to departures from intended interventions, bias from measurement of outcomes, and bias from selective reporting of results. For nonrandomized controlled intervention studies, Cochrane’s ROBINS-I tool was used.^66^ For studies of diagnostic test accuracy, the QUADAS-2 instrument was used.^67^ Our risk-of-bias assessments using these instruments were translated into an overall study quality rating of good, fair, or poor using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B Table 3). Only studies rated as having good or fair quality were included. For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. A second team member reviewed all data extractions for completeness and accuracy.

## Data Synthesis and Analysis

Findings for each KQ were summarized in tabular and narrative format. The overall strength of the evidence for each KQ was assessed as high, moderate, low, or insufficient based on the overall quality of the studies, consistency of results between studies, precision of findings, risk of reporting bias, and limitations of the body of evidence, using methods developed for the USPSTF (and the EPC program).^68^ Additionally, the applicability of the findings to U.S. primary care populations and settings was assessed. Discrepancies were resolved through consensus discussion.

To determine whether meta-analyses were appropriate, the clinical heterogeneity and methodological heterogeneity of the studies were assessed following established guidance.^69^ The populations, tests, treatments, comparators, outcomes, and study designs were assessed qualitatively, looking for similarities and differences. For KQ 2 (the only KQ with sufficient numbers of similar studies for quantitative syntheses), pooled sensitivities and specificities for screening tests were calculated using a hierarchical summary receiver operating characteristic curve analysis when at least four similar studies were available. Pooled results and synthesis of individual studies were synthesized by type of screening test, as well as severity of hearing loss (e.g., detection of mild vs. moderate hearing loss). For studies that reported on multiple definitions of hearing loss, estimates included in pooled analyses were chosen based on similarity in decibel level, frequencies included in pure-tone average (PTA), and laterality to other included studies. Separate models were developed for each type of screening test. The metandi program in Stata version 14 was used to conduct all quantitative analyses.^70^

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF website for public comment from November 11, 2018, to December 13, 2018. In response to comments, the following changes were made: (1) expanded the list of eligible health outcomes (KQ 4) to include social isolation and falls, (2) expanded the list of eligible harms of screening (KQ 3) to include overdiagnosis, (3) clarified that eligible screening tests (KQ 2) include smartphone and other newer technology, and (4) clarified that eligible interventions could have multiple components (e.g., amplification and brief counseling related to hearing loss). The final version of the research plan was posted on the USPSTF website on February 14, 2019. A draft report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and subsequently addressed in revisions of this report when appropriate. The draft was also posted for public comment from September 8, 2020, to October 5, 2020. All comments were reviewed and considered in finalizing this report; minor revisions were made to the background and discussion sections based on reviewer suggestions, but no substantial changes to the conclusions were implemented.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and members of the USPSTF participated in developing the scope of work and reviewed draft reports, but the authors are solely responsible for the content.