# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to update its recommendation on screening for hearing loss in asymptomatic older adults. In 2012, the USPSTF concluded that evidence was insufficient to assess the balance of benefits and harms of screening for hearing loss in adults age 50 years or older. The purpose of this report is to systematically review the evidence on (1) benefits and harms of screening for hearing loss in adults 50 years or older, (2) accuracy of screening tools, and (3) benefits and harms of interventions for hearing loss that was screen detected or recently diagnosed for populations and settings relevant to primary care in the United States.

## Condition Definition

A person with normal hearing perceives sounds at frequencies between 20 and 20,000 Hz.^1^ Frequencies between 500 and 4,000 Hz are most important for speech processing. There is often discordance between objectively measured deficits in tonal perception at specific frequencies and intensity levels (audiometrically measured as decibels [dB] hearing level) and subjective perceptions of hearing problems.^2,^ ^3^ One study found that 20 percent of persons reporting hearing difficulty had normal hearing tests, while 6.2 percent of those not reporting difficulty had significant hearing loss.^4^ Hearing problems despite normal hearing thresholds could be caused by abnormal signal processing or sound discrimination. Because treatments for hearing loss are targeted at improving tonal perception by signal amplification, this review uses the term “hearing loss” to refer specifically to deficits found on objective testing (consistent with the prior review for the USPSTF).^5^

The standard objective test for hearing loss is the pure-tone audiogram, in which a person is tested on the ability to hear tones at a series of discrete frequencies, typically in the range of 250 to 8,000 Hz, at various decibel levels. There is no universally accepted definition for hearing loss. Reference criteria vary regarding the frequencies and intensity thresholds used to determine hearing loss and whether one or both ears are affected. Many studies and guidelines define mild hearing loss as the inability to detect frequencies associated with speech understanding under 25 dB and moderate hearing loss as the inability to detect those frequencies under 40 dB. Commonly used reference criteria to define audiometry thresholds indicative of hearing loss in studies assessing screening test accuracy include the Ventry and Weinstein criteria (>40 dB hearing loss at either 1,000 or 2,000 Hz in both ears or >40 dB hearing loss at 1,000 and 2,000 Hz in one ear),^3^ the speech frequency pure-tone average criteria (≥25 dB average hearing loss at 500, 1,000, and 2,000 Hz in the better ear),^6^ and the high-frequency pure-tone average criteria (≥25 dB average hearing loss at 1,000, 2,000, and 4,000 Hz in the better ear).^7^ Epidemiologic studies of adult hearing loss prevalence commonly use World Health Organization grades of impairment, defined as the better ear average for four frequencies (500, 1,000, 2,000, and 4,000 Hz) categorized by threshold level ranging from no impairment, slight impairment (26 to 40 dB hearing loss), moderate impairment (41 to 60 dB hearing loss), severe impairment (61 to 80 dB hearing loss), to profound impairment/deafness (81 dB hearing loss or greater).^8^

## Etiology and Natural History

Hearing loss may be classified into three types:^9^ (1) sensorineural, involving the inner ear or the auditory nerve; (2) conductive, involving any cause that in some way limits the amount of external sound from gaining access to the inner ear (e.g., cerumen impaction or middle ear fluid); and (3) mixed loss, which is a combination of sensorineural and conductive hearing loss. Within each category, there are multiple etiologies of hearing loss. Age-related hearing loss (or presbycusis) is the most common cause of hearing loss in older adults. It refers to a type of sensorineural hearing loss involving degeneration of the cells of the organ of Corti. The hearing loss associated with presbycusis is typically gradual, progressive, and bilateral and affects the higher frequencies before progressing to the lower frequencies.^10,^ ^11^

Hearing loss in older adults is multifactorial. In addition to age-related degeneration, other contributing factors include genetic factors, exposure to loud noises, exposure to ototoxic agents, history of middle ear infections, and presence of systemic diseases such as diabetes mellitus.^2,^ ^12–15^ In terms of progression, cohort studies measuring changes in pure-tone thresholds over time have documented an approximate 1 dB per year increase among adults age 50 years or older.^16,^ ^17^ Prospective observational studies of adults indicate that hearing impairment is associated with higher rates of incident disability and need for nursing care.^18^ Additional burden associated with untreated hearing loss is summarized below.

## Risk Factors

Aging is the greatest risk factor for both the incidence and progression of hearing loss, though other risk factors are also important. Besides older age, nonmodifiable risk factors include male sex,^19^ white race/ethnicity,^20^ and family history of hearing loss.^21^ Modifiable risk factors include societal, environmental, and health-related risk factors, such as lower educational level,^19^ exposure to loud noises, and inner ear infections; cardiovascular risk factors, such as smoking,^22,^ ^23^ diabetes,^24^ and hypertension, are all associated with hearing loss. While hearing loss is common among the general population, U.S. Service members and veterans are particularly at risk for hearing loss because of a combination of factors.^25^

## Prevalence and Burden

### Prevalence

Based on 2011-2012 data from the National Health and Nutrition Examination Survey (NHANES), the prevalence of unilateral and bilateral speech-frequency hearing impairment (defined by pure-tone average of thresholds across 500, 1,000, 2,000 and 4,000 Hz >25 dB hearing level) was 14.1 percent among adults (20 to 69 years of age) (n=3,831).^26^ Men had nearly twice the prevalence of hearing impairment as women (18.6% vs. 9.6%, respectively). The prevalence of speech frequency hearing loss increases significantly with age (Appendix A Table 1); prevalence was highest in adults age 60 to 69 years (39.3%). In addition to age, male sex (odds ratio [OR], 1.8 [95% confidence interval (CI), 1.1 to 3.0]), non-Hispanic white (OR, 2.3 [95% CI, 1.3 to 3.9]) and non-Hispanic Asian race/ethnicity (OR, 2.1 [95% CI, 1.1 to 4.2]), lower educational level (less than high school: OR, 4.2 [95% CI, 2.1 to 8.5]), and heavy use of firearms (≥1,000 rounds fired: OR, 1.8 [95% CI, 1.1 to 3.0]) were significant risk factors.^26^ The National Health Interview Survey (NHIS) also measures prevalence of hearing loss in adults 18 years or older based on self-reported difficulty hearing without the use of an assistive device.^27^ Estimates from the 2014-2016 NHIS data indicate that 15.9 percent of U.S. adults have hearing loss. The 2014 NHIS (N=35,697) also reports on prevalence by age category, and findings are consistent with estimates from NHANES data despite differences in measurement and age categorization.^28^ The prevalence of self-reported hearing loss was highest among adults 70 years or older (43.2%) compared with adults ages 40 to 69 years (19.0%) and 18 to 39 years (5.5%).

### Burden

A recent review in the Lancet reported that, in 2015, hearing loss was the fourth leading cause of years lived with disability globally.^29^ Untreated hearing loss can lead to significant burden for patients, family members, and society. Moderate to severe hearing loss in older adults is associated with significantly higher impairment in instrumental activities of daily living (IADLs), such as driving and managing medications or finances, as well as impairment in basic ADLs such as ambulation, bathing, and toileting.^18,^ ^30^ Individuals in the Epidemiology of Hearing Loss Study (n=2,688) with moderate to severe hearing loss were significantly more likely than individuals without hearing loss to have impaired ADLs and IADLs after controlling for age, sex, education, arthritis, other chronic diseases, and impaired visual acuity (ADL OR, 1.54 [95% CI, 1.06 to 2.24]; IADL OR, 1.54 [95% CI, 1.18 to 2.00]).^31^

Hearing loss is also associated with other adverse health and social outcomes. A nationally representative sample of 860 females between the age of 60 and 69 found that hearing loss is associated with increased odds of social isolation (OR, 3.49 per 25-dB hearing loss [95% CI, 1.91 to 6.39]).^32^ Multiple observational studies suggest an association between age-related hearing loss and cognitive decline or dementia, although the strength of association varies based on study design, cognitive measure, and other factors.^33^ One systematic review (k=36 studies included in pooled estimates; 20,264 participants) found a significant association between hearing loss and cognitive impairment (pooled OR, 1.22 [95% CI, 1.24 to 4.72]) as well as dementia (pooled OR, 1.28 [95% CI, 1.02 to 1.59]), but not for Alzheimer disease specifically (OR, 1.69 [95% CI, 0.72 to 4.0]) among prospective cohort studies.^33^ A cross-sectional study of 1,328 Blue Mountains Eye Study participants age 60 or older found depressive symptoms (assessed according to the mental health index) were significantly higher in participants with mild bilateral hearing loss (OR, 1.83 [95% CI, 1.18 to 2.83]) after multivariable adjustment, although participants with moderate to severe hearing loss (10.2%) did not have a higher likelihood of depressive symptoms than those with normal hearing (OR, 1.20 [95% CI, 0.66 to 2.17]).^34^

Some evidence suggests that hearing loss is also associated with increased hospitalizations and higher rates of mortality.^35–37^ One prospective observational study found that hearing loss was associated with a 20 percent increased mortality risk compared with normal hearing in models adjusting for multiple demographics and cardiovascular risk factors (hazard ratio, 1.20 [95% CI, 1.03 to 1.41]).^37^ However, other evidence suggests that the association is attenuated (not statistically significant) when adjusting for factors such as subclinical atherosclerosis and inflammatory markers.^38^ A 2017 systematic review (25 studies set in the United States) reported the economic costs of lost productivity associated with hearing loss varied from $1.8 to $194 billion, and direct medical costs of hearing loss ranged from $3.3 to $12.8 billion.^39,^ ^40^

## Rationale for Screening and Screening Strategies

Identifying hearing loss early, followed by appropriate interventions, may reduce the burden of functional decline associated with hearing loss. Although hearing loss is common in older adults, symptoms may be unrecognized because they can be relatively mild and slowly progressive. Older adults may also perceive hearing loss but not seek evaluation for it, or they may have difficulty recognizing or reporting hearing loss because of comorbid conditions, such as cognitive impairment. Screening could identify individuals with hearing loss who could benefit from hearing aids or other interventions to address hearing loss.

Screening tests that could be used in primary care range from direct questioning and clinician-administered tests to screening devices (Appendix A Table 3).^41,^ ^42^ Two common forms of direct questioning include a single-item question, “Do you have difficulty hearing?”^43^ and the 10-item Hearing Handicap Inventory for the Elderly-Screening (HHIE-S) questionnaire.^44^ Clinician-administered tests include the whispered voice test. Screening devices include use of a handheld audiometric device.^44^

## Interventions for Hearing Loss

The primary intervention for persons with a mild or moderate sensorineural hearing loss is use of hearing aids. Hearing loss is a chronic condition that cannot be cured; the use of hearing aids is intended to improve communication and function and prevent future morbidity associated with hearing-related disability. Hearing aids do not prevent or slow progression of hearing loss. Counseling and education about alternative communication techniques and use of assistive listening devices may also be recommended. For those with severe or profound hearing loss, cochlear implants are also a potential treatment option. Hearing aids amplify the sound reaching the middle or inner ear; the degree of amplification can be adjusted to suit the person’s degree of hearing loss. There is no standard of care or guideline consensus on when hearing aids are recommended. Published guidance by the Department of Veteran Affairs (VA) recommends hearing aids for thresholds of 40 dB hearing loss or greater at 500, 1,000, 2,000, 3,000, or 4,000 Hz or hearing thresholds of 26 dB at three of these frequencies, or speech recognition less than 94 percent.^45^ The UK National Institute for Health and Care Excellence guidelines on hearing loss state that provision of hearing aids should be based on need (e.g., hearing loss that affects communication, awareness of warning sounds and the environment, or appreciation of music) and not only on categories of “mild,” “moderate,” or “severe” based on pure-tone audiogram testing.^46^

Hearing aids can vary in design and in where they are positioned: in the canal, in the ear, behind the ear, and body worn. Although amplification improves the ability to detect sounds, other disabilities associated with sensorineural hearing loss such as sound processing, discrimination, and interpretation may be not improved. Persons with bilateral hearing loss may be offered one aid, fitted to one specific ear, or two aids fitted to both ears. Although most practitioners believe the use of two hearing aids is more effective for adults with bilateral symmetrical hearing loss, some evidence suggests that patients prefer to use only one hearing aid.^47,^ ^48^

In addition to traditional hearing aids, other amplification devices are available and may be recommended for persons with hearing loss, including assistive listening devices (ALDs) (for use with or without hearing aids) and personal sound amplification products (PSAPs). Auditory (or aural) rehabilitation is another potential treatment strategy that may be recommended in addition to amplification. ALDs and PSAPs include a range of over-the-counter devices that help amplify sound but are not currently labeled for individuals with hearing loss. This may change due to the 2017 Over-the-Counter (OTC) Hearing Aid Act intended to enable adults with perceived mild to moderate hearing loss to access OTC hearing aids and other devices marketed for hearing loss without being seen by a hearing care professional.^49^ The OTC Hearing Aid Act directed the Food and Drug Administration to establish criteria to regulate safety and labeling for OTC devices. Currently available ALDs vary in design and features, ranging from older models that include a remote transmitter connected to headphones to newer devices that include technology similar to hearing aids (Bluetooth-enabled, single-ear-worn devices that can be paired with a smartphone).^50^ Auditory rehabilitation includes a range of strategies aimed at improving hearing loss–induced deficits of function, activity, participation, and quality of life (QOL) through a combination of sensory management, instruction, perceptual training, and counseling.^51^ Components of auditory rehabilitation may include one or more of the following: active listening training, speech reading (e.g., education on reading facial expressions or lip contours of speakers), and communication enhancement.

## Recommendations of Other Organizations

The American Academy of Family Physicians references the current (2012) Task Force I Statement for hearing loss screening in asymptomatic adults age 50 years or older.^52^ The UK National Screening Committee does not recommend a national screening program for hearing loss in adults age 50 years or older.^53^ The Royal Australian College of General Practitioners recommends screening all adults age 65 years or older for hearing loss.^54^ The American Speech-Language-Hearing Association recommends that adults be screened by an audiologist once per decade and every 3 years after age 50 or more frequently in those with known exposures or risk factors associated with hearing loss.^55^ Other guidelines recommend screening only among those with specific risk factors, exposures, or symptoms (Appendix A Table 4).

## Clinical Practice in the United States

Screening rates for hearing loss in adult primary care are not clear; no recent estimates were found in the literature. Older surveys (from 2008) indicate that primary care clinicians generally agreed that hearing loss negatively affects their patients and reported screening rates were low.^56^ A 2008 study of 710 primary care physicians found that nearly three fourths (72.4%) reported screening only if they suspect a problem or patients complain about hearing and/or balance difficulties; few screen the elderly for hearing (3.4%), balance (5.7%), or disorders in both areas (10.3%) on a routine basis.^56^ Based on surveys from 2005-2008, clinicians’ self-reported barriers to screening and treatment of hearing loss include issues such as lack of knowledge, poor perception of audiology services, lack of time, and lack of reimbursement.^56–58^ A more recent review article (2016) highlighted the following barriers to obtaining hearing loss healthcare among older adults: lack of awareness of hearing loss manifestations (among providers and patients); confusion about options for accessing hearing-related care (e.g., primary care assessment, audiology evaluation, over-the-counter device); and decision making related to treatment options/preferences, cost, and device effectiveness (e.g., dissatisfaction or difficulties with hearing aids). These factors may limit rates of screening and treatment for hearing loss.^59^