# Appendix References

1 Hoffman HJ, Dobie RA, Losonczy KG, . Declining prevalence of hearing loss in US adults aged 20 to 69 years. JAMA Otolaryngol Head Neck Surg. 2017 Mar 1;143(3):274–85. doi: 10.1001/jamaoto.2016.3527. PMID: 27978564.27978564
2 Goman AM, Lin FR. Prevalence of Hearing Loss by Severity in the United States. Am J Public Health. 2016 Oct;106(10):1820–2. doi: 10.2105/ajph.2016.303299. PMID: 27552261.27552261
3 QuickStats: percentage of adults aged ≥18 years with any hearing loss,* by state - National Health Interview Survey,† 2014-2016. MMWR Morb Mortal Wkly Rep. 2017 Dec 22;66(50):1389. doi: 10.15585/mmwr.mm6650a7. PMID: 29267261.29267261
4 Zelaya CE, Lucas JW, Hoffman HJ. Self-reported hearing trouble in adults aged 18 and over: United States, 2014. NCHS Data Brief. 2015 Sep(214):1–8. PMID: 26462204.26462204
5 Clark K, Sowers M, Wallace RB, . The accuracy of self-reported hearing loss in women aged 60-85 years. Am J Epidemiol. 1991 Oct 1;134(7):704–8. PMID: 1951276.1951276
6 Academy of Doctors of Audiology. Preventive medicine and the need for routine hearing screening in adults. ; Unitron. 2474 MANL 09-12. n.d. https://www.audiologist.org/item/diabetes-hearing-loss-resources
7 American Academy of Family Physicians. Clinical preventive service recommendation: hearing. 2012. https://www.aafp.org/patient-care/clinical-recommendations/all/hearing.html. Accessed on August 16, 2018.
8 American Speech-Language-Hearing Association. Preferred practice patterns for the profession of audiology [preferred practice patterns]. Rockville, MD: ASHA National Office; 2006. www.asha.org/policy. Accessed on August 16, 2018.
9 Hearing Loss Association of America. Position paper: screening for hearing loss in primary health care settings. Bethesda, MD: Hearing Loss Association of America (HLAA); 2015. http://hearingloss.org
10 Ftouh S, Harrop-Griffiths K, Harker M, . Hearing loss in adults, assessment and management: summary of NICE guidance. BMJ. 2018 Jun 22;361:k2219. doi: 10.1136/bmj.k2219. PMID: 29934300.29934300
11 Royal Australian College of General Practitioners. Guidelines for preventive activities in general practice. East Melbourne, Victoria, Australia: Royal Australian College of General Practitioners; 2016.
12 UK National Screening Committee. UK NSC hearing loss in adults recommendation. Crown Copyright; 2016. https://legacyscreening.phe.org.uk/hearing-adult
13 Cruickshanks KJ, Wiley TL, Tweed TS, . Prevalence of hearing loss in older adults in Beaver Dam, Wisconsin. The Epidemiology of Hearing Loss Study. Am J Epidemiol. 1998 Nov 1;148(9):879–86. PMID: 9801018.9801018
14 Gates GA, Cooper JC, Jr., Kannel WB, . Hearing in the elderly: the Framingham cohort, 1983-1985. Part I. Basic audiometric test results. Ear Hear. 1990 Aug;11(4):247–56. PMID: 2210098.2210098
15 Mulrow CD, Aguilar C, Endicott JE, . Quality-of-life changes and hearing impairment. A randomized trial. Ann Intern Med. 1990 Aug 1;113(3):188–94. PMID: 2197909.2197909
16 Barker F, Mackenzie E, Elliott L, . Interventions to improve hearing aid use in adult auditory rehabilitation. Cochrane Database Syst Rev. 2016 Aug 18(8):Cd010342. doi: 10.1002/14651858.CD010342.pub3. PMID: 27537242.27537242
17 Collins MP, Liu CF, Taylor L, . Hearing aid effectiveness after aural rehabilitation: individual versus group trial results. J Rehabil Res Dev. 2013;50(4):585–98. doi: 10.1682/jrrd.2012.03.0049. PMID: 23934877.23934877
18 Willink A, Shoen C, Davis K. How Medicare could provide dental, vision, and hearing care for beneficiaries. Issue brief (Commonwealth Fund). 2018;2018:1–12. PMID: 29345890.29345890
19 Yueh B, Collins MP, Souza PE, . Long-term effectiveness of screening for hearing loss: the screening for auditory impairment--which hearing assessment test (SAI-WHAT) randomized trial. J Am Geriatr Soc. 2010 Mar;58(3):427–34. doi: 10.1111/j.1532-5415.2010.02738.x. PMID: 20398111.20398111
20 Yueh B, Collins MP, Souza PE, . Screening for Auditory Impairment-Which Hearing Assessment Test (SAI-WHAT): RCT design and baseline characteristics. Contemp Clin Trials. 2007 May;28(3):303–15. doi: 10.1016/j.cct.2006.08.008. PMID: 17030153.17030153
21 Yueh B, Souza PE, McDowell JA, . Randomized trial of amplification strategies. Arch Otolaryngol Head Neck Surg. 2001 Oct;127(10):1197–204. PMID: 11587599.11587599
22 Meyer C, Hickson L, Khan A, . Investigation of the actions taken by adults who failed a telephone-based hearing screen. Ear Hear. 2011 Nov–Dec;32(6):720–31. doi: 10.1097/AUD.0b013e318220d973. PMID: 21292333.21697715
23 Hickson L, Meyer C, Lovelock K, . Factors associated with success with hearing aids in older adults. Int J Audiol. 2014 Feb;53 Suppl 1:S18–27. doi: 10.3109/14992027.2013.860488. PMID: 24405446.24447233
24 Kaplan-Neeman R, Muchnik C, Hildesheimer M, . Hearing aid satisfaction and use in the advanced digital era. Laryngoscope. 2012 Sep;122(9):2029–36. doi: 10.1002/lary.23404. PMID: 22243971.22752928
25 Sciacca A, Meyer C, Ekberg K, . Exploring Audiologists’ Language and Hearing Aid Uptake in Initial Rehabilitation Appointments. Am J Audiol. 2017 Jun 13;26(2):110–8. doi: 10.1044/2017_aja-16-0061. PMID: 28492830.28538948
26 Solheim J, Hickson L. Hearing aid use in the elderly as measured by datalogging and self-report. Int J Audiol. 2017 Jul;56(7):472–9. doi: 10.1080/14992027.2017.1303201. PMID: 27761741.28332420
27 Korkmaz MH, Bayir O, Er S, . Satisfaction and compliance of adult patients using hearing aid and evaluation of factors affecting them. Eur Arch Otorhinolaryngol. 2016 Nov;273(11):3723–32. doi: 10.1007/s00405-016-4046-x. PMID: 26324881.27094053
28 Willink A, Reed NS, Lin FR. Access to hearing care services among older Medicare beneficiaries using hearing aids. Health Aff (Millwood). 2019 Jan;38(1):124–31. doi: 10.1377/hlthaff.2018.05217. PMID: 30615534.30615534
29 Jenstad L, Moon J. Systematic review of barriers and facilitators to hearing aid uptake in older adults. Audiology research. 2011;1(1):e25–e. doi: 10.4081/audiores.2011.e25. PMID: 26557310.26557310
30 Knudsen LV, Oberg M, Nielsen C, . Factors influencing help seeking, hearing aid uptake, hearing aid use and satisfaction with hearing aids: a review of the literature. Trends in amplification. 2010;14(3):127–54. doi: 10.1177/1084713810385712. PMID: 21109549.21109549
31 McCormack A, Fortnum H. Why do people fitted with hearing aids not wear them? Int J Audiol. 2013;52(5):360–8. doi: 10.3109/14992027.2013.769066. PMID: 23473329.23473329
32 Wallhagen MI. The stigma of hearing loss. The Gerontologist. 2010;50(1):66–75. doi: 10.1093/geront/gnp107. PMID: 19592638.19592638
33 Meyer C, Hickson L, Fletcher A. Identifying the barriers and facilitators to optimal hearing aid self-efficacy. Int J Audiol. 2014 Feb;53 Suppl 1:S28–37. doi: 10.3109/14992027.2013.832420. PMID: 24447233.24447235
34 Meyer C, Hickson L, Lovelock K, . An investigation of factors that influence help-seeking for hearing impairment in older adults. Int J Audiol. 2014 Feb;53 Suppl 1:S3–17. doi: 10.3109/14992027.2013.839888. PMID: 24891755.24405446
35 Meister H, Walger M, Brehmer D, . The relationship between pre-fitting expectations and willingness to use hearing aids. Int J Audiol. 2008;47(4):153–9. doi: 10.1080/14992020701843111. PMID: 18389410.18389410
36 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force procedure manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. https://www.uspreventiveservicestaskforce.org/Page/Name/procedure-manual. Accessed on December 17, 2019.
37 Mulrow CD, Tuley MR, Aguilar C. Sustained benefits of hearing aids. J Speech Hear Res. 1992 Dec;35(6):1402–5. doi: 10.1044/jshr.3506.1402. PMID: 1494282.1494282
38 Nieman CL, Marrone N, Mamo SK, . The Baltimore HEARS Pilot study: an affordable, accessible, community-delivered hearing care intervention. Gerontologist. 2017 Nov 10;57(6):1173–86. doi: 10.1093/geront/gnw153. PMID: 27927734.27927734
39 Humes LE, Rogers SE, Quigley TM, . The effects of service-delivery model and purchase price on hearing-aid outcomes in older adults: a randomized double-blind placebo-controlled clinical trial. Am J Audiol. 2017 Mar 1;26(1):53–79. doi: 10.1044/2017_aja-16-0111. PMID: 28122108.28252160
40 McArdle R, Chisolm TH, Abrams HB, . The WHO-DAS II: measuring outcomes of hearing aid intervention for adults. Trends in amplification. 2005;9(3):127–43.16244759
41 Chisolm TH, Abrams HB, McArdle R, . The WHO-DAS II: psychometric properties in the measurement of functional health status in adults with acquired hearing loss. Trends Amplif. 2005;9(3):111–26. doi: 10.1177/108471380500900303. PMID: 16244758.16244758
42 Jerger J, Chmiel R, Florin E, . Comparison of conventional amplification and an assistive listening device in elderly persons. Ear Hear. 1996 Dec;17(6):490–504. PMID: 8979037.8979037
43 Mahmoudi E, Basu T, Langa K, . Can Hearing Aids Delay Time to Diagnosis of Dementia, Depression, or Falls in Older Adults? J Am Geriatr Soc. 2019;67(11):2362–9. doi: 10.1111/jgs.16109. PMID: 31486068.31486068
44 Bienvenue GR, Michael PL, Chaffinch JC, . The AudioScope: a clinical tool for otoscopic and audiometric examination. Ear Hear. 1985 Sep–Oct;6(5):251–4. PMID: 4054439.4054439
45 Boatman DF, Miglioretti DL, Eberwein C, . How accurate are bedside hearing tests? Neurology. 2007 Apr 17;68(16):1311–4. doi: 10.1212/01.wnl.0000259524.08148.16. PMID: 17438223.17438223
46 Bonetti L, Simunjak B, Franic J. Validation of self-reported hearing loss among adult Croatians: the performance of the Hearing Self-Assessment Questionnaire against audiometric evaluation. Int J Audiol. 2018 Jan;57(1):1–9. doi: 10.1080/14992027.2017.1355073. PMID: 29946686.28749193
47 Ciurlia-Guy E, Cashman M, Lewsen B. Identifying hearing loss and hearing handicap among chronic care elderly people. Gerontologist. 1993 Oct;33(5):644–9. PMID: 8225009.8225009
48 Eekhof JA, de Bock GH, de Laat JA, . The whispered voice: the best test for screening for hearing impairment in general practice? Br J Gen Pract. 1996 Aug;46(409):473–4. PMID: 8949327.8949327
49 Frank T, Petersen DR. Accuracy of a 40 dB HL audioscope and audiometer screening for adults. Ear Hear. 1987 Jun;8(3):180–3. PMID: 3609515.3609515
50 Gates GA, Murphy M, Rees TS, . Screening for handicapping hearing loss in the elderly. J Fam Pract. 2003 Jan;52(1):56–62. PMID: 12540314.12540314
51 Hannula S, Bloigu R, Majamaa K, . Self-reported hearing problems among older adults: prevalence and comparison to measured hearing impairment. J Am Acad Audiol. 2011 Sep;22(8):550–9. doi: 10.3766/jaaa.22.8.7. PMID: 21828156.22031679
52 Kelly EA, Stadler ME, Nelson S, . Tablet-based Screening for Hearing Loss: Feasibility of Testing in Nonspecialty Locations. Otol Neurotol. 2018 Apr;39(4):410–6. doi: 10.1097/mao.0000000000001752. PMID: 30452748.29494473
53 Koike KJ, Hurst MK, Wetmore SJ. Correlation between the American Academy of Otolaryngology-Head and Neck Surgery five-minute hearing test and standard audiologic data. Otolaryngol Head Neck Surg. 1994 Nov;111(5):625–32. doi: 10.1177/019459989411100514. PMID: 7970802.7970802
54 Koole A, Nagtegaal AP, Homans NC, . Using the digits-in-noise test to estimate age-related hearing loss. Ear Hear. 2016 Sep–Oct;37(5):508–13. doi: 10.1097/aud.0000000000000282. PMID: 28555600.26871876
55 Lee AT, Tong MC, Yuen KC, . Hearing impairment and depressive symptoms in an older chinese population. J Otolaryngol Head Neck Surg. 2010 Oct;39(5):498–503. PMID: 20673695.20828511
56 Lichtenstein MJ, Bess FH, Logan SA. Validation of screening tools for identifying hearing-impaired elderly in primary care. JAMA. 1988 May 20;259(19):2875–8. PMID: 3285039.3285039
57 López-Torres Hidalgo J, Boix Gras C, Téllez Lapeira J, . Functional status of elderly people with hearing loss. Arch Gerontol Geriatr. 2009 Jul–Aug;49(1):88–92. doi: 10.1016/j.archger.2008.05.006. PMID: 18603314.18603314
58 Lycke M, Boterberg T, Martens E, . Implementation of uHear--an iOS-based application to screen for hearing loss--in older patients with cancer undergoing a comprehensive geriatric assessment. J Geriatr Oncol. 2016 Mar;7(2):126–33. doi: 10.1016/j.jgo.2016.01.008. PMID: 22628261.26924571
59 Lycke M, Debruyne PR, Lefebvre T, . The use of uHear to screen for hearing loss in older patients with cancer as part of a comprehensive geriatric assessment. Acta Clin Belg. 2018 Apr;73(2):132–8. doi: 10.1080/17843286.2017.1392070. PMID: 29063810.29063810
60 Macphee GJ, Crowther JA, McAlpine CH. A simple screening test for hearing impairment in elderly patients. Age Ageing. 1988 Sep;17(5):347–51. PMID: 3068972.3068972
61 McBride WS, Mulrow CD, Aguilar C, . Methods for screening for hearing loss in older adults. Am J Med Sci. 1994 Jan;307(1):40–2. PMID: 8291505.8291505
62 McShefferty D, Whitmer WM, Swan IRC, . The effect of experience on the sensitivity and specificity of the whispered voice test: a diagnostic accuracy study. BMJ Open. 2013;3(4). doi: 10.1136/bmjopen-2012-002394.
63 Nondahl DM, Cruickshanks KJ, Wiley TL, . Accuracy of self-reported hearing loss. Audiology. 1998 Sep–Oct;37(5):295–301. PMID: 9776206.9776206
64 Wiley TL, Cruickshanks KJ, Nondahl DM, . Self-reported hearing handicap and audiometric measures in older adults. J Am Acad Audiol. 2000 Feb;11(2):67–75. PMID: 10685672.10685672
65 Oosterloo BC, Homans NC, Baatenburg de Jong RJ, . Assessing hearing loss in older adults with a single question and person characteristics; Comparison with pure tone audiometry in the Rotterdam Study. PLoS One. 2020;15(1):e0228349–e. doi: 10.1371/journal.pone.0228349. PMID: 31986178.31986178
66 Rawool VW, Keihl JM. Perception of hearing status, communication, and hearing aids among socially active older individuals. J Otolaryngol Head Neck Surg. 2008 Feb;37(1):27–42. PMID: 18479626.18479626
67 Saliba J, Al-Reefi M, Carriere JS, . Accuracy of mobile-based audiometry in the evaluation of hearing loss in quiet and noisy environments. Otolaryngol Head Neck Surg. 2017 Apr;156(4):706–11. doi: 10.1177/0194599816683663. PMID: 27140227.28025906
68 Salonen J, Johansson R, Karjalainen S, . Relationship between self-reported hearing and measured hearing impairment in an elderly population in Finland. Int J Audiol. 2011;50(5):297–302. doi: 10.3109/14992027.2010.549517.21303228
69 Sever JC, Jr., Harry DA, Rittenhouse TS. Using a self-assessment questionnaire to identify probable hearing loss among older adults. Percept Mot Skills. 1989 Oct;69(2):511–4. doi: 10.2466/pms.1989.69.2.511. PMID: 2813000.2813000
70 Sindhusake D, Mitchell P, Smith W, . Validation of self-reported hearing loss. The Blue Mountains Hearing Study. Int J Epidemiol. 2001 Dec;30(6):1371–8. PMID: 11821349.11821349
71 Swan IR, Browning GG. The whispered voice as a screening test for hearing impairment. J R Coll Gen Pract. 1985 Apr;35(273):197. PMID: 3989786.3989786
72 Swanepoel de W, Eikelboom RH, Hunter ML, . Self-reported hearing loss in baby boomers from the Busselton Healthy Ageing Study: audiometric correspondence and predictive value. J Am Acad Audiol. 2013 Jun;24(6):514–21; quiz 29. doi: 10.3766/jaaa.24.6.7. PMID: 26924571.23886428
73 Tomioka K, Ikeda H, Hanaie K, . The Hearing Handicap Inventory for Elderly-Screening (HHIE-S) versus a single question: reliability, validity, and relations with quality of life measures in the elderly community, Japan. Qual Life Res. 2013;22(5):1151–9. doi: 10.1007/s11136-012-0235-2.22833152
74 Torre P, Moyer CJ, Haro NR. The accuracy of self-reported hearing loss in older Latino-American adults. Int J Audiol. 2006 Oct;45(10):559–62. doi: 10.1080/14992020600860935. PMID: 17062497.17062497
75 Ventry IM, Weinstein BE. Identification of elderly people with hearing problems. ASHA. 1983 Jul;25(7):37–42. PMID: 6626295.6626295
76 Voeks SK, Gallagher CM, Langer EH, . Self-reported hearing difficulty and audiometric thresholds in nursing home residents. J Fam Pract. 1993 Jan;36(1):54–8. PMID: 8419504.8419504
77 Watson CS, Kidd GR, Miller JD, . Telephone screening tests for functionally impaired hearing: current use in seven countries and development of a US version. J Am Acad Audiol. 2012 Nov–Dec;23(10):757–67. doi: 10.3766/jaaa.23.10.2. PMID: 22337493.23169193
78 Weinstein BE. Validity of a screening protocol for identifying elderly people with hearing problems. ASHA. 1986 May;28(5):41–5. PMID: 3718608.3718608
79 Williams-Sanchez V, McArdle RA, Wilson RH, . Validation of a screening test of auditory function using the telephone. J Am Acad Audiol. 2014 Nov–Dec;25(10):937–51. doi: 10.3766/jaaa.25.10.3. PMID: 25459311.25514447
80 Bradburn N. The structure of psychological well-being. Chicago: Aldine Publishing Company; 1969.
81 Cox R, Alexander G. The abbreviated profile of hearing aid benefit. Ear Hear. 1995;16:176–86.7789669
82 Derogatis L, Rickels K, Rock F. The SCL-90 and the MMDI: a step in the validation of a new self-report scale. Br J Psychiatry. 1976;128:280–9.1252693
83 American Psychological Association. Geriatric Depression Scale (GDS). Washington, DC: American Psychological Association; 2020. https://www.apa.org/pi/about/publications/caregivers/practice-settings/assessment/tools/geriatric-depression. Accessed on January 6, 2020.
84 Weinstein BE, Spitzer JB, Ventry IM. Test-retest reliability of the Hearing Handicap Inventory for the Elderly. Ear Hear. 1986 Oct;7(5):295–9. doi: 10.1097/00003446-198610000-00002. PMID: 3770324.3770324
85 Newman CW, Jacobson GP, Hug GA, . Practical method for quantifying hearing aid benefit in older adults. J Am Acad Audiol. 1991 Apr;2(2):70–5. PMID: 1768876.1768876
86 Tuley MR, Mulrow CD, Aguilar C, . A critical reevaluation of the Quantified Denver Scale of Communication Function. Ear Hear. 1990 Feb;11(1):56–61. doi: 10.1097/00003446-199002000-00011. PMID: 2307305.2307305
87 Linn MW, Linn BS. Self-evaluation of life function (self) scale: a short, comprehensive self-report of health for elderly adults. J Gerontol. 1984 Sep;39(5):603–12. doi: 10.1093/geronj/39.5.603. PMID: 6470452.6470452
88 Pfeiffer E. A short portable mental status questionnaire for the assessment of organic brain deficit in elderly patients. J Am Geriatr Soc. 1975 Oct;23(10):433–41. doi: 10.1111/j.1532-5415.1975.tb00927.x. PMID: 1159263.1159263