# Appendix G Description of Quality-of-Life or Function Measures

Outcome Measure | Description | Score Ranges and Interpretations | MCIDs
Affect Balance Scale^80^ | A 10-item scale that measures global feelings toward one’s present life by asking participants whether they have experienced 10 specific feelings (i.e., five positive and five negative feelings) in the past 2 weeks | Overall scores range from 0 to 5, with higher scores indicating more affect balance and, therefore, more desirable outcomes | Unclear
APHAB^81^ | A 24-item questionnaire in which individuals report the amount of trouble they have with communication or noises in various everyday situations | Scored from 0 to 100, with higher scores indicating greater dysfunction | Improvement on all 3 subscales by ≥5 points
Brief Symptom Inventory^82^ | A 58-item self-report inventory that measures emotional status by asking participants to determine the extent to which each item has been a “bother” in the past 2 weeks. Subscales of the scale address paranoia, irritability, anxiety, and interpersonal sensitivity. | Scored from 0 to 5, with higher scores indicating greater dysfunction | Unclear
Geriatric Depression Scale^83^ | A 15-item self-report scale that assesses depression in older adults | Scored from 0 to 15, with higher scores indicating greater dysfunction | None established yet
HHIE^84^ | A 25-item questionnaire that consists of 13 emotional and 12 social questions | Total scale scores range from 0 to 100, with higher scores indicating greater perceived difficulties | Change of ≥18.7 points
HHIE-S^85^ | A 10-item self-administered questionnaire and screening version of the full HHIE that assesses the degree of social and emotional handicap associated with hearing loss and requires about 2 minutes to complete | Subscale scores range from 0 to 40, with higher scores indicating greater perceived difficulties | Change of ≥9 points
QDS^86^ | A 25-item questionnaire that assesses perceived communication difficulties due to hearing loss | Scored from 0 to 100, with higher scores indicating greater dysfunction | Unclear
SELF^87^ | A 54-item global scale that assesses six areas of functioning: physical disability (13 items), social satisfaction (6 items), symptoms of aging (13 items), depression (11 items), self-esteem (7 items), and personal control (4 items). | Scored from 54 to 216, with higher scores indicating greater dysfunction | Unclear
Short Portable Mental Status Questionnaire^88^ | A 10-item clinician-administered scale that assesses cognitive function | Scored from 0 to 10, with higher scores indicating greater intellectual impairment | Unclear
WHO-DAS II^41^ | A 36-item instrument that provides 6 domain scores—communication, mobility, self-care, interpersonal; life activities at home and work, and participation—and a total score. In the WHO-DAS II, if respondents do not work, only 32 items are administered, and the life activities score is based only on participation in home-related activities. | Raw scores are transformed into standardized scores ranging from 0 to 100, with 0 indicating the best health state and 100 indicating the poorest health state | None established yet

Abbreviations: APHAB=Abbreviated Profile of Hearing Aid Benefit; HHIE(-S)=Hearing Handicap Inventory for the Elderly(-Screening version); MCID=minimal clinically important difference; QDS=Quantified Denver Scale of Communication Function; SELF=Self-Evaluation of Life Function; WHO-DAS II=World Health Organization’s Disability Assessment Scale II.