# Appendix F Pooled Analyses of Screening Test Accuracy (KQ 2)

Appendix F Figure 1 Summary Receiver Operating Characteristics Curve for Screening Test Accuracy of the Single Question for Detecting Mild Hearing Loss (20 to 25 dB)

Figure Notes: The 95 percent confidence region provides a visual estimate of the amount of variation around the pooled estimate that is due to sampling variation (i.e., chance). It is the region within which we expect the true pooled summary point to lie. It can be used to assess precision of the pooled estimate. The smaller the region, the more precise the estimate. In this figure, precision of the estimates for specificity is higher compared with the precision of the estimates for sensitivity. The 95 percent prediction region provides a visual estimate of the between-study variability that cannot be attributed to chance. It is the region within which we expect any future individual study estimate to lie. It can be used to assess the consistency of study findings. The larger the prediction region is within the SROC space and relative to the size of the confidence region, the more inconsistency (i.e., heterogeneity) is present.

Abbreviations: HSROC=hierarchical summary receiver operating characteristic; SROC=summary receiver operating characteristic.

“Appendix F Figure 1 is titled ““Summary Receiver Operating Characteristics Curve for Screening Test Accuracy of the Single Question for Detecting Mild Hearing Loss (20 to 25 dB)””. It is a summary receiver operating characteristics curve (ROC) designed to measure the accuracy of single question screening tests for detecting mild hearing loss (at 20 to 25 dB). In total, data from 10 studies appear as individual accuracy point estimates representing test sensitivity (values of 0 to 1 along the y-axis) and specificity (values of 0 to 1 along the x-axis). Each individual study’s accuracy estimate appears as an open circle with size directly proportional to the study’s sample size; in other words, the larger the sample size, the larger the study’s circle. All 10 studies’ point estimates were used to generate the ROC curve, as well as an overall pooled effect estimate of test accuracy. It corresponds to a pooled sensitivity of 66% (95% confidence interval or CI, 58% to 73%) and pooled specificity of 76% (95% CI, 68% to 83%). The pooled estimate appears as a summary point (a red box) along the ROC curve, and that point lies centered within a 95% confidence region, depicted as an orange dashed oval surrounding the estimate. About 5 of the 10 studies’ estimates lie within the confidence region. An even larger 95% prediction region – represented by a green dashed oval – encompasses the 95% confidence region, the pooled effect estimate described earlier, and all but one of the 10 studies’ study point estimates, which lies slightly outside the boundary of the prediction region and represents a substantially lower sensitivity than all other estimates.”

Appendix F Figure 2 Summary Receiver Operating Characteristics Curve for Screening Test Accuracy of the Single Question for Detecting Moderate Hearing Loss (at 35 to 40 dB)

Figure Notes: The 95 percent confidence region provides a visual estimate of the amount of variation around the pooled estimate that is due to sampling variation (i.e., chance). It is the region within which we expect the true pooled summary point to lie. It can be used to assess precision of the pooled estimate. The smaller the region, the more precise the estimate. In this figure, precision of the estimates for specificity is higher compared with the precision of the estimates for sensitivity. The 95 percent prediction region provides a visual estimate of the between-study variability that cannot be attributed to chance. It is the region within which we expect any future individual study estimate to lie. It can be used to assess the consistency of study findings. The larger the prediction region is within the SROC space and relative to the size of the confidence region, the more inconsistency (i.e., heterogeneity) is present.

Abbreviations: HSROC=hierarchical summary receiver operating characteristic; SROC=summary receiver operating characteristic.

Appendix F Figure 2 is titled “Summary Receiver Operating Characteristics Curve for Screening Test Accuracy of the Single Question for Detecting Moderate Hearing Loss (at 35 to 40 dB)”. It is a summary receiver operating characteristics curve (ROC) designed to measure the accuracy of single question screening tests for detecting moderate hearing loss (at 35 to 40 dB). In total, data from 6 studies appear as individual accuracy point estimates representing test sensitivity (values of 0 to 1 along the y-axis) and specificity (values of 0 to 1 along the x-axis). Each individual study’s accuracy estimate appears as an open circle with size directly proportional to the study’s sample size; in other words, the larger the sample size, the larger the study’s circle. All 6 studies’ point estimates were used to generate the ROC curve, as well as an overall pooled effect estimate of test accuracy. It corresponds to a pooled sensitivity of 80% (95% confidence interval or CI, 68% to 88%) and pooled specificity of 74% (95% CI, 59% to 85%). The pooled estimate appears as a summary point (a red box) along the ROC curve, and that point lies centered within a 95% confidence region, depicted as an orange dashed oval surrounding the estimate. About 4 of the 6 studies’ estimates lie within the confidence region. An even larger 95% prediction region – represented by a green dashed oval – encompasses the 95% confidence region, the pooled effect estimate described earlier, and all 6 studies’ study point estimates.

Appendix F Figure 3 Summary Receiver Operating Characteristics Curve for Screening Test Accuracy of HHIE-S for Detecting Moderate Hearing Loss (at 40 dB)

Figure Notes: The 95 percent confidence region provides a visual estimate of the amount of variation around the pooled estimate that is due to sampling variation (i.e., chance). It is the region within which we expect the true pooled summary point to lie. It can be used to assess precision of the pooled estimate. The smaller the region, the more precise the estimate. In this figure, precision of the estimates for specificity is higher compared with the precision of the estimates for sensitivity. The 95 percent prediction region provides a visual estimate of the between-study variability that cannot be attributed to chance. It is the region within which we expect any future individual study estimate to lie. It can be used to assess the consistency of study findings. The larger the prediction region is within the SROC space and relative to the size of the confidence region, the more inconsistency (i.e., heterogeneity) is present.

Abbreviations: HHIE-S=Hearing Handicap Inventory-Screening Version; HSROC=hierarchical summary receiver operating characteristic; SROC=summary receiver operating characteristic.

Appendix F Figure 3 is titled “Summary Receiver Operating Characteristics Curve for Screening Test Accuracy of HHIE-S for Detecting Moderate Hearing Loss (at 40 dB)”. It is a summary receiver operating characteristics curve (ROC) designed to measure the accuracy of a HHIE-S screening test cutoff score >8 for detecting moderate hearing loss (at 40 dB). In total, data from 5 studies appear as individual accuracy point estimates representing test sensitivity (values of 0 to 1 along the y-axis) and specificity (values of 0 to 1 along the x-axis). Each individual study’s accuracy estimate appears as an open circle with size directly proportional to the study’s sample size; in other words, the larger the sample size, the larger the study’s circle. All 5 studies’ point estimates were used to generate the ROC curve, as well as an overall pooled effect estimate of test accuracy. It corresponds to a pooled sensitivity of 68% (95% CI, 52% to 81%) and pooled specificity of 79% (95% CI, 69% to 86%). The pooled estimate appears as a summary point (a red box) along the ROC curve, and that point lies centered within a 95% confidence region, depicted as an orange dashed oval surrounding the estimate. All 5 studies’ estimates lie within the confidence region. An even larger 95% prediction region – represented by a green dashed oval – encompasses the 95% confidence region, the pooled effect estimate just described, and all 5 studies’ study point estimates.

Appendix F Figure 4 Summary Receiver Operating Characteristics Curve for Screening Test Accuracy of the Whispered Voice Test for Detecting Mild Hearing Loss (at 25 to 30 dB)

Figure Notes:

* The 95 percent confidence region provides a visual estimate of the amount of variation around the pooled estimate that is due to sampling variation (i.e., chance). It is the region within which we expect the true pooled summary point to lie. It can be used to assess precision of the pooled estimate. The smaller the region, the more precise the estimate. In this figure, precision of the estimates for specificity is higher compared with the precision of the estimates for sensitivity. The 95 percent prediction region provides a visual estimate of the between-study variability that cannot be attributed to chance. It is the region within which we expect any future individual study estimate to lie. It can be used to assess the consistency of study findings. The larger the prediction region is within the SROC space and relative to the size of the confidence region, the more inconsistency (i.e., heterogeneity) is present.

^†^ One study^62^ included in this analysis measured the accuracy of the whispered voice test when applied by older experienced or younger inexperienced providers. For this analysis, only the inexperienced provider data were used. A sensitivity analysis was also done using experienced provider data instead, and the pooled sensitivity was slightly higher (96% [95% CI, 55% to 100%]) and specificity was slightly lower (79% [95% CI, 68% to 87%]).

Abbreviations: CI=confidence interval; HSROC=hierarchical summary receiver operating characteristic; SROC=summary receiver operating characteristic.

Appendix F Figure 4 is titled “Summary Receiver Operating Characteristics Curve for Screening Test Accuracy of the Whispered Voice Test for Detecting Mild Hearing Loss (at 25 to 30 dB)”. It is a summary receiver operating characteristics curve (ROC) designed to measure the accuracy of the whispered voice test for detecting mild hearing loss (at 25 to 30 dB). In total, data from 5 studies appear as individual accuracy point estimates representing test sensitivity (values of 0 to 1 along the y-axis) and specificity (values of 0 to 1 along the x-axis). Each individual study’s accuracy estimate appears as an open circle with size directly proportional to the study’s sample size; in other words, the larger the sample size, the larger the study’s circle. All 5 studies’ point estimates were used to generate the ROC curve, as well as an overall pooled effect estimate of test accuracy. It corresponds to a pooled sensitivity of 94% (95% confidence interval or CI, 31% to 100%) and pooled specificity of 87% (95% CI, 82% to 90%). The pooled estimate appears as a summary point (a red box) along the ROC curve, and that point lies centered within a 95% confidence region, depicted as an orange dashed oval surrounding the estimate. Four of the 5 studies’ estimates lie within the confidence region. An even larger 95% prediction region – represented by a green dashed oval – encompasses the 95% confidence region, the pooled effect estimate just described, and all but one of the 5 studies’ study point estimates, which lies slightly outside the boundary of the prediction region and represents a lower sensitivity but higher specificity than all other estimates.