# Appendix E Additional Evidence Tables of Screening Test Accuracy

Appendix E Table 1 Detailed Evidence Tables of Single-Question Test Accuracy

Appendix E Table 2 Detailed Evidence Tables of Questionnaire Screening Accuracy (KQ 2)

Appendix E Table 3 Detailed Evidence Tables of Clinical Test Screening Accuracy (KQ 2)

Appendix E Table 4 Detailed Evidence Tables of Handheld or Mobile-based Device Screening Accuracy (KQ 2)