# Appendix D Assessments of Study Quality

Appendix D Table 1 Quality Assessment of Parallel Randomized, Controlled Trials (KQs 1 and 4), Part 1

First Author, Year; Trial Name Outcome of Interest | 1.1. Random allocation conceal-ment? | 1.2. Allocation sequence concealed until participants enrolled and assigned to intervention? | 1.3. Baseline differences suggesting a problem with randomi-zation process? | ROB due to Randomi-zation Process | Comments on Randomization Process | 2.1. Participants aware of assigned intervention during trial? | 2.2. Carers and people delivering interventions aware of participant assignments? | 2.3. If Y/PY/NI to 2.2, deviations from intended intervention because of experimental context? | 2.4. If Y/PY to 2.3, deviations from intended intervention balanced between group? | 2.5. If N/PN/NI to 2.4, deviations likely to have affected outcome?
Mulrow, 1990;^15^ Mulrow, 1992^37^; QOL and function | Y | Y | PN | Low | | Y | PY | NI | NA | NA
Yueh, 2001^21^; Hearing-related QOL | Y | Y | PN | Some concerns | Participants were randomized separately based on whether they had hearing loss that was considered service-connected (randomized to a standard aid vs. programmable aid) or nonservice connected (randomized to no-amplification or assistive listening device); samples in all 4 groups were small (n=14-16). Compared with the control group, the assistive listening device group had a higher HHIE score. Participants in the hearing aid groups were older and had slightly higher HHIE scores than the control group. | Y | Y | PN | NA | NA
Nieman, 2016^38^; Hearing-related function, QOL | Y | NI | PN | Some concerns | Small sample (n=15); minor differences between groups at baseline unlikely related to randomization process. Delayed treatment group was slightly older than intervention group (72 vs. 70 years). | Y | Y | NI | NA | NA
Humes, 2017^39^; Hearing-related function, QOL | Y | Y | N | Low | | PN | PN | NA | NA | NA
McArdle, 2005;^40^ Chisolm, 2005^41^; Disability, hearing-related function | NI | NI | PN | Some concerns | Randomization and allocation sequences not described; few baseline characteristics reported. Participants were similar in terms of baseline scores on hearing outcome assessments. | Y | Y | NI | NA | NA
Yueh, 2010;^19^ Yueh, 2007^20^; SAI-WHAT Hearing-related QOL | PY | Y | N | Low | | Y | Y | PY | PN | PY

Abbreviations: HHIE=Hearing Handicap Inventory for the Elderly; KQ=key question; n=number of participants; N=no; NA=not applicable; NI=no information; PN=probably no; PY=probably yes; QOL=quality of life; ROB=risk of bias; SAI-WHAT=Screening for Auditory Impairment – Which Hearing Assessment Test; vs.=versus; Y=yes.

Appendix D Table 2 Quality Assessment of Parallel Randomized, Controlled Trials (KQs 1 and 4), Part 2

First Author, Year; Trial Name Outcome of Interest | 2.6. Appropriate analysis used to estimate effect of intervention assignment? | 2.7. If N/PN/NI to 2.6, potential for substantial impact (on result) of failure to analyze participant in group to which randomized? | ROB due to deviation from intended intervention? | Comments on Deviation from Intended Intervention | 3.1. Outcome data available for all (or nearly all) participants? | 3.2. If N/PN/NI to 3.1, evidence of bias by missing outcome data? | 3.3. If N/PN to 3.2, could missingness in outcome depend on true value? | 3.4. If Y/PY/NI to 3.3, likely that missingness in outcome depended on true value? | ROB due to Missing Outcome Data | Comments on Missing Outcome Data Bias
Mulrow, 1990;^15^ Mulrow, 1992^37^; QOL and function | Y | NA | Some concerns | Participants were not blinded to intervention assignment; carers and people delivering the interventions were likely aware of participants’ assigned intervention during the trial. | Y | NA | NA | NA | Low
Yueh, 2001^21^; Hearing-related QOL | Y | NA | Some concerns | Lack of blinding may have introduced bias; knowledge of hearing loss status in control group may have led participants to expect difficulties in hearing-related function. | Y (5% were not included) | NA | NA | NA | Low
Nieman, 2016^38^; Hearing-related function, QOL | Y | NA | Some concerns | Lack of blinding and repeat assessment of hearing-related function and QOL may have led to expectation of worsening function among control group. | Y | NA | NA | NA | Low
Humes, 2017^39^; Hearing-related function, QOL | Y | NA | Low | | PY (5% excluded because of problems with intervention) (ear/health problems, could not use HA) | NA | NA | NA | Low
McArdle, 2005;^40^ Chisolm, 2005^41^; Disability, hearing-related function | PY | NA | Some concerns | No blinding. Unclear whether assignment to intervention or delayed treatment may have affected participant response on disability and hearing handicap assessments. | Y (approximately 5% attrition; however, ITT analyses imputed missing data) | NA | NA | NA | Low
Yueh, 2010;^19^ Yueh, 2007^20^; SAI-WHAT Hearing-related QOL | Y | NA | Some concerns | Bias towards null hypothesis | N | PN | PY | PN | Some concerns | High attrition (approxi-mately 23% for hearing-related function); no differential attrition.

Abbreviations: HA=hearing aid; ITT=intent-to-treat; KQ=key question; n=number of participants; N=no; NA=not applicable; NI=no information; PN=probably no; PY=probably yes; QOL=quality of life; ROB=risk of bias; SAI-WHAT=Screening for Auditory Impairment – Which Hearing Assessment Test; vs.=versus; Y=yes.

Appendix D Table 3 Quality Assessment of Parallel Randomized, Controlled Trials (KQs 1 and 4), Part 3

First Author, Year; Trial Name Outcome of Interest | 4.1. Inappropriate method of measuring outcome? | 4.2. Outcome ascertainment /measurement different between groups? | 4.3. If N/PN/NI to 4.1 and 4.2, outcome assessors aware of intervention received by participants? | 4.4. If Y/PY/NI to 4.3, outcome assessment influenced by knowledge of intervention received? | 4.5. If Y/PY/NI to 4.4, likely that outcome assessment influenced by knowledge of intervention received? | ROB due to Outcome Measurement | Comments on Outcome Measurement
Mulrow, 1990;^15^ Mulrow, 1992^37^; QOL and function | N | PN | PY | PN | NA | Low
Yueh, 2001^21^; Hearing-related QOL | N | PN | Y | PY | PN | Some concerns | Lack of blinding may have influenced outcome assessment.
Nieman, 2016^38^; Hearing-related function, QOL | N | PN | Y | PY | PN | Some concerns | Lack of blinding may have influenced assessment of outcomes.
Humes, 2017^39^; Hearing-related function, QOL | PN | PN | PN | NA | NA | Some concerns | For some followup and outcome assessments, procedures differed between intervention and placebo devices.
McArdle, 2005;^40^ Chisolm, 2005^41^; Disability, hearing-related function | PN | PN | Y | PN | NA | Some concerns | Knowledge of intervention status may have influenced ascertainment of outcomes.
Yueh, 2010;^19^ Yueh, 2007^20^; SAI-WHAT Hearing-related QOL | N (unclear if outcome assessors were masked) | N | NI | PY | PN | Some concerns | Study not powered to detect a difference in function and also failed to meet recruitment target to detect a significant difference in the primary outcome (hearing aid adherence).

Abbreviations: KQ=key question; N=no; NA=not applicable; NI=no information; PN=probably no; PY=probably yes; QOL=quality of life; ROB=risk of bias; SAI-WHAT=Screening for Auditory Impairment – Which Hearing Assessment Test; Y=yes.

Appendix D Table 4 Quality Assessment of Parallel Randomized, Controlled Trials (KQs 1 and 4), Part 4

First Author, Year; Trial Name Outcome of Interest | 5.1. Were data producing results of interest analyzed according to prespecified plan finalized before unblinded outcome data available for analysis? | 5.2. Numerical result being assessed likely to have been selected, on basis of results, from multiple outcome measurements? | 5.3. Numerical result being assessed likely to have been selected, on basis of results, from multiple analyses of data? | ROB due to Selection of Reported Result | Comments on Selection of Reported Result
Mulrow, 1990;^15^ Mulrow, 1992^37^; QOL and function | Y | PN | PN | Low
Yueh, 2001^21^; Hearing-related QOL | PY | PN | PN | Low
Nieman, 2016^38^; Hearing-related function, QOL | PY | PN | PN | Low
Humes, 2017^39^; Hearing-related function, QOL | PY | NI | NI | Some concerns | Unclear whether numerical results assessed may have been selected on the basis of results from multiple outcome measurements or multiple analyses of the data.
McArdle, 2005;^40^ Chisolm, 2005^41^; Disability, hearing-related function | NI | NI | NI | Some concerns | No information on whether outcomes assessed were prespecified, including specific outcome measurements or whether multiple analyses of data were conducted.
Yueh, 2010;^19^ Yueh, 2007^20^; SAI-WHAT Hearing-related QOL | Y | PN | PN | Low

Abbreviations: KQ=key question; NI=no information; PN=probably no; PY=probably yes; QOL=quality of life; ROB=risk of bias; SAI-WHAT=Screening for Auditory Impairment – Which Hearing Assessment Test; Y=yes.

Appendix D Table 5 Quality Assessment of Parallel Randomized, Controlled Trials (KQs 1 and 4): Domain Rating Summary and Overall Rating

First Author, Year; Trial Name Outcome of Interest | Randomization Process Domain | Deviations from Intended Interventions Domain | Missing Outcome Data Domain | Outcome Measurement Domain | Selection of Reported Result Domain | Overall ROB | Comments
Mulrow, 1990;^15^ Mulrow, 1992^37^; QOL and function | Low | Some concerns | Low | Low | Low | Some concerns | Participants were not blinded. Carers and outcome assessors were likely aware of intervention assignment during the trial.
Yueh, 2001^21^; Hearing-related QOL | Some concerns | Some concerns | Low | Some concerns | Low | Some concerns | Potential for selection bias because of minor differences between groups at baseline. Lack of blinding may have influenced outcome assessment.
Nieman, 2016^38^; Hearing-related function, QOL | Some concerns | Some concerns | Low | Some concerns | Low | Some concerns | Allocation concealment not described; however minor baseline difference between groups likely because of small sample size (n=15). Lack of blinding may have influenced measurement of outcomes.
Humes, 2017^39^; Hearing-related function, QOL | Low | Low | Low | Some concerns | Some concerns | Some concerns | For certain followup and outcome assessments, procedures differed between intervention and placebo devices. Unclear whether numerical results assessed may have been selected on the basis of results from multiple outcome measurements or multiple analyses of the data.
McArdle, 2005;^40^ Chisolm, 2005^41^; Disability, hearing-related function | Some concerns | Some concerns | Low | Some concerns | Some concerns | Some concerns | Randomization and allocation sequences not described; few baseline characteristics reported. Participants similar in terms of baseline scores on hearing outcome assessments. Lack of blinding may have affected participant response on disability and hearing handicap assessments. Knowledge of intervention status may have influenced ascertainment of outcomes.
Yueh, 2010;^19^ Yueh, 2007^20^; SAI-WHAT Hearing-related QOL | Low | Some concerns | Some concerns | Some concerns | Low | Some concerns | Study aims to compare screening with usual care; however, baseline assessment (prior to randomization) included an assessment of self-perceived HL. Control group and those who screened negative for HL were provided with a number for the audiology clinic if they wanted further assessment. High overall attrition for hearing related function is a potential source of bias; although there was no differential attrition, it is possible that participants with worse function were less likely to respond to the survey. In addition to high attrition, study was not powered to detect a difference in function and also failed to meet recruitment target to detect a significant difference in the primary outcome (hearing aid adherence).

Abbreviations: HL=hearing loss; KQ=key question; n=number of participants; QOL=quality of life; ROB=risk of bias; SAI-WHAT=Screening for Auditory Impairment – Which Hearing Assessment Test; Y=yes.

Appendix D Table 6 Quality Assessment of Crossover Randomized, Controlled Trials (KQs 1 and 4), Part 1

First Author, Year; Trial Name Outcome of Interest | 1.1. Random allocation concealment? | 1.2. Allocation sequence concealed until participants enrolled and assigned to interventions? | 1.3. Baseline differences suggesting a problem with randomization process? | 1.4. Roughly equal proportion of participant allocated to each group? | 1.5. If N/PN/NI to 1.4, are period effects included in analysis? | ROB due to Randomi-zation Process | Comments on Randomization Process | 2.1. Participants aware of assigned intervention during each period of trial? | 2.2. Carers and people delivering interventions aware of participant assignments during each period of trial? | 2.3. If Y/PY/NI to 2.1 or 2.2, deviations from intended interventions beyond what would be expected in usual practice?
Jerger, 1996^42^; NA; QOL and function | NI | NI | NI | NI | NA | Some concerns | Randomization procedures not described. | Y | PY | NI

Abbreviations: KQ=key question; N=no; NA=not applicable; NI=no information; NR=not reported; PN=probably no; PY=probably yes; QOL=quality of life; ROB=risk of bias; Y=yes.

Appendix D Table 7 Quality Assessment of Crossover Randomized, Controlled Trials (KQs 1 and 4), Part 2

First Author, Year; Trial Name Outcome of Interest | 2.4. If Y/PY to 2.3, deviations from intended interventions unbalanced between groups and likely to have affected outcome? | 2.5. Sufficient time for any carryover effects to disappear before outcome assessment in second period? | ROB due to deviation from intended interven-tion? | Comments on Deviation from Intended Intervention | 3.1. Outcome data available for all (or nearly all) participants? | 3.2. If N/PN/NI to 3.1, proportions of (and reasons for) missing outcome data similar across interventions? | 3.3. If N/PN to 3.1, evidence that results were robust to presence of missing outcome data? | ROB due to Missing Outcome Data | Comments on Missing Outcome Data Bias
Jerger, 1996^42^; NA; QOL and function | NA | PN | Some concerns | Unclear whether there was imbalance in participant variables at the start of the first crossover period; no wash-out period between each 6-week outcome assessment and intervention assignment. | PY | NA | NA | Low

Abbreviations: KQ=key question; N=no; NA=not applicable; NI=no information; NR=not reported; PN=probably no; PY=probably yes; QOL=quality of life; ROB=risk of bias; vs.=versus; Y=yes.

Appendix D Table 8 Quality Assessment of Crossover Randomized, Controlled Trials (KQs 1 and 4), Part 3

First Author, Year; Trial Name Outcome of Interest | 4.1. Outcome assessors aware of intervention received by participants? | 4.2. If Y/PY/NI to 4.1, likely that outcome assessment influenced by knowledge of intervention received? | ROB due to Outcome Measurement | Comments on Outcome Measurement
Jerger, 1996^42^; NA; QOL and function | Y | PN | Some concerns | No statistical adjustments were made for potential imbalances in baseline characteristics, nor was it clear if the investigators had any reason to suspect a need for adjusted analyses of study outcomes.

Abbreviations: KQ=key question; NA=not applicable; NI=no information; PN=probably no; PY=probably yes; QOL=quality of life; ROB=risk of bias; Y=yes.

Appendix D Table 9 Quality Assessment of Crossover Randomized, Controlled Trials (KQs 1 and 4), Part 4

First Author, Year; Trial Name Outcome of Interest | 5.1. Reported outcome data likely to have been selected, on basis of results, from multiple outcome measurements within outcome domain? | 5.2. Reported outcome data likely to have been selected, on basis of results, from multiple analyses of data? | 5.3. Reported outcome data likely to have been selected, on basis of results, from outcome of statistical test for carryover? | ROB due to Selection of Reported Result | Comments on Selection of Reported Result
Jerger, 1996^42^; NA; QOL and function | NI | NI | PY | Some concerns | Reporting on statistical analysis, including how the investigators chose their statistical approach, is unclear. Authors note that they used a “within-subjects” (subject-by-condition) analysis of variance for each outcome.

Abbreviations: KQ=key question; NA=not applicable; NI=no information; PY=probably yes; QOL=quality of life; ROB=risk of bias.

Appendix D Table 10 Quality Assessment of Crossover Randomized, Controlled Trials (KQs 1 and 4): Domain Rating Summary and Overall Rating

First Author, Year; Trial Name Outcome of Interest | Randomization Process Domain | Deviations from Intended Interventions Domain | Missing Outcome Data Domain | Outcome Measurement Domain | Selection of Reported Result Domain | Overall ROB | Comments
Jerger, 1996^42^; NA; QOL and function | Some concerns | Some concerns | Low | Some concerns | Some concerns | Some concerns | Authors note that subjects were randomly allocated to the intervention and control arms but do not comment on baseline differences at the start of the crossover. No wash-out period between crossover to new amplification device or control. Reporting on statistical analysis, including how the investigators chose their statistical approach, is unclear.

Abbreviations: KQ=key question; NA=not applicable; QOL=quality of life; ROB=risk of bias.

Appendix D Table 11 Quality Assessment of Controlled Cohort Studies (KQs 1 and 4), Part 1

First Author, Year; Trial Name Outcome of Interest | Bias due to confounding? | Comments | Bias in selection of participants into the study? | Comments | Bias in classification of intervention? | Comments
Mahmoudi, 2019^43^; NA; Health outcomes | High | Participants selected from claims data based on diagnosis of HL and use vs. non-use of HAs. Those using HAs had lower rates of various comorbidities that are also associated with adverse health outcomes. Groups may have also differed by other (unmeasured) factors associated with higher rates of HL and poor health outcomes (e.g., socioeconomic status, education, past noise exposure). | High | Study used claims and diagnostic codes to define HL and use of HAs. Participants who have true HL, but no official diagnoses would not have been included; participants may also have had a HL diagnosis entered before undergoing diagnostic evaluation with audiometry. | High | Intervention classification was defined based only on HA procedure codes. Participants may have obtained HAs but not used them; some may have obtained OTC hearing amplification in the non-user group. Severity of HL was also not defined; some “non-users” may not have met criteria for prescription HAs.

Abbreviations: HA=hearing aid; HL=hearing loss; NA=not applicable; OTC=over-the-counter.

Appendix D Table 12 Quality Assessment of Controlled Cohort Studies (KQs 1 and 4), Part 2

First Author, Year; Trial Name Outcome of Interest | Bias due to deviation from intended intervention (assignment to the intervention)? | Bias due to missing data? | Bias in measurement of outcomes? | Comments | Bias in selection of reported result? | Overall Rating | Comments
Mahmoudi, 2019^43^; NA; Health outcomes | No Information | Low | Medium | Authors measured incident dementia, anxiety, depression, and injurious fall rates by limiting data to participants with no diagnosis claims for these conditions one year prior to a HL diagnosis. Diagnostic codes may not have fully captured people who were free of these conditions before receiving an HL diagnosis. | Low | Poor | High risk of confounding (measured and unmeasured), selection bias, intervention classification bias, and measurement bias.

Abbreviations: HL=hearing loss; NA=not applicable.

Appendix D Table 13 Quality Assessment of Screening Test Accuracy Studies (KQ 2), Part 1

First Author, Year; Index Test | Consecutive or random sample of patients used? | Case control design avoided? | Did the study avoid inappropriate exclusions? | Bias due to patient selection? | Comments about Patient Selection | Test and reference standard results interpreted independently (blinded)? | If a threshold was used, was it pre-specified? | Bias due to index test?
Bienvenue, 1985^44^; AudioScope | Unclear | Yes | Unclear | Unclear | Little is known about how patients were selected. | Yes | Yes | Low
Boatman, 2007^45^; Finger rub test | Yes | Yes | Yes | Low | | Yes | Yes | Low
Boatman, 2007^45^; Single question (“Do you think you have difficulty hearing?”) | Yes | Yes | Yes | Low | | Yes | NA | Low
Boatman, 2007^45^; Watch tick test | Yes | Yes | Yes | Low | | Yes | Yes | Low
Boatman, 2007^45^; WVT | Yes | Yes | Yes | Low | | Yes | Yes | Low
Bonetti, 2018^46^; HSAQ | Yes | Yes | No | Low | | Yes | No | Unclear
Ciurlia-Guy, 1993^47^; AudioScope | Yes | Yes | Yes | Low | | Yes | Yes | Low
Clark, 1991^5^; Single question (“Would you say that you have any difficulty hearing?”) | Unclear | Yes | Yes | Unclear | Women were enrolled from two communities in rural Iowa; no details about patient selection provided. Of women participating in larger observational study of bone density, 94% of sample completed the hearing assessment. | Unclear | Yes | Unclear
Eekhof, 1996^48^; AudioScope | Yes | Yes | Yes | Low | | Unclear | Yes | Unclear
Eekhof, 1996^48^; WVT at 2 feet | Yes | Yes | Yes | Low | | Unclear | Yes | Unclear
Frank, 1987^49^; AudioScope | Yes | Yes | Yes | Unclear | Unclear if the sample included patients with dementia because there was no screening for it (30 participants could not follow instructions). | Yes | Yes | Unclear
Frank, 1987^49^; PTA screening with portable audiometer | Yes | Yes | Yes | Unclear | Unclear if the sample included patients with dementia because there was no screening for it (30 participants could not follow instructions). | Yes | Yes | Unclear
Gates, 2003^50^; HHIE-S | Yes | Yes | Yes | Low | | Unclear | Yes | Low
Gates, 2003^50^; Single question (“Do you have a hearing problem now?”) | Yes | Yes | Yes | Low | | Unclear | Yes | Low
Hannula, 2011^51^; Single question (“Q1. Do you have any difficulty with your hearing?”) | Yes | Yes | Yes | Low | | Unclear | NA | Unclear
Kelly, 2018^52^; EarTrumpet app | Unclear | Yes | Yes | Unclear | Patients included those coming to clinic for symptoms such as HL. Not clear how many reported HL symptoms or even had SNHL (vs. other types of HL). | Yes | Yes | Low
Kelly, 2018^52^; Audiogram Mobile app | Unclear | Yes | Yes | Unclear | Patients included those coming to clinic for symptoms such as HL. Not clear how many reported HL symptoms or even had SNHL (vs. other types of HL). | Yes | Yes | Low
Kelly, 2018^52^; Hearing Test with Audiogram app | Unclear | Yes | Yes | Unclear | Patients included those coming to clinic for symptoms such as HL. Not clear how many reported HL symptoms or even had SNHL (vs. other types of HL). | Yes | Yes | Low
Koike, 1994^53^; Five Minute Hearing Test | Unclear | Yes | Unclear | Unclear | No information about exclusion of patients during enrollment or whether sample was consecutively or randomly chosen | Yes | Yes | Low
Koole, 2016^54^; DIN test | Unclear | Yes | Yes | Unclear | Participants are from larger Rotterdam Study (population cohort from the Netherlands focused on risk factors for common diseases in the elderly); unclear how participants were selected or what proportion underwent hearing evaluation. | Unclear | Yes | Unclear
Lee, 2010^55^; Self-reported hearing loss | Unclear | Yes | Unclear | Unclear | Community-dwelling adults presenting for care in community centers Hong Kong were enrolled; those with MMSE score ≥18 (n=99) were excluded. Unclear what proportion of included sample may have had mild cognitive impairment. | Unclear | NA | Unclear
Lichtenstein, 1988^56^; AudioScope | Yes | Yes | Yes | Low | | Unclear | Yes | Unclear
Lichtenstein, 1988^56^; HHIE-S | Yes | Yes | Yes | Low | | Unclear | NA | Unclear
Lopez-Torres, 2009^57^; HHIE-S | Yes | Yes | Yes | Low | | Unclear | Unclear | Low
Lopez-Torres, 2009^57^; Single question (“How good do you think your hearing is?”) | Yes | Yes | Yes | Low | | Unclear | No | High
Lycke, 2016^58^; uHear | Yes | Yes | Yes | Low | | Unclear | NA | Unclear
Lycke, 2016^58^; WVT | Yes | Yes | Yes | Low | | Unclear | Yes | Unclear
Lycke, 2018^59^; uHear™ (iOS-based app) | Unclear | Yes | Yes | Unclear | Unclear patient selection process | Yes | Yes | Low
Macphee, 1988^60^; Conversational voice test at 2 feet | Yes | Yes | Yes | Unclear | 11/62 patients (22/124 ears, or 17.7%) were previous HA users. | Yes | Yes | Unclear
Macphee, 1988^60^; WVT at 2 feet | Yes | Yes | Yes | Unclear | 11/62 patients (22/124 ears, or 17.7%) were previous HA users. | Yes | Yes | Unclear
Macphee, 1988^60^; WVT at 6 inches | Yes | Yes | Yes | Unclear | 11/62 patients (22/124 ears, or 17.7%) were previous HA users. | Yes | Yes | Unclear
McBride, 1994^61^; AudioScope | Yes | Yes | Unclear | Unclear | Of those eligible, 7% declined to participate and 6% were excluded because of cerumen impaction or severe comorbid illness. Unclear what comorbid illnesses led to exclusions. | Yes | Yes | Low
McBride, 1994^61^; HHIE-S | Yes | Yes | Unclear | Unclear | Of those eligible, 7% declined to participate and 6% were excluded because of cerumen impaction or severe comorbid illness. Unclear what comorbid illnesses led to exclusions. | Yes | Yes | Low
McShefferty, 2013^62^; WVT | Unclear | Yes | Yes | Unclear | Whether the sample was consecutive or random is unknown | Yes | Unclear | Unclear
Nondahl, 1998,^63^ Wiley, 2000^64^; Single question (“Do you feel you have hearing loss?”) | Yes | Yes | Yes | Low | | Unclear | Yes | Unclear
Nondahl, 1998,^63^ Wiley, 2000^64^; HHIE-S | Yes | Yes | Yes | Low | | Unclear | Yes | Unclear
Nondahl, 1998,^63^ Wiley, 2000^64^; Single question (“In general, would you say your hearing is fair or poor?”) | Yes | Yes | Yes | Low | | Unclear | Yes | Unclear
Oosterloo, 2020^65^; Single question (“Do you have any difficulty with your hearing [without hearing aids]?”) | Yes | Yes | Yes | Low | | Yes | Yes | Low
Rawool, 2008^66^; Single question (“Do you think you have a hearing loss?”) | Yes | Yes | Yes | Low | | Unclear | Yes | Unclear
Saliba, 2017^67^; Mobile-based hearing test (iOS-based app) | Yes | Yes | Yes | Low | | Yes | Yes | Low
Salonen, 2011^68^; HHIE-S (Finnish) | No | Yes | Yes | Unclear | Participants selected based on initial of last name from a larger Finnish cohort study. | Yes | NA | Low
Salonen, 2011^68^; Single question (“Do you feel you have hearing loss?”) | No | Yes | Yes | Unclear | Participants selected based on initial of last name from a larger Finnish cohort study. | Yes | NA | Low
Sever, 1989^69^; HHIE-S | Yes | Yes | Yes | Low | | Yes | Yes | Low
Sindhusake, 2001^70^; Single question (“Do you feel you have hearing loss?) | Unclear | Yes | Yes | Unclear | 74.7% of eligible patients from the original Blue Mountains Eye Study cohort participated, and unclear how much their risk of HL differed from that of the 25.3% who declined to participate. | Unclear | Yes | Unclear
Sindhusake, 2001^70^; HHIE-S | Unclear | Yes | Yes | Unclear | 74.7% of eligible patients from the original Blue Mountains Eye Study cohort participated, and unclear how much their risk of HL differed from that of the 25.3% who declined to participate. | Unclear | Yes | Unclear
Swan, 1985^71^; WVT at 2 feet | Yes | Yes | Unclear | Unclear | No exclusion criteria listed. | Yes | Yes | Unclear
Swanepoel de, 2013^72^; Single question (“Do you have a hearing impairment? Yes or No”) | Yes | Yes | Yes | Low | | Unclear | Yes | Low
Tomioka, 2013^73^; HHIE-S | No | Yes | Unclear | Unclear | Insufficient information given about recruitment—whether consecutive or by some other method, those who could not walk independently were excluded. | Unclear | Yes | Unclear
Tomioka, 2013^73^; Single question (“Do you feel you have hearing loss?”) | Unclear | Yes | Unclear | Unclear | No description provided about patient sampling (whether consecutive or by some other method); those who could not walk independently were excluded. | Unclear | NA | Unclear
Torre, 2006^74^; Single question (“Do you feel you have a hearing loss?”) | Unclear | Yes | Yes | Unclear | Unclear what criteria were used by physicians and staff when referring patients for study. | Unclear | Yes | Unclear
Ventry, 1983^75^; HHIE-S | Unclear | Yes | Yes | Unclear | No description of whether the community sample (N=104) was selected consecutively. | Unclear | Yes | Unclear
Voeks, 1993^76^; Single question (“Do you have trouble hearing?”) | Yes | Yes | Yes | Unclear | Consecutive sample of participants being admitted to a VA skilled nursing facility were eligible. Those who refused or who were too ill to participate were excluded (no criteria for illness exclusions described). Authors included participants who may have been previously identified with HL but did not describe proportion with known or suspected HL. | Unclear | NA | Unclear
Watson, 2012^77^; Telephone DIN test | Unclear | Yes | Unclear | Unclear | No description of whether selection was consecutive or random. Participants were enrolled from one hearing clinic and from a newspaper advertisement. No description of inclusion/exclusion criteria. | Yes | No | High
Weinstein, 1986^78^; HHIE-S | Unclear | Yes | Unclear | Unclear | Some may have had prior audiological evaluation and had hearing aids; unclear recruitment information. | Yes | Yes | Low
Weinstein, 1986^78^; PTA screening: 40 dB HL at 1 kHz and 2 kHz in each ear | Unclear | Yes | Unclear | Unclear | Some may have had prior audiological evaluation and had hearing aids; unclear recruitment information. | Yes | Yes | Low
Williams-Sanchez, 2014^79^; U.S. NHT | No | Yes | Unclear | Unclear | Participant selection described as “convenience sampling,” but not clearly described; inclusion/exclusion criteria not described. | Unclear | Yes | Unclear
Williams-Sanchez, 2014^79^; WIN test | No | Yes | Unclear | Unclear | Participant selection described as “convenience sampling,” but not clearly described; inclusion/exclusion criteria not described. | Unclear | Yes | Unclear

Abbreviations: DIN=Digits-in-Noise; HA=hearing aid; HHIE-S=Hearing Handicap Inventory for the Elderly – Screening Version; HL=hearing loss; HSAQ=Hearing Self-Assessment Questionnaire; KQ=key question; MMSE=Mini-Mental State Examination; n=number of patients in a group; N=number of patients in overall sample; NA=not applicable; NHT=National Hearing Test; PTA=pure-tone audiometry; SNHL=sensorineural hearing loss; U.S.=United States; vs.=versus; VA=Veterans Administration; WIN=Words-in-Noise; WVT=whispered voice test.

Appendix D Table 14 Quality Assessment of Screening Test Accuracy Studies (KQ 2), Part 2

First Author, Year; Index Test | Comments about Index Test | Is the reference standard likely to correctly classify the target condition? | If the reference standard includes additional diagnostic criteria (other than pure-tone thresholds), were the reference standard results interpreted without knowledge of the results of the index test? | Bias due to the reference standard? | Comments about Reference Standard
Bienvenue, 1985^44^; AudioScope | | Yes | NA | Low
Boatman, 2007^45^; Finger rub test | | Yes | NA | Low
Boatman, 2007^45^; Single question (“Do you think you have difficulty hearing?”) | | Yes | NA | Low
Boatman, 2007^45^; Watch tick test | | Yes | NA | Low
Boatman, 2007^45^; WVT | | Yes | NA | Low
Bonetti, 2018^46^; HSAQ | Used ROC to determine cut point | Yes | NA | Low
Ciurlia-Guy, 1993^47^; AudioScope | | Yes | NA | Low
Clark, 1991^5^; Single question (“Would you say that you have any difficulty hearing?”) | Unclear whether index test and reference standard were interpreted independently | Yes | NA | Low
Eekhof, 1996^48^; AudioScope | Unclear if results were interpreted independently | Yes | NA | Low
Eekhof, 1996^48^; WVT at 2 feet | Index and reference testing were performed in an audiology clinic; unclear if results were interpreted independently. | Yes | NA | Low
Frank, 1987^49^; AudioScope | 40-dB HL version; they tested both ears, and if subjects did not hear one or more tones in one or each ear, they were immediately reinstructed and rescreened in the same manner as the original screening. This was done for both screening tests to minimize the incidence of false negatives. The results of the second screening were used for data analysis. | Yes | NA | Low
Frank, 1987^49^; PTA screening with portable audiometer | 40-dB HL version; they tested both ears, and if subjects did not hear one or more tones in one or each ear, they were immediately reinstructed and rescreened in the same manner as the original screening. This was done for both screening tests to minimize the incidence of false negatives. The results of the second screening were used for data analysis. | Yes | NA | Low
Gates, 2003^50^; HHIE-S | | Yes | NA | Low
Gates, 2003^50^; Single question (“Do you have a hearing problem now?”) | | Yes | NA | Low
Hannula, 2011^51^; Single question (“Q1. Do you have any difficulty with your hearing?”) | Sequence of testing was not specified. | Yes | NA | Low
Kelly, 2018^52^; EarTrumpet app | | Yes | NA | Low
Kelly, 2018^52^; Audiogram Mobile app | | Yes | NA | Low
Kelly, 2018^52^; Hearing Test with Audiogram app | | Yes | NA | Low
Koike, 1994^53^; Five Minute Hearing Test | | Yes | NA | Low
Koole, 2016^54^; DIN test | PTA was performed before DIN screening, but unclear if results from the two tests were interpreted independently. | Yes | NA | Low
Lee, 2010^55^; Self-reported hearing loss | No description of how self-perceived hearing loss was measured or whether it was asked independent of reference test results. | Yes | NA | Low
Lichtenstein, 1988^56^; AudioScope | Unclear if index and reference test were interpreted independently; index test also repeated by audiologist at time of referral (in addition to reference test). | Yes | NA | Low
Lichtenstein, 1988^56^; HHIE-S | Unclear if index and reference test were interpreted independently; index test also repeated by audiologist at time of referral (in addition to reference test). | Yes | NA | Low
Lopez-Torres, 2009^57^; HHIE-S | No description of whether index test interpreted independently. However, because the HHIE-S is patient reported, knowledge of reference test results is unlikely to influence interpretation. Also unclear whether the threshold of >10 was prespecified or chosen over >8 based on how results for the two cutoffs compared. | Yes | NA | Low
Lopez-Torres, 2009^57^; Single question (“How good do you think your hearing is?”) | No description of whether index test interpreted independently, however because the single-question screener is patient reported, knowledge of reference test results is unlikely to influence interpretation. Index test included 5 options to single question, and the article’s results do describe a threshold for positive responses. However, a response of “normal” was grouped with “poor” and “very poor” to define positive response, and no rationale is provided for this. | Yes | NA | Low
Lycke, 2016^58^; uHear | Unclear whether index test and reference standard were interpreted independently. The uHear™ app measures hearing at different frequencies (not threshold for positive/negative screening test used). | Yes | NA | Low
Lycke, 2016^58^; WVT | Unclear whether index test and reference standard were interpreted independently. A pass was given if patient could repeat all 3 numbers correctly at each level of loudness, or ≥50% success over 3 consecutive triplet sets. | Yes | NA | Low
Lycke, 2018^59^; uHear™ (iOS-based app) | | Yes | NA | Low
Macphee, 1988^60^; Conversational voice test at 2 feet | While criteria for passing are clear, it is not obvious that administration was uniform. | Yes | NA | Low
Macphee, 1988^60^; WVT at 2 feet | While criteria for passing are clear, it is not obvious that administration was uniform. | Yes | NA | Low
Macphee, 1988^60^; WVT at 6 inches | While criteria for passing are clear, it is not obvious that administration was uniform. | Yes | NA | Low
McBride, 1994^61^; AudioScope | | Yes | NA | Low
McBride, 1994^61^; HHIE-S | | Yes | NA | Low
McShefferty, 2013^62^; WVT | Unclear what the criteria are for fail. | Yes | NA | Low
Nondahl, 1998,^63^ Wiley, 2000^64^; Single question (“Do you feel you have hearing loss?”) | Unclear whether the screening question was conducted and interpreted independent of PTA. | Yes | NA | Low
Nondahl, 1998,^63^ Wiley, 2000^64^; HHIE-S | Unclear whether the HHIE-S was conducted and interpreted independent of PTA. | Yes | NA | Low
Nondahl, 1998,^63^ Wiley, 2000^64^; Single question (“In general, would you say your hearing is fair or poor?”) | Unclear whether the screening question was conducted and interpreted independent of PTA. | Yes | NA | Low
Oosterloo, 2020^65^; Single question (“Do you have any difficulty with your hearing [without hearing aids]?”) | | Yes | NA | Low
Rawool, 2008^66^; Single question (“Do you think you have a hearing loss?”) | Not clear whether the screening question was asked prior to PTA. | Yes | NA | Low
Saliba, 2017^67^; Mobile-based hearing test (iOS-based app) | | Yes | NA | Low
Salonen, 2011^68^; HHIE-S (Finnish) | | Yes | NA | Low
Salonen, 2011^68^; Single question (“Do you feel you have hearing loss?”) | | Yes | NA | Low
Sever, 1989^69^; HHIE-S | | Yes | NA | Low
Sindhusake, 2001^70^; Single question (“Do you feel you have hearing loss?) | Unclear whether index test and reference standard were interpreted independently. | Yes | NA | Low
Sindhusake, 2001^70^; HHIE-S | Unclear whether index test and reference standard were interpreted independently. | Yes | NA | Low
Swan, 1985^71^; WVT at 2 feet | Unclear how consistently the whisper test was applied in terms of who performed the test and the actual volume used. | Yes | NA | Low
Swanepoel de, 2013^72^; Single question (“Do you have a hearing impairment? Yes or No”) | | Yes | NA | Low
Tomioka, 2013^73^; HHIE-S | Unclear whether index test and reference test were interpreted independently. | Yes | NA | Low
Tomioka, 2013^73^; Single question (“Do you feel you have hearing loss?”) | Unclear whether index test and reference test were interpreted independently. | Yes | NA | Low
Torre, 2006^74^; Single question (“Do you feel you have a hearing loss?”) | Unclear whether the single screening question was administered before PTA testing. | Yes | NA | Low
Ventry, 1983^75^; HHIE-S | Unclear if index and reference test were interpreted independently. | Yes | NA | Low
Voeks, 1993^76^; Single question (“Do you have trouble hearing?”) | Unclear whether index test and reference test were interpreted independently. Screening question implies yes/no answer; however, authors report number of participants who replied with an equivocal response and count those as “yes” to the single-question screener in analyses. | Yes | NA | Low
Watson, 2012^77^; Telephone DIN test | Threshold for positive screening test was not prespecified; authors presented accuracy for two thresholds but did not provide a rationale for why these were chosen. Accuracy statistics for two thresholds reported vary substantially. | Yes | NA | Low
Weinstein, 1986^78^; HHIE-S | | Unclear | Yes | High | Reference standard was the audiologist’s recommendation for followup, and audiologists did not follow a protocol in terms of weighting the results of their PTA when making a recommendation.
Weinstein, 1986^78^; PTA screening: 40 dB HL at 1 kHz and 2 kHz in each ear | | Unclear | Yes | High | Reference standard was the audiologist’s recommendation for followup, and audiologists did not follow a protocol in terms of weighting the results of their PTA when making a recommendation.
Williams-Sanchez, 2014^79^; U.S. NHT | Unclear if results from the NHT and PTA were interpreted independently. | Yes | NA | Low
Williams-Sanchez, 2014^79^; WIN test | Unclear if results from the WIN test and PTA were interpreted independently. | Yes | NA | Low

Abbreviations: DIN=Digits-in-Noise; HHIE-S=Hearing Handicap Inventory for the Elderly – Screening Version; HL=hearing loss; HSAQ=Hearing Self-Assessment Questionnaire; KQ=key question; NA=not applicable; NHT=National Hearing Test; PTA=pure-tone audiometry; ROC=receiver operating characteristic; U.S.=United States; WIN=Words-in-Noise; WVT=whispered voice test.

Appendix D Table 15 Quality Assessment of Screening Test Accuracy Studies (KQ 2), Part 3

First Author, Year; Index Test | Appropriate interval between index test and reference standard? | Did all patients (or a random sample) receive the same reference standard? | All patients included in the analysis? | If “No” to the previous question, proportion of patients not included in the analysis? | Methods for calculating accuracy clearly reported and valid or sufficient data provided to allow calculation of accuracy measures (both sens and spec)? | Bias due to flow and timing? | Comments about Flow and Timing
Bienvenue, 1985^44^; AudioScope | Yes | Yes | Yes | | Yes | Low
Boatman, 2007^45^; Finger rub test | Yes | Yes | Yes | NA | Unclear | Unclear | Authors used modeling to account for within-subject correlation between ear measurements (screening tests were conducted in both ears); reference standard definition of HL was >25 dB at one or more frequencies in either ear. For PPV calculations, authors used prevalence of HL by age group from the literature (not prevalence in included sample).
Boatman, 2007^45^; Single question (“Do you think you have difficulty hearing?”) | Yes | Yes | Yes | NA | Unclear | Unclear | Authors used modeling to account for within-subject correlation between ear measurements (screening tests were conducted in both ears); reference standard definition of HL was >25 dB at one or more frequencies in either ear. For PPV calculations, authors used prevalence of HL by age group from the literature (not prevalence in included sample).
Boatman, 2007^45^; Watch tick test | Yes | Yes | Yes | NA | Unclear | Unclear | Authors used modeling to account for within-subject correlation between ear measurements (screening tests were conducted in both ears); reference standard definition of HL was >25 dB at one or more frequencies in either ear. For PPV calculations, authors used prevalence of HL by age group from the literature (not prevalence in included sample).
Boatman, 2007^45^; WVT | Yes | Yes | Yes | NA | Unclear | Unclear | Authors used modeling to account for within-subject correlation between ear measurements (screening tests were conducted in both ears); reference standard definition of HL was >25 dB at one or more frequencies in either ear. For PPV calculations, authors used prevalence of HL by age group from the literature (not prevalence in included sample).
Bonetti, 2018^46^; HSAQ | Yes | Yes | Yes | | Yes | Low
Ciurlia-Guy, 1993^47^; AudioScope | Yes | Yes | No | 4.8% | Unclear | Unclear | Numbers do not match when attempting to replicate authors’ calculated sensitivity and specificity outcomes, so it is necessary to accept their calculations of sensitivity and specificity as correct.
Clark, 1991^5^; Single question (“Would you say that you have any difficulty hearing?”) | Yes | Yes | Yes | NA | Yes | Low
Eekhof, 1996^48^; AudioScope | Yes | Yes | Yes | NA | Yes | Low
Eekhof, 1996^48^; WVT at 2 feet | Yes | Yes | Yes | NA | Yes | Low
Frank, 1987^49^; AudioScope | Yes | Yes | No | 10.8% ears (146/1,356) | Yes | Low
Frank, 1987^49^; PTA screening with portable audiometer | Yes | Yes | No | 10.8% ears (146/1,356) | Yes | Low
Gates, 2003^50^; HHIE-S | Yes | Yes | No | 25% (546/723); 8% (546/597) when accounting for those excluded because of known hearing aid use | No | High | Unclear how participants with a HHIE-S score of 9 were categorized in analyses; cutoff is defined as 0-8 vs. ≥10; risk of selection bias because of high attrition; however, the largest proportion excluded were those wearing hearing aids.
Gates, 2003^50^; Single question (“Do you have a hearing problem now?”) | Yes | Yes | No | 25% (546/723); 8% (546/597) when accounting for those excluded because of known hearing aid use | Yes | High | Risk of selection bias because of high attrition may introduce bias; however, the largest proportion excluded were those wearing hearing aids.
Hannula, 2011^51^; Single question (“Q1. Do you have any difficulty with your hearing?”) | Yes | Yes | Yes | | Yes | Low
Kelly, 2018^52^; EarTrumpet app | Yes | Yes | No | 7/114 (6.1%) of those enrolled overall | No | Unclear | Only Se and Sp were reported, but not the data needed to calculate those outcomes or other measures of test accuracy. Table 1 data do not agree with information in text. Study’s definition of HL not clearly defined in terms of ears or frequencies used.
Kelly, 2018^52^; Audiogram Mobile app | Yes | Yes | No | 7/114 (6.1%) of those enrolled overall | No | Unclear | Only Se and Sp were reported, but not the data needed to calculate those outcomes or other measures of test accuracy. Table 1 data do not agree with information in text. Study’s definition of HL not clearly defined in terms of ears or frequencies used.
Kelly, 2018^52^; Hearing Test with Audiogram app | Yes | Yes | No | 7/114 (6.1%) of those enrolled overall | No | Unclear | Only Se and Sp were reported, but not the data needed to calculate those outcomes or other measures of test accuracy. Table 1 data do not agree with information in text. Study’s definition of HL not clearly defined in terms of ears or frequencies used.
Koike, 1994^53^; Five Minute Hearing Test | Yes | Yes | Unclear | NR | Yes | Unclear | No information on how many failed the reference test and whether all were included in the analysis.
Koole, 2016^54^; DIN test | Yes | Yes | No | 7.8% patients (283/3,610) were excluded because of having an air and bone gap of ≥15 dB at the best ear, failing to complete the DIN test, and having an average SNR deviation of >3.7 dB (+2 SDs above the mean) | Yes | Unclear | Possible that participants may have experienced fatigue when completing the DIN screening test, according to the authors, but it “probably” did not play a major role in the test’s accuracy.
Lee, 2010^55^; Self-reported hearing loss | Yes | Yes | No | 6/1.019= 0.6% | Yes | Low
Lichtenstein, 1988^56^; AudioScope | Yes | Yes | No | 41% (126/304) of those screened and referred to the study did not keep their appointments for PTA retesting. Additionally, for patients who did complete PTA testing and were included in the final sample, data were missing for a range of 1.7% (3/178 for right ear at 500-2.000 Hz) to 3.9% (7/178 for left ear at 4.000 Hz) of patients. | Yes | High | Of those initially screened, only 41% followed up for reference standard testing; nonresponders had a slightly lower rate of HL identified via AudioScope screening (42% vs. 48%) and lower mean HHIE-S scores (7.6 vs. 10.0).
Lichtenstein, 1988^56^; HHIE-S | Yes | Yes | No | 41% (126/304) of those screened and referred to the study did not keep their appointments for PTA retesting. Additionally, for patients who did complete PTA testing and were included in the final sample, data were missing for a range of 1.7% (3/178 for right ear at 500-2.000 Hz) to 3.9% (7/178 for left ear at 4.000 Hz) of patients. | Yes | High | Of those initially screened, only 41% followed up for reference standard testing; nonresponders had a slightly lower rate of HL identified via AudioScope screening (42% vs. 48%) and lower mean HHIE-S scores (7.6 vs. 10.0).
Lopez-Torres, 2009^57^; HHIE-S | Yes | Yes | Unclear | | Yes | Unclear | Unclear if the number of participants assessed included all those who responded by mail or if some participants who were willing to participate were excluded because they were not able to be tested on a specific day, etc.
Lopez-Torres, 2009^57^; Single question (“How good do you think your hearing is?”) | Yes | Yes | Unclear | | Yes | Unclear | Unclear if the number of participants assessed included all those who responded by mail or if some participants who were willing to participate were excluded for some reason (e.g., because they were not able to be tested on a specific day).
Lycke, 2016^58^; uHear | Yes | Yes | No | 1 person (3%) withdrew; one additional person’s ear was excluded because of a known hearing condition. | Yes | Low
Lycke, 2016^58^; WVT | Yes | Yes | No | 1 person (3%) withdrew; one additional person’s ear was excluded because of a known hearing condition. | Yes | Low
Lycke, 2018^59^; uHear™ (iOS-based app) | Yes | Yes | Yes | | Yes | Low
Macphee, 1988^60^; Conversational voice test at 2 feet | Yes | Yes | Yes | NA | Yes | Low
Macphee, 1988^60^; WVT at 2 feet | Yes | Yes | Yes | NA | Yes | Low
Macphee, 1988^60^; WVT at 6 inches | Yes | Yes | Yes | NA | Yes | Low
McBride, 1994^61^; AudioScope | Yes | Yes | Yes | NA | Yes | Low
McBride, 1994^61^; HHIE-S | Yes | Yes | Yes | NA | Yes | Low
McShefferty, 2013^62^; WVT | Yes | Yes | Yes | | Yes | Low
Nondahl, 1998,^63^ Wiley, 2000^64^; Single question (“Do you feel you have hearing loss?”) | Unclear | Yes | No | 11% patients (411/3,753) | Yes | Unclear | Unclear if there was an appropriate interval between tests.
Nondahl, 1998,^63^ Wiley, 2000^64^; HHIE-S | Unclear | Yes | No | 7.5% patients (282/3,753) | Yes | Unclear | Unclear if there was an appropriate interval between tests.
Nondahl, 1998,^63^ Wiley, 2000^64^; Single question (“In general, would you say your hearing is fair or poor?”) | Unclear | Yes | No | 6.2% patients (231/3,753) | Yes | Unclear | Unclear if there was an appropriate interval between tests.
Oosterloo, 2020^65^; Single question (“Do you have any difficulty with your hearing [without hearing aids]?”) | Yes | Yes | Yes | | Yes | Low
Rawool, 2008^66^; Single question (“Do you think you have a hearing loss?”) | Yes | Yes | Yes | NA | Yes | Low
Saliba, 2017^67^; Mobile-based hearing test (iOS-based app) | Yes | Yes | Yes | | Yes | Low | Note that a single ear (1.5% of all 66 ears originally recruited) was excluded.
Salonen, 2011^68^; HHIE-S (Finnish) | Yes | Yes | No | Of those who responded to the questionnaire, 164/262 = 37% did not attend the hearing examination | Yes | High | High attrition (37% did not attend audiometry), a higher proportion of those who attended audiometry had an HHIE-S score >8 than nonattenders.
Salonen, 2011^68^; Single question (“Do you feel you have hearing loss?”) | Yes | Yes | No | Of those who responded to the questionnaire, 164/262 = 37% did not attend the hearing examination | Yes | High | Subjects with self-perceived hearing difficulty were more likely to respond to questionnaires and attend hearing exam than those without hearing problems.
Sever, 1989^69^; HHIE-S | Yes | Yes | Yes | NA | Yes | Low
Sindhusake, 2001^70^; Single question (“Do you feel you have hearing loss?) | Yes | Yes | No | 3.6% (72/1,879) with missing values | Yes | Low
Sindhusake, 2001^70^; HHIE-S | Yes | Yes | No | 9.8% (198/2,005) with missing responses | Yes | Low
Swan, 1985^71^; WVT at 2 feet | Yes | Yes | Yes | | Yes | Low
Swanepoel de, 2013^72^; Single question (“Do you have a hearing impairment? Yes or No”) | Yes | Yes | No | 6% (947/1,004) | Yes | Low
Tomioka, 2013^73^; HHIE-S | Yes | Yes | No | 1.7% (30/1,761) were excluded for incomplete information on demographic and hearing-related comorbidity | Unclear | Unclear | Number of individuals who failed reference test are missing, so independent checking of accuracy is not possible.
Tomioka, 2013^73^; Single question (“Do you feel you have hearing loss?”) | Yes | Yes | No | 1.7% (30/1,761) were excluded for incomplete information on demographic and hearing-related comorbidity | Unclear | Unclear | Number of participants who failed reference test is not described, so independent checking of accuracy is not possible.
Torre, 2006^74^; Single question (“Do you feel you have a hearing loss?”) | Yes | Yes | Yes | NA | Yes | Low
Ventry, 1983^75^; HHIE-S | Unclear | Yes | Unclear | NA | Yes | Unclear | Unclear how long the interval was between the questionnaire and PTA tests or if all patients were included in the analysis.
Voeks, 1993^76^; Single question (“Do you have trouble hearing?”) | Yes | Yes | No | 17.1% (41/239) excluded because of poor audiometric response reliability (defined as >5 dB difference in repeat measurement at 1,000 Hz after all other frequencies were tested) | Yes | Unclear | Relatively high proportion of participants excluded because of poor reliability on PTA (17%); no description of whether excluded participants with poor audiometric response were more likely to report trouble hearing. Reference standard was offered via sound-proof booth or room environment (via earphones) to accommodate those in a wheelchair; unclear if difference in setting may have affected test performance.
Watson, 2012^77^; Telephone DIN test | Yes | Yes | Yes | NA | Yes | Low
Weinstein, 1986^78^; HHIE-S | Unclear | Yes | Unclear | NR | Yes | Unclear | Unclear if there was an appropriate interval between tests.
Weinstein, 1986^78^; PTA screening: 40 dB HL at 1 kHz and 2 kHz in each ear | Unclear | Yes | Unclear | NR | Yes | Unclear | Unclear if there was an appropriate interval between tests.
Williams-Sanchez, 2014^79^; U.S. NHT | Yes | Yes | Unclear | NR | Yes | Unclear | No description of enrolled participants who declined to participate or who were excluded from analyses because of missing data.
Williams-Sanchez, 2014^79^; WIN test | Yes | Yes | Unclear | NR | Yes | Unclear | No description of enrolled participants who declined to participate or who were excluded from analyses because of missing data.

Abbreviations: DIN=Digits-in-Noise; HHIE-S=Hearing Handicap Inventory for the Elderly – Screening Version; HL=hearing loss; HSAQ=Hearing Self-Assessment Questionnaire; KQ=key question; NA=not applicable; NR=not reported; PPV=positive predictive value; PTA=pure-tone audiometry; NHT=National Hearing Test; SD=standard deviation; SNR=sound-to-noise ratio; Se or sens=sensitivity; Sp or spec=specificity; U.S.=United States; vs.=versus; WIN=Words-in-Noise; WVT=whispered voice test.

Appendix D Table 16 Quality Assessment of Screening Test Accuracy Studies (KQ 2): Domain Rating Summary and Overall Rating

First Author, Year; Index Test | Bias due to patient selection? | Bias due to index test? | Bias due to the reference standard? | Bias due to flow and timing? | Quality Rating | Rationale
Bienvenue, 1985^44^; AudioScope | Unclear | Low | Low | Low | Fair | Patient selection unclear
Boatman, 2007^45^; Finger rub test | Low | Low | Low | Unclear | Fair | Methods for calculating PPV and sens/spec unclear in terms of how logistic regression/modeling was used to adjust values.
Boatman, 2007^45^; Single question (“Do you think you have difficulty hearing?”) | Low | Low | Low | Unclear | Fair | Methods for calculating PPV and sens/spec unclear in terms of how logistic regression/modeling was used to adjust values.
Boatman, 2007^45^; Watch tick test | Low | Low | Low | Unclear | Fair | Methods for calculating PPV and sens/spec unclear in terms of how logistic regression/modeling was used to adjust values.
Boatman, 2007^45^; WVT | Low | Low | Low | Unclear | Fair | Methods for calculating PPV and sens/spec unclear in terms of how logistic regression/modeling was used to adjust values.
Bonetti, 2018^46^; HSAQ | Low | Unclear | Low | Low | Fair | Index test used ROC to determine cut point.
Ciurlia-Guy, 1993^47^; AudioScope | Low | Low | Low | Unclear | Fair | Flow and timing: unclear methods for accuracy.
Clark, 1991^5^; Single question (“Would you say that you have any difficulty hearing?”) | Unclear | Unclear | Low | Low | Fair | Unclear sampling strategy; no description of whether index and reference test were interpreted independently.
Eekhof, 1996^48^; AudioScope | Low | Unclear | Low | Low | Fair | Unclear whether index and reference test were interpreted independently.
Eekhof, 1996^48^; WVT at 2 feet | Low | Unclear | Low | Low | Fair | Unclear whether index and reference test were interpreted independently.
Frank, 1987^49^; AudioScope | Unclear | Unclear | Low | Low | Fair | Unclear ROB because of patient selection (no screening for dementia, even though 30 patients were excluded because they could not repeat back the screening instructions) and index test (investigators screened patients in a way that would reduce false-negative rates)
Frank, 1987^49^; PTA screening with portable audiometer | Unclear | Unclear | Low | Low | Fair | Unclear ROB because of patient selection (no screening for dementia, even though 30 patients were excluded because they could not repeat back the screening instructions) and index test (investigators screened patients in a way that would reduce false-negative rates)
Gates, 2003^50^; HHIE-S | Low | Low | Low | High | Fair | Unclear how participants with an HHIE-S score of 9 were categorized in analyses; cut-off defined as 0=8 vs. ≥10; risk of selection bias because of high attrition; however, the largest proportion excluded were those wearing hearing aids.
Gates, 2003^50^; Single question (“Do you have a hearing problem now?”) | Low | Low | Low | High | Fair | Risk of selection bias because of high attrition may introduce bias; however, the largest proportion excluded were those wearing hearing aids.
Hannula, 2011^51^; Single question (“Q1. Do you have any difficulty with your hearing?”) | Low | Unclear | Low | Low | Fair | Index test
Kelly, 2018^52^; EarTrumpet app | Unclear | Low | Low | Unclear | Fair | Unclear risk of bias due to patient selection (inclusion of some unknown number of patients with suspected HL and possibly HL that was not sensorineural) and flow and timing (no data provided to calculate any accuracy measures).
Kelly, 2018^52^; Audiogram Mobile app | Unclear | Low | Low | Unclear | Fair | Unclear risk of bias due to patient selection (inclusion of some unknown number of patients with suspected HL and possibly HL that was not sensorineural) and flow and timing (no data provided to calculate any accuracy measures).
Kelly, 2018^52^; Hearing Test with Audiogram app | Unclear | Low | Low | Unclear | Fair | Unclear risk of bias due to patient selection (inclusion of some unknown number of patients with suspected HL and possibly HL that was not sensorineural) and flow and timing (no data provided to calculate any accuracy measures).
Koike, 1994^53^; Five Minute Hearing Test | Unclear | Low | Low | Unclear | Fair | Unclear to what extent the study avoided inappropriate exclusions when enrolling patients or prior to analysis. This could be a lack of reporting issue, rather than a potential flaw in the study’s design.
Koole, 2016^54^; DIN test | Unclear | Unclear | Low | Unclear | Fair | Unclear whether their results were interpreted independently. Also, possible that participant fatigue reduced the accuracy of the DIN test because HL testing was part of a full day of testing for the Rotterdam Study.
Lee, 2010^55^; Self-reported hearing loss | Unclear | Unclear | Low | Low | Fair | Methods do not state how self-perceived HL was measured and assessed or whether it was asked independently of reference test results.
Lichtenstein, 1988^56^; AudioScope | Low | Unclear | Low | High | Fair | Potential for bias because of high attrition (41% screened followed up for reference standard testing); mean HHIE-S scores and proportion with HL identified via AudioScope were slightly higher among nonresponders than responders.
Lichtenstein, 1988^56^; HHIE-S | Low | Unclear | Low | High | Fair | Potential for bias because of high attrition (41% screened followed up for reference standard testing); mean HHIE-S scores and proportion with HL identified via AudioScope were slightly higher among nonresponders than responders.
Lopez-Torres, 2009^57^; HHIE-S | Low | Low | Low | Unclear | Fair | Unclear if the number of participants assessed included all those who responded by mail or if some participants who were willing to participate were excluded for some reason (e.g., because they were not able to be tested on a specific day). Also unclear if the threshold for the HHIE-S was prespecified or chosen based on the results.
Lopez-Torres, 2009^57^; Single question (“How good do you think your hearing is?”) | Low | High | Low | Unclear | Poor | High risk of bias because of how a positive result on the index test was defined. Specifically, a response of “normal” was grouped with “poor” and “very poor” to define positive responses, but the article does not provide a rationale for this. Also unclear if the number of participants assessed included all those who responded by mail or if some participants who were willing to participate were excluded for some reason (e.g., because they were not able to be tested on a specific day).
Lycke, 2016^58^; uHear | Low | Unclear | Low | Low | Fair | Unclear if uHear and PTA tests were interpreted independent of one another.
Lycke, 2016^58^; WVT | Low | Unclear | Low | Low | Fair | Unclear if WVT and PTA tests were interpreted independent of one another.
Lycke, 2018^59^; uHear™ (iOS-based app) | Unclear | Low | Low | Low | Fair | Unclear patient selection process. No description of the N of participants approached who declined to participate.
Macphee, 1988^60^; Conversational voice test at 2 feet | Unclear | Unclear | Low | Low | Fair | Unclear risk of patient selection bias (17.7% of patients were previous HA users) and also bias related to the index test because it was unclear if administration was uniform.
Macphee, 1988^60^; WVT at 2 feet | Unclear | Unclear | Low | Low | Fair | Unclear risk of patient selection bias (17.7% of patients were previous HA users) and also bias related to the index test because it was unclear if administration was uniform.
Macphee, 1988^60^; WVT at 6 inches | Unclear | Unclear | Low | Low | Fair | Unclear risk of patient selection bias (17.7% of patients were previous HA users) and also bias related to the index test because it was unclear if administration was uniform.
McBride, 1994^61^; AudioScope | Unclear | Low | Low | Low | Good
McBride, 1994^61^; HHIE-S | Unclear | Low | Low | Low | Good
McShefferty, 2013^62^; WVT | Unclear | Unclear | Low | Low | Fair | Patient selection and index test were unclear.
Nondahl, 1998,^63^ Wiley, 2000^64^; Single question (“Do you feel you have hearing loss?”) | Low | Unclear | Low | Unclear | Fair | Unclear whether the screening question was conducted and interpreted independent of PTA or if there was an appropriate interval between tests.
Nondahl, 1998,^63^ Wiley, 2000^64^; HHIE-S | Low | Unclear | Low | Unclear | Fair | Unclear whether the HHIE-S was conducted and interpreted independent of PTA or if there was an appropriate interval between tests.
Nondahl, 1998,^63^ Wiley, 2000^64^; Single question (“In general, would you say your hearing is fair or poor?”) | Low | Unclear | Low | Unclear | Fair | Unclear whether the screening question was conducted and interpreted independent of PTA or if there was an appropriate interval between tests.
Oosterloo, 2020^65^; Single question (“Do you have any difficulty with your hearing [without hearing aids]?”) | Low | Low | Low | Low | Good
Rawool, 2008^66^; Single question (“Do you think you have a hearing loss?”) | Low | Unclear | Low | Low | Good
Saliba, 2017^67^; Mobile-based hearing test (iOS-based app) | Low | Low | Low | Low | Good
Salonen, 2011^68^; HHIE-S (Finnish) | Unclear | Low | Low | High | Poor | Of those who responded to the initial questionnaire, 164/262=37% did not attend the hearing examination. Subjects with self-perceived hearing difficulty were more likely to respond to questionnaires and attend hearing exam than those without hearing problems.
Salonen, 2011^68^; Single question (“Do you feel you have hearing loss?”) | Unclear | Low | Low | High | Poor | Of those who responded to the initial questionnaire, 164/262=37% did not attend the hearing examination. Subjects with self-perceived hearing difficulty were more likely to respond to questionnaires and attend hearing exam than those without hearing problems.
Sever, 1989^69^; HHIE-S | Low | Low | Low | Low | Good
Sindhusake, 2001^70^; Single question (“Do you feel you have hearing loss?) | Unclear | Unclear | Low | Low | Fair | Unclear risk of selection bias because 26% of eligible patients did not participate, and unclear if index test and reference standard were interpreted independently.
Sindhusake, 2001^70^; HHIE-S | Unclear | Unclear | Low | Low | Fair | Unclear risk of selection bias because 26% of eligible patients did not participate, and unclear if index test and reference standard were interpreted independently.
Swan, 1985^71^; WVT at 2 feet | Unclear | Unclear | Low | Low | Fair | Unclear ROB because of index test; unclear how consistently the whisper test was applied in terms of who performed the test and the actual volume used.
Swanepoel de, 2013^72^; Single question (“Do you have a hearing impairment? Yes or No”) | Low | Low | Low | Low | Good
Tomioka, 2013^73^; HHIE-S | Unclear | Unclear | Low | Unclear | Fair | Patient selection, index test, flow, and timing are all unclear.
Tomioka, 2013^73^; Single question (“Do you feel you have hearing loss?”) | Unclear | Unclear | Low | Unclear | Fair | No description provided about patient sampling (whether consecutive or by some other method); those who could not walk independently were excluded. Unclear whether index and screening tests were interpreted independently.
Torre, 2006^74^; Single question (“Do you feel you have a hearing loss?”) | Unclear | Unclear | Low | Low | Fair | Unclear risk of patient selection bias because of lack of detail about criteria physicians and staff used when referring patients for study, and unclear if index test was administered before PTA testing.
Ventry, 1983^75^; HHIE-S | Unclear | Unclear | Low | Unclear | Fair | Selection of participants unclear; no description of whether index and reference tests were interpreted independently; unclear how long the interval was between the questionnaire and PTA tests; and unclear if all patients were included in the analysis.
Voeks, 1993^76^; Single question (“Do you have trouble hearing?”) | Unclear | Unclear | Low | Unclear | Fair | Relatively high proportion of participants excluded because of poor reliability on PTA (17%); no description of whether excluded participants with poor audiometric response were more likely to report trouble hearing. Risk of selection bias because of exclusion of participants with illness/comorbidity (not described in detail) and inclusion of some residents who likely had known hearing loss (proportion not described).
Watson, 2012^77^; Telephone DIN test | Unclear | High | Low | Low | Fair | No description of whether selection was consecutive or random. Threshold for positive screening test was not prespecified; authors presented accuracy for two thresholds but did not provide a rationale for why these were chosen. Accuracy statistics for two thresholds reported vary substantially.
Weinstein, 1986^78^; HHIE-S | Unclear | Low | High | Unclear | Poor | Potential ROB because of possible enrollment of patients with prior audiological evaluation and HA use, the reference standard’s subjective nature (audiologist’s recommendation for followup, which was informed by audiometry and information from patient interviews), and lack of clarity about how much time elapsed between screening visits and audiology exams.
Weinstein, 1986^78^; PTA screening: 40 dB HL at 1 kHz and 2 kHz in each ear | Unclear | Low | High | Unclear | Poor | Potential ROB because of possible enrollment of patients with prior audiological evaluation and HA use, the reference standard’s subjective nature (audiologist’s recommendation for followup, which was informed by audiometry and information from patient interviews), and lack of clarity about how much time elapsed between screening visits and audiology exams.
Williams-Sanchez, 2014^79^; U.S. NHT | Unclear | Unclear | Low | Unclear | Fair | Participant selection described as “convenience sampling” but not clearly described. No description of proportion of participants approached who declined to participate or whether some participants were excluded from analyses because of missing data. Unclear whether index and reference test were interpreted independently. No adjustments for the effect of screening location (VA clinic vs. home), given that NHT accuracy outcomes varied by location.
Williams-Sanchez, 2014^79^; WIN test | Unclear | Unclear | Low | Unclear | Fair | Participant selection “convenience sampling” but not clearly described; inclusion/exclusion criteria not described. No description of enrolled participants who declined to participate or who were excluded from analyses because of missing data. Unclear whether index and reference test were interpreted independently.

Abbreviations: DIN=Digits-in-Noise; HA=hearing aid; HHIE-S=Hearing Handicap Inventory for the Elderly – Screening Version; HL=hearing loss; HSAQ=Hearing Self-Assessment Questionnaire; KQ=key question; N=number; NHT= National Hearing Test; PPV=positive predictive value; PTA=pure-tone audiometry; ROB=risk of bias; ROC=receiver operating characteristic; sens=sensitivity; spec=specificity; U.S.=United States; VA=Veterans Administration; vs.=versus; WIN=Words-in-Noise; WVT=whispered voice test.