# Appendix C Excluded Studies

- X1: Ineligible population
- X2: Ineligible or no screening or treatment
- X3: Ineligible or no eligible outcome reported
- X4: Ineligible or no comparator
- X5: Ineligible setting
- X6: Ineligible study design
- X7: Ineligible publication type
- X8: Non-English
- X9: Ineligible country
- X10: Poor quality rating

1 Hearing Aids for Tinnitus with Hearing Loss (HUSH). International Standard Randomised Controlled Trial Number. 2018 PMID: CN-01905914. Exclusion Code: X3.
2 Hearing Impairment, Strategies, and Outcomes in Emergency Departments. ClinicalTrials.gov. 2018 PMID: CN-01661303. Exclusion Code: X3.
3 Academy of Doctors of Audiology. Preventive medicine and the need for routine hearing screening in adults; Unitron. 2474 MANL 09-12. n.d. https://www.audiologist.org/item/diabetes-hearing-loss-resources Exclusion Code: X7.
4 Adrait A, Perrot X, Nguyen MF, . Do hearing aids influence behavioral and psychological symptoms of dementia and quality of life in hearing impaired Alzheimer’s disease patients and their caregivers? J Alzheimers Dis. 2017;58(1):109–21. doi: 10.3233/jad-160792. PMID: 25811932. Exclusion Code: X1.28269769
5 Ahmed OH, Gallant SC, Ruiz R, . Validity of the hum test, a simple and reliable alternative to the Weber test. Ann Otol Rhinol Laryngol. 2018 Jun;127(6):402–5. doi: 10.1177/0003489418772860. PMID: 29490364. Exclusion Code: X1.29776326
6 Aiello CP, Lima, II, Ferrari DV. Validity and reliability of the hearing handicap inventory for adults. Braz J Otorhinolaryngol. 2011 Jul–Aug;77(4):432–8. PMID: 21521901. Exclusion Code: X3.21860968
7 Albu S, Chirtes F. Intratympanic dexamethasone plus melatonin versus melatonin only in the treatment of unilateral acute idiopathic tinnitus. Am J Otolaryngol. 2014 Sep–Oct;35(5):617–22. doi: 10.1016/j.amjoto.2014.06.009. PMID: 24770406. Exclusion Code: X2.25066140
8 Alcas O, Salazar MA. Complications of cochlear implant surgery: a ten-year experience in a referral hospital in Peru, 2006-2015. Cochlear Implants Int. 2016 Sep;17(5):238–42. doi: 10.1080/14670100.2016.1219480. PMID: 26632254. Exclusion Code: X2.27535059
9 Alexander TH, Harris JP, Nguyen QT, . Dose effect of intratympanic dexamethasone for idiopathic sudden sensorineural hearing loss: 24 mg/mL Is superior to 10 mg/mL. Otol Neurotol. 2015 Sep;36(8):1321–7. doi: 10.1097/mao.0000000000000834. PMID: 25583631. Exclusion Code: X2.26196209
10 Ali H, Hazrati O, Tobey EA, . Evaluation of adaptive dynamic range optimization in adverse listening conditions for cochlear implants. J Acoust Soc Am. 2014 Sep;136(3):El242. doi: 10.1121/1.4893334. PMID: 24907838. Exclusion Code: X1.25190428
11 Ambrosch P, Muller-Deile J, Aschendorff A, . European adult multi-centre HiRes(R) 120 study--an update on 65 subjects. Cochlear Implants Int. 2010 Jun;11 Suppl 1:406–11. doi: 10.1179/146701010x12671177204183. PMID: 21174276. Exclusion Code: X1.21756661
12 American Academy of Family Physicians. Clinical preventive service recommendation: hearing. 2012. https://www.aafp.org/patient-care/clinical-recommendations/all/hearing.html. Accessed August 16, 2018. Exclusion Code: X7.
13 Amieva H, Ouvrard C, Giulioli C, . Self-reported hearing loss, hearing aids, and cognitive decline in elderly adults: a 25-year study. J Am Geriatr Soc. 2015;63(10):2099–104. Exclusion Code: X1.26480972
14 Amieva H, Ouvrard C, Meillon C, . Death, Depression, Disability, and Dementia Associated With Self-reported Hearing Problems: A 25-Year Study. J Gerontol A Biol Sci Med Sci. 2018 Sep 11;73(10):1383–9. doi: 10.1093/gerona/glx250. PMID: 30248131. Exclusion Code: X3.29304204
15 Arndt S, Laszig R, Aschendorff A, . [Unilateral deafness and cochlear implantation: audiological diagnostic evaluation and outcomes]. HNO. 2011;59(5):437–46. Exclusion Code: X8.21505923
16 Barbara M, Biagini M, Lazzarino AI, . Hearing and quality of life in a south European BAHA population. Acta Otolaryngol. 2010 Sep;130(9):1040–7. doi: 10.3109/00016481003591756. PMID: 21756638. Exclusion Code: X1.20141489
17 Barbara M, Volpini L, Filippi C, . A new semi-implantable middle ear implant for sensorineural hearing loss: three-years follow-up in a pilot patient’s group. Acta Otolaryngol. 2018 Jan;138(1):31–5. doi: 10.1080/00016489.2017.1371327. PMID: 28854835. Exclusion Code: X1.28854835
18 Becerril-Ramirez PB, Gonzalez-Sanchez DF, Gomez-Garcia A, . Hearing loss screening tests for adults. Acta Otorrinolaringol Esp. 2013 May–Jun;64(3):184–90. doi: 10.1016/j.otorri.2012.11.004. PMID: 23529883. Exclusion Code: X9.23332791
19 Boeschen Hospers JM, Smits N, Smits C, . Reevaluation of the Amsterdam Inventory for Auditory Disability and Handicap Using Item Response Theory. J Speech Lang Hear Res. 2016 Apr 1;59(2):373–83. doi: 10.1044/2015_jslhr-h-15-0156. PMID: 26164445. Exclusion Code: X3.27115096
20 Böheim K, Nahler A, Schlögel M. [Rehabilitation of high frequency hearing loss: use of an active middle ear implant]. HNO. 2007;55(9):690–5. Exclusion Code: X8.17160659
21 Boleas-Aguirre MS, Bulnes Plano MD, de Erenchun Lasa IR, . Audiological and subjective benefit results in bone-anchored hearing device users. Otol Neurotol. 2012 Jun;33(4):494–503. doi: 10.1097/MAO.0b013e31824b76f1. PMID: 22415523. Exclusion Code: X1.22472615
22 Bonnard D. Validation and Evaluation of the French Version of a Hearing Loss Screening Questionnaire in Adults Aged 60 Years Old and More (VF DEPIST 60) University Hospital, Bordeaux. NCT04159428. Bordeaux, France: 2019. Exclusion Code: X3.
23 Borrie SA. Visual speech information: a help or hindrance in perceptual processing of dysarthric speech. J Acoust Soc Am. 2015 Mar;137(3):1473–80. doi: 10.1121/1.4913770. PMID: 25579238. Exclusion Code: X1.25786958
24 Bosman AJ, Hol MKS, Snik AFM, . Bone-anchored hearing aids in unilateral inner ear deafness. Acta Otolaryngol. 2003;123(2):258–60. Exclusion Code: X1.12701753
25 Brennan-Jones CG, Eikelboom RH, Swanepoel de W, . Clinical validation of automated audiometry with continuous noise-monitoring in a clinically heterogeneous population outside a sound-treated environment. Int J Audiol. 2016 Sep;55(9):507–13. doi: 10.1080/14992027.2016.1178858. PMID: 28376930. Exclusion Code: X1.27206551
26 Bruinewoud EM, Kraak JT, van Leeuwen LM, . The Otology Questionnaire Amsterdam: a generic patient reported outcome measure about the severity and impact of ear complaints. A cross-sectional study on the development of this questionnaire. Clin Otolaryngol. 2018 Feb;43(1):240–8. doi: 10.1111/coa.12950. PMID: 28772342. Exclusion Code: X1.28772342
27 Brungart DS, Cohen J, Cord M, . Assessment of auditory spatial awareness in complex listening environments. J Acoust Soc Am. 2014 Oct;136(4):1808–20. doi: 10.1121/1.4893932. PMID: 24892363. Exclusion Code: X1.25324082
28 Canale A, Dagna F, Lacilla M, . Relationship between pure tone audiometry and tone burst auditory brainstem response at low frequencies gated with Blackman window. Eur Arch Otorhinolaryngol. 2012 Mar;269(3):781–5. doi: 10.1007/s00405-011-1723-7. PMID: 23231814. Exclusion Code: X3.21814732
29 Caruso A, Giannuzzi AL, Sozzi V, . Bone anchored hearing implants without skin thinning: the Gruppo Otologico surgical and audiological experience. Eur Arch Otorhinolaryngol. 2017 Feb;274(2):695–700. doi: 10.1007/s00405-016-4305-x. PMID: 28125445. Exclusion Code: X1.27637751
30 Cassarly C, Matthews LJ, Simpson AN, . The Revised Hearing Handicap Inventory and Screening Tool Based on Psychometric Reevaluation of the Hearing Handicap Inventories for the Elderly and Adults. Ear Hear. 2020 Jan/Feb;41(1):95–105. doi: 10.1097/AUD.0000000000000746. PMID: 31124792. Exclusion Code: X6.31124792
31 Castiglione A, Benatti A, Velardita C, . Aging, cognitive decline and hearing loss: effects of auditory rehabilitation and training with hearing aids and cochlear implants on cognitive function and depression among older adults. Audiol Neurootol. 2016;21 Suppl 1:21–8. doi: 10.1159/000448350. PMID: 26388240. Exclusion Code: X2.27806352
32 Chenault M, Berger M, Kremer B, . Quantification of experienced hearing problems with item response theory. Am J Audiol. 2013;22(2):252–62. doi: 10.1044/1059-0889(2013/12-0038). Exclusion Code: X2.23824431
33 Chew HS, Yeak S. Quality of life in patients with untreated age-related hearing loss. J Laryngol Otol. 2010;124(8):835–41. doi: 10.1017/S0022215110000757. Exclusion Code: X1.20403224
34 Chisolm TH, Saunders GH, Frederick MT, . Learning to listen again: the role of compliance in auditory training for adults with hearing loss. Am J Audiol. 2013 Dec;22(2):339–42. doi: 10.1044/1059-0889(2013/12-0081). PMID: 24606294. Exclusion Code: X2.24018575
35 Cho SW, Han KH, Jang HK, . Auditory brainstem responses to CE-Chirp(R) stimuli for normal ears and those with sensorineural hearing loss. Int J Audiol. 2015;54(10):700–4. doi: 10.3109/14992027.2015.1043148. PMID: 25649884. Exclusion Code: X4.25997814
36 Choi JM, Sohn J, Ku Y, . Phoneme-based self hearing assessment on a smartphone. IEEE J Biomed Health Inform. 2013 May;17(3):526–9. PMID: 23270794. Exclusion Code: X1.24592452
37 Choi JS, Betz J, Deal J, . A comparison of self-report and audiometric measures of hearing and their associations with functional outcomes in older adults. J Aging Health. 2016 Aug;28(5):890–910. doi: 10.1177/0898264315614006. PMID: 26459989. Exclusion Code: X3.26553723
38 Clark JG. Uses and abuses of hearing loss classification. ASHA. 1981 Jul;23(7):493–500. PMID: 7052898. Exclusion Code: X7.7052898
39 Contrera KJ, Betz J, Genther DJ, . Association of hearing impairment and mortality in the National Health and Nutrition Examination Survey. JAMA Otolaryngol Head Neck Surg. 2015 Oct;141(10):944–6. doi: 10.1001/jamaoto.2015.1762. PMID: 26401904. Exclusion Code: X2.26401904
40 Contrera KJ, Betz J, Li L, . Quality of life after intervention with a cochlear implant or hearing aid. Laryngoscope. 2016 Sep;126(9):2110–5. doi: 10.1002/lary.25848. PMID: 27310369. Exclusion Code: X4.26775283
41 Contrera KJ, Sung YK, Betz J, . Change in loneliness after intervention with cochlear implants or hearing aids. Laryngoscope. 2017 Aug;127(8):1885–9. doi: 10.1002/lary.26424. PMID: 28059448. Exclusion Code: X4.28059448
42 Convery E, Keidser G, Seeto M, . Identification of conductive hearing loss using air conduction tests alone: reliability and validity of an automatic test battery. Ear Hear. 2014 Jan–Feb;35(1):e1–8. doi: 10.1097/AUD.0b013e31829e058f. PMID: 24384082. Exclusion Code: X3.24080948
43 Costa K, Ferreira SMS, Menezes PL. Hearing handicap in patients with chronic kidney disease: a study of the different classifications of the degree of hearing loss. Braz J Otorhinolaryngol. 2017 Sep – Oct;83(5):580–4. doi: 10.1016/j.bjorl.2016.08.008. PMID: 27329283. Exclusion Code: X1.27649632
44 Costa-Guarisco LP, Dalpubel D, Labanca L, . Perception of hearing loss: use of the subjective faces scale to screen hearing among the elderly. Cien Saude Colet. 2017 Nov;22(11):3579–88. doi: 10.1590/1413-812320172211.277872016. PMID: 29211164. Exclusion Code: X9.29211163
45 Cote M, Deguine O, Calmels MN, . BAHA or MedEl Vibrant Soundbridge: results and criteria of decision. Cochlear Implants Int. 2011 May;12 Suppl 1:S130–2. doi: 10.1179/146701011x13001036693377. PMID: 21756843. Exclusion Code: X1.21756496
46 Cox RM, Johnson JA, Xu J. Impact of advanced hearing aid technology on speech understanding for older listeners with mild to moderate, adult-onset, sensorineural hearing loss. Gerontology. 2014;60(6):557–68. doi: 10.1159/000362547. PMID: 28806338. Exclusion Code: X1.25139516
47 Cox RM, Schwartz KS, Noe CM, . Preference for one or two hearing AIDS among adult patients. Ear Hear. 2011 Mar–Apr;32(2):181–97. doi: 10.1097/AUD.0b013e3181f8bf6c. PMID: 20890203. Exclusion Code: X4.20890203
48 Cruickshanks KJ, Tweed TS, Wiley TL, . The 5-year incidence and progression of hearing loss: the epidemiology of hearing loss study. Arch Otolaryngol Head Neck Surg. 2003 Oct;129(10):1041–6. doi: 10.1001/archotol.129.10.1041. PMID: 14568784. Exclusion Code: X2.14568784
49 Dawes P, Cruickshanks KJ, Fischer ME, . Hearing-aid use and long-term health outcomes: hearing handicap, mental health, social engagement, cognitive function, physical health, and mortality. Int J Audiol. 2015;54(11):838–44. doi: 10.3109/14992027.2015.1059503. PMID: 24532083. Exclusion Code: X1.26140300
50 Dawes P, Hopkins R, Munro KJ. Placebo effects in hearing-aid trials are reliable. Int J Audiol. 2013 Jul;52(7):472–7. doi: 10.3109/14992027.2013.783718. PMID: 23398728. Exclusion Code: X1.23594421
51 Dawes P, Munro KJ, Kalluri S, . Acclimatization to hearing aids. Ear Hear. 2014 Mar–Apr;35(2):203–12. doi: 10.1097/AUD.0b013e3182a8eda4. PMID: 24384083. Exclusion Code: X4.24351612
52 de Andrade AN, Iorio MC, Gil D. Speech recognition in individuals with sensorineural hearing loss. Braz J Otorhinolaryngol. 2016 May–Jun;82(3):334–40. doi: 10.1016/j.bjorl.2015.10.002. PMID: 27351868. Exclusion Code: X1.26614048
53 de Paiva SM, Simoes J, Paiva A, . Validity and reliability of the hearing handicap inventory for elderly: version adapted for use on the Portuguese population. J Am Acad Audiol. 2016 Sep;27(8):677–82. doi: 10.3766/jaaa.15146. PMID: 26808287. Exclusion Code: X1.27564445
54 De Sousa KC, Swanepoel W, Moore DR, . A Smartphone National Hearing Test: Performance and Characteristics of Users. Am J Audiol. 2018 Nov 19;27(3s):448–54. doi: 10.1044/2018_aja-imia3-18-0016. PMID: 29959525. Exclusion Code: X4.30452748
55 de Wolf MJ, Hendrix S, Cremers CW, . Better performance with bone-anchored hearing aid than acoustic devices in patients with severe air-bone gap. Laryngoscope. 2011 Mar;121(3):613–6. doi: 10.1002/lary.21167. Exclusion Code: X1.21344443
56 de Wolf MJ, Shival ML, Hol MK, . Benefit and quality of life in older bone-anchored hearing aid users. Otol Neurotol. 2010 Jul;31(5):766–72. doi: 10.1097/MAO.0b013e3181e3d740. PMID: 20649230. Exclusion Code: X1.20581615
57 Deal JA, Betz J, Yaffe K, . Hearing impairment and incident dementia and cognitive decline in older adults: the Health ABC Study. J Gerontol A Biol Sci Med Sci. 2017 May 1;72(5):703–9. doi: 10.1093/gerona/glw069. PMID: 28259857. Exclusion Code: X2.27071780
58 Deal JA, Sharrett AR, Albert MS, . Hearing impairment and cognitive decline: a pilot study conducted within the atherosclerosis risk in communities neurocognitive study. Am J Epidemiol. 2015 May 1;181(9):680–90. doi: 10.1093/aje/kwu333. PMID: 25680293. Exclusion Code: X2.25841870
59 Deepthi R, Kasthuri A. Validation of the use of self-reported hearing loss and the Hearing Handicap Inventory for elderly among rural Indian elderly population. Arch Gerontol Geriatr. 2012 Nov–Dec;55(3):762–7. doi: 10.1016/j.archger.2012.07.006. PMID: 22333494. Exclusion Code: X9.22898672
60 Demeester K, Topsakal V, Hendrickx JJ, . Hearing disability measured by the speech, spatial, and qualities of hearing scale in clinically normal-hearing and hearing-impaired middle-aged persons, and disability screening by means of a reduced SSQ (the SSQ5). Ear Hear. 2012;33(5):615–6. Exclusion Code: X1.22568994
61 den Besten CA, Stalfors J, Wigren S, . Stability, survival, and tolerability of an auditory osseointegrated implant for bone conduction hearing: long-term follow-up of a randomized controlled trial. Otol Neurotol. 2016 Sep;37(8):1077–83. doi: 10.1097/mao.0000000000001111. PMID: 28177335. Exclusion Code: X4.27482783
62 Derin S, Cam OH, Beydilli H, . Initial assessment of hearing loss using a mobile application for audiological evaluation. J Laryngol Otol. 2016 Mar;130(3):248–51. doi: 10.1017/s0022215116000062. PMID: 26183518. Exclusion Code: X1.26781699
63 Desjardins JL, Doherty KA. Changes in psychosocial measures after a 6-week field trial. Am J Audiol. 2017 Jun 13;26(2):119–28. doi: 10.1044/2017_aja-16-0066. PMID: 28271322. Exclusion Code: X4.28492830
64 Dewyer NA, Jiradejvong P, Henderson Sabes J, . Automated smartphone audiometry: validation of a word recognition test app. Laryngoscope. 2018 Mar;128(3):707–12. doi: 10.1002/lary.26638. PMID: 29781704. Exclusion Code: X1.28543040
65 Diao M, Sun J, Jiang T, . Comparison between self-reported hearing and measured hearing thresholds of the elderly in China. Ear Hear. 2014 Sep–Oct;35(5):e228–32. doi: 10.1097/aud.0000000000000050. PMID: 25597462. Exclusion Code: X9.24979248
66 DiGiovanni JJ, Davlin EA, Nagaraj NK. Effects of transient noise reduction algorithms on speech intelligibility and ratings of hearing aid users. Am J Audiol. 2011 Dec;20(2):140–50. doi: 10.1044/1059-0889(2011/10-0007). PMID: 21659922. Exclusion Code: X1.21940982
67 Dobie RA. The AMA method of estimation of hearing disability: a validation study. Ear Hear. 2011 Nov–Dec;32(6):732–40. doi: 10.1097/AUD.0b013e31822228be. PMID: 22031674. Exclusion Code: X2.21694598
68 Dumper J, Hodgetts B, Liu R, . Indications for bone-anchored hearing AIDS: a functional outcomes study. J Otolaryngol. 2009;38(1):96–105. Exclusion Code: X1.
69 Dwyer NY, Firszt JB, Reeder RM. Effects of unilateral input and mode of hearing in the better ear: self-reported performance using the speech, spatial and qualities of hearing scale. Ear Hear. 2014 Jan–Feb;35(1):126–36. doi: 10.1097/AUD.0b013e3182a3648b. PMID: 24237041. Exclusion Code: X1.24084062
70 Eberhard KE, Olsen SO, Miyazaki H, . Objective and subjective outcome of a new transcutaneous bone conduction hearing device: half-year follow-up of the first 12 Nordic implantations. Otol Neurotol. 2016 Mar;37(3):267–75. doi: 10.1097/mao.0000000000000969. PMID: 26063637. Exclusion Code: X1.26859460
71 Eekhof JA, De Bock GH, Schaapveld K, . Screening for hearing and visual loss among elderly with questionnaires and tests: which method is the most convincing for action? Scand J Prim Health Care. 2000;18(4):203–7. Exclusion Code: X4.11205087
72 Eichenauer A, Dillon H, Clinch B, . Effect of bone-conduction harmonic distortions on hearing thresholds. J Acoust Soc Am. 2014 Aug;136(2):El96–102. doi: 10.1121/1.4885771. PMID: 24962178. Exclusion Code: X1.25096153
73 Eikelboom RH, Swanepoel de W, Motakef S, . Clinical validation of the AMTAS automated audiometer. Int J Audiol. 2013 May;52(5):342–9. doi: 10.3109/14992027.2013.769065. PMID: 22951430. Exclusion Code: X3.23548148
74 Eley KA, Fitzgerald JE. Quality improvement in action. Direct general practitioner referrals to audiology for the provision of hearing aids: a single centre review. Qual Prim Care. 2010;18(3):201–6. PMID: 19825223. Exclusion Code: X2.20659404
75 Fausto BA, Badana ANS, Arnold ML, . Comparison of Subjective and Objective Measures of Hearing, Auditory Processing, and Cognition Among Older Adults With and Without Mild Cognitive Impairment. J Speech Lang Hear Res. 2018 Apr 17;61(4):945–56. doi: 10.1044/2017_jslhr-h-17-0263. PMID: 29524681. Exclusion Code: X3.29594311
76 FDA. Esteem safety and effectiveness. PMA P090018: FDA Summary of Safety and Effectiveness Data (SSED). 2010:1–57. Exclusion Code: X1.
77 Fisch U, Cremers CW, Lenarz T, . Clinical experience with the Vibrant Soundbridge implant device. Otol Neurotol. 2001;22(6):962–72. Exclusion Code: X1.11698826
78 Foghsgaard S, Caye-Thomasen P. A new wide-diameter bone-anchored hearing implant-prospective 1-year data on complications, implant stability, and survival. Otol Neurotol. 2014 Aug;35(7):1238–41. doi: 10.1097/mao.0000000000000345. PMID: 24737843. Exclusion Code: X1.24608379
79 Folmer RL, Vachhani J, McMillan GP, . Validation of a computer-administered version of the digits-in-noise test for hearing screening in the United States. J Am Acad Audiol. 2017 Feb;28(2):161–9. doi: 10.3766/jaaa.16038. PMID: 27574724. Exclusion Code: X3.28240983
80 Fredriksson S, Hammar O, Magnusson L, . Validating self-reporting of hearing-related symptoms against pure-tone audiometry, otoacoustic emission, and speech audiometry. Int J Audiol. 2016 Aug;55(8):454–62. doi: 10.1080/14992027.2016.1177210. PMID: 25979791. Exclusion Code: X1.27195802
81 Frohne-Buechner C, Brendel M, Saalfeld H, . Evaluation of the built-in TCoil of the behind-the-ear sound processor Harmony. Cochlear Implants Int. 2010 Jun;11 Suppl 1:412–5. doi: 10.1179/146701010x12671177204066. PMID: 21756630. Exclusion Code: X2.21756662
82 Fuentes-Lopez E, Fuente A, Cardemil F, . Prevalence and associated factors of hearing aid use among older adults in Chile. Int J Audiol. 2017 Nov;56(11):810–8. doi: 10.1080/14992027.2017.1337937. PMID: 28639872. Exclusion Code: X1.28639872
83 Garcia TM, Jacob RT, Mondelli MF. Speech perception and quality of life of open-fit hearing aid users. J Appl Oral Sci. 2016 May–Jun;24(3):264–70. doi: 10.1590/1678-775720150321. PMID: 25790770. Exclusion Code: X4.27383708
84 Gardell IS, Andresen K, Faber CE, . Bone-anchored hearing aids are effective and associated with a high degree of satisfaction. Dan Med J. 2015 Jul;62(7)PMID: 25373837. Exclusion Code: X1.25373837
85 Garin P, Debaty M, Galle C. Hearing in noise with the vibrant Soundbridge middle-ear implant. Cochlear implants international. 2005;6 Suppl 1:72–4. Exclusion Code: X1.18792365
86 Garin P, Thill MP, Gerard JM. Speech discrimination in background noise with the Vibrant® Soundbridge™ Middle Ear Implant. Oto-Rhino-Laryngologia Nova. 2002;12(3):119–23. Exclusion Code: X1.
87 Goehring T, Chapman JL, Bleeck S, . Tolerable delay for speech production and perception: effects of hearing ability and experience with hearing aids. Int J Audiol. 2018 Jan;57(1):61–8. doi: 10.1080/14992027.2017.1367848. PMID: 27759911. Exclusion Code: X1.28838277
88 Goldstein DP. Hearing impairment, hearing aids and audiology. ASHA. 1984 Sep;26(9):24–35, 8. PMID: 6487402. Exclusion Code: X7.6487402
89 Gonzalez-Navarro M, Manrique-Huarte R, Manrique-Rodriguez M, . Long-term follow-up of late onset vestibular complaints in patients with cochlear implant. Acta Otolaryngol. 2015;135(12):1245–52. doi: 10.3109/00016489.2015.1072874. PMID: 26113252. Exclusion Code: X1.26224013
90 Gopinath B, McMahon CM, Burlutsky G, . Hearing and vision impairment and the 5-year incidence of falls in older adults. Age Ageing. 2016 May;45(3):409–14. doi: 10.1093/ageing/afw022. PMID: 27157689. Exclusion Code: X2.26946051
91 Gopinath B, Schneider J, Hickson L, . Hearing handicap, rather than measured hearing impairment, predicts poorer quality of life over 10 years in older adults. Maturitas. 2012 Jun;72(2):146–51. doi: 10.1016/j.maturitas.2012.03.010. PMID: 22497235. Exclusion Code: X1.22521684
92 Gopinath B, Schneider J, McMahon CM, . Severity of age-related hearing loss is associated with impaired activities of daily living. Age Ageing. 2012 Mar;41(2):195–200. doi: 10.1093/ageing/afr155. PMID: 23169195. Exclusion Code: X2.22130560
93 Gurgel RK, Curtis SH, Shelton C. A novel intraoral bone conduction hearing prosthesis: one-year safety and efficacy study. Otol Neurotol. 2015 Jan;36(1):106–10. doi: 10.1097/mao.0000000000000624. PMID: 24402676. Exclusion Code: X1.25275866
94 Hannula S, Bloigu R, Majamaa K, . Audiogram configurations among older adults: prevalence and relation to self-reported hearing problems. Int J Audiol. 2011 Nov;50(11):793–801. doi: 10.3109/14992027.2011.593562. PMID: 21959114. Exclusion Code: X3.21916791
95 Hearing Loss Association of America. Position paper: screening for hearing loss in primary health care settings. Bethesda, MD: Hearing Loss Association of America (HLAA); 2015. http://hearingloss.org Exclusion Code: X7.
96 Heflin MT. Geriatric health maintenance. UpToDate; 2018. https://www.uptodate.com/contents/geriatric-health-maintenance?search=geriatric%20health%20maintenance&source=search_result&selectedTitle=1~11&usage_type=default&display_rank=1. Accessed August 16, 2018. Exclusion Code: X7.
97 Hickson L, Meyer C, Lovelock K, . Factors associated with success with hearing aids in older adults. Int J Audiol. 2014 Feb;53 Suppl 1:S18–27. doi: 10.3109/14992027.2013.860488. PMID: 24405446. Exclusion Code: X1.24447233
98 Hiraumi H, Yamamoto N, Sakamoto T, . Multivariate analysis of hearing outcomes in patients with idiopathic sudden sensorineural hearing loss. Acta Otolaryngol Suppl. 2010 Nov(563):24–8. doi: 10.3109/00016489.2010.487191. PMID: 20403228. Exclusion Code: X1.20879814
99 Hol MKS, Kunst SJW, Snik AFM, . Pilot study on the effectiveness of the conventional CROS, the transcranial CROS and the BAHA transcranial CROS in adults with unilateral inner ear deafness. Eur Arch Otorhinolaryngol. 2010;267(6):889–96. Exclusion Code: X1.19904546
100 Honeth L, Bexelius C, Eriksson M, . An internet-based hearing test for simple audiometry in nonclinical settings: preliminary validation and proof of principle. Otol Neurotol. 2010 Jul;31(5):708–14. doi: 10.1097/MAO.0b013e3181de467a. PMID: 20047543. Exclusion Code: X1.20458255
101 Hong O, Ronis DL, Antonakos CL. Validity of self-rated hearing compared with audiometric measurement among construction workers. Nurs Res. 2011 Sep–Oct;60(5):326–32. doi: 10.1097/NNR.0b013e3182281ca0. PMID: 21873915. Exclusion Code: X5.21873915
102 Hoover E, Pasquesi L, Souza P. Comparison of clinical and traditional gap detection tests. J Am Acad Audiol. 2015 Jun;26(6):540–6. doi: 10.3766/jaaa.14088. PMID: 25705651. Exclusion Code: X2.26134721
103 Hopkins K, Khanom M, Dickinson AM, . Benefit from non-linear frequency compression hearing aids in a clinical setting: the effects of duration of experience and severity of high-frequency hearing loss. Int J Audiol. 2014 Apr;53(4):219–28. doi: 10.3109/14992027.2013.873956. PMID: 24518401. Exclusion Code: X4.24617592
104 Hougaard DD, Boldsen SK, Jensen AM, . A multicenter study on objective and subjective benefits with a transcutaneous bone-anchored hearing aid device: first Nordic results. Eur Arch Otorhinolaryngol. 2017 Aug;274(8):3011–9. doi: 10.1007/s00405-017-4614-8. PMID: 28534731. Exclusion Code: X1.28534117
105 Hultcrantz M. Outcome of the bone-anchored hearing aid procedure without skin thinning: a prospective clinical trial. Otol Neurotol. 2011 Sep;32(7):1134–9. doi: 10.1097/MAO.0b013e31822a1c47. PMID: 21917216. Exclusion Code: X4.21817939
106 Hultcrantz M, Lanis A. A five-year follow-up on the osseointegration of bone-anchored hearing device implantation without tissue reduction. Otol Neurotol. 2014 Sep;35(8):1480–5. doi: 10.1097/mao.0000000000000352. PMID: 23552078. Exclusion Code: X1.24770406
107 Humes LE, Kinney DL, Brown SE, . The effects of dosage and duration of auditory training for older adults with hearing impairment. J Acoust Soc Am. 2014 Sep;136(3):El224. doi: 10.1121/1.4890663. PMID: 24079471. Exclusion Code: X2.25190425
108 Humes LE, Kinney DL, Main AK, . A Follow-Up Clinical Trial Evaluating the Consumer-Decides Service Delivery Model. Am J Audiol. 2019;28(1):69–84. doi: 10.1044/2018_AJA-18-0082. PMID: CN-01981857. Exclusion Code: X1.30938563
109 Ingo E, Brannstrom KJ, Andersson G, . Measuring motivation using the transtheoretical (stages of change) model: a follow-up study of people who failed an online hearing screening. Int J Audiol. 2016 Jul;55 Suppl 3:S52–8. doi: 10.1080/14992027.2016.1182650. PMID: 25996680. Exclusion Code: X1.27206679
110 Johansson ML, Stokroos RJ, Banga R, . Short-term results from seventy-six patients receiving a bone-anchored hearing implant installed with a novel minimally invasive surgery technique. Clin Otolaryngol. 2017 Oct;42(5):1043–8. doi: 10.1111/coa.12803. PMID: 27930877. Exclusion Code: X1.27930877
111 John AB, Kreisman BM, Pallett S. Validity of hearing impairment calculation methods for prediction of self-reported hearing handicap. Noise Health. 2012 Jan–Feb;14(56):13–20. doi: 10.4103/1463-1741.93321. PMID: 21756459. Exclusion Code: X1.22387708
112 Jones CA, Siever J, Knuff K, . Walk, Talk and Listen: a pilot randomised controlled trial targeting functional fitness and loneliness in older adults with hearing loss. BMJ open. 2019;9(4):e026169. PMID: 30987987. Exclusion Code: X2.30987987
113 Kaandorp MW, Smits C, Merkus P, . Assessing speech recognition abilities with digits in noise in cochlear implant and hearing aid users. Int J Audiol. 2015 Jan;54(1):48–57. doi: 10.3109/14992027.2014.945623. PMID: 27121117. Exclusion Code: X1.25156097
114 Kam AC, Sung JK, Lee T, . Clinical evaluation of a computerized self-administered hearing test. Int J Audiol. 2012 Aug;51(8):606–10. doi: 10.3109/14992027.2012.688144. PMID: 23026039. Exclusion Code: X1.22676699
115 Kam AC, Sung JK, Lee T, . Improving mobile phone speech recognition by personalized amplification: application in people with normal hearing and mild-to-moderate hearing loss. Ear Hear. 2017 Mar/Apr;38(2):e85–e92. doi: 10.1097/aud.0000000000000371. PMID: 28527538. Exclusion Code: X3.28225737
116 Kamil RJ, Genther DJ, Lin FR. Factors associated with the accuracy of subjective assessments of hearing impairment. Ear Hear. 2015 Jan;36(1):164–7. doi: 10.1097/aud.0000000000000075. PMID: 25158982. Exclusion Code: X3.25158982
117 Kasemsiri P, Yimtae K, Thanawirattananit P, . Community-based hearing screening of disabled elders using the Thai-FMHT: clinical implications and cost-effectiveness. J Med Assoc Thai. 2015 Aug;98(Suppl 7):S168–73. PMID: 25294170. Exclusion Code: X3.26742386
118 Kelly-Campbell RJ, Atcherson SR. Perception of quality of life for adults with hearing impairment in the LGBT community. J Commun Disord. 2012 Sep–Oct;45(5):367–77. doi: 10.1016/j.jcomdis.2012.05.002. PMID: 22201414. Exclusion Code: X1.22738877
119 Kenny Gibson W, Cronin H, Kenny RA, . Validation of the self-reported hearing questions in the Irish Longitudinal Study on Ageing against the Whispered Voice Test. BMC Res Notes. 2014 Jun 14;7:361. doi: 10.1186/1756-0500-7-361. PMID: 24495275. Exclusion Code: X2.24928453
120 Khon Kaen University. Thai-version five minute hearing test. 2011. Exclusion Code: X9.
121 Khon Kaen University. Effectiveness of P02 Digital Hearing Aids. 2014. Exclusion Code: X4.
122 Kim G, Na W, Kim G, . The development and standardization of self-assessment for hearing screening of the elderly. Clin Interv Aging. 2016;11:787–95. doi: 10.2147/cia.S107102. PMID: 26854774. Exclusion Code: X3.27366055
123 Kim SY, Kim HJ, Kim MS, . Discrepancy between self-assessed hearing status and measured audiometric evaluation. PLoS One. 2017;12(8):e0182718. doi: 10.1371/journal.pone.0182718. PMID: 28372143. Exclusion Code: X2.28792529
124 Kirk KM, McGuire A, Nasveld PE, . Comparison of self-reported and audiometrically-measured hearing loss in the Australian Defence Force. Int J Audiol. 2012 Apr;51(4):294–8. doi: 10.3109/14992027.2011.625981. PMID: 27556525. Exclusion Code: X1.22149463
125 Kitterick PT, Ferguson MA. Hearing aids and health-related quality of life in adults with hearing loss. JAMA. 2018 Jun 5;319(21):2225–6. doi: 10.1001/jama.2018.5567. PMID: 28407310. Exclusion Code: X7.29872841
126 Kreisman BM, Mazevski AG, Schum DJ, . Improvements in speech understanding with wireless binaural broadband digital hearing instruments in adults with sensorineural hearing loss. Trends Amplif. 2010 Mar;14(1):3–11. doi: 10.1177/1084713810364396. PMID: 21154366. Exclusion Code: X4.20457725
127 Kutlar G, Koyuncu M, Elmali M, . Are computed tomography and densitometric measurements useful in otosclerosis with mixed hearing loss? A retrospective clinical study. Eur Arch Otorhinolaryngol. 2014 Sep;271(9):2421–5. doi: 10.1007/s00405-013-2729-0. PMID: 26233036. Exclusion Code: X1.24096812
128 Labanca L, Guimaraes FS, Costa-Guarisco LP, . Screening of hearing in elderly people: assessment of accuracy and reproducibility of the whispered voice test. Cien Saude Colet. 2017 Nov;22(11):3589–98. doi: 10.1590/1413-812320172211.31222016. PMID: 28587489. Exclusion Code: X9.29211164
129 Labassi S, Beliaeff M. Retrospective of 1000 patients implanted with a vibrant Soundbridge middle-ear implant. Cochlear Implants International. 2005;6(Suppl 1):74–7. doi: 10.1179/cim.2005.6.Supplement-1.74 PMID: 18792366 Exclusion Code: X7.18792366
130 Lambert J, Ghadry-Tavi R, Knuff K, . Targeting functional fitness, hearing and health-related quality of life in older adults with hearing loss: Walk, Talk ‘n’ Listen, study protocol for a pilot randomized controlled trial. Trials. 2017 Jan 28;18(1):47. doi: 10.1186/s13063-017-1792-z. PMID: 25190425. Exclusion Code: X2.28129779
131 Laplante-Levesque A, Hickson L, Worrall L. What makes adults with hearing impairment take up hearing AIDS or communication programs and achieve successful outcomes? Ear Hear. 2012 Jan–Feb;33(1):79–93. doi: 10.1097/AUD.0b013e31822c26dc. PMID: 22545384. Exclusion Code: X4.21841487
132 Lasisi AO, Fehintola FA, Yusuf OB. Age-related hearing loss, vitamin B12, and folate in the elderly. Otolaryngol Head Neck Surg. 2010 Dec;143(6):826–30. doi: 10.1016/j.otohns.2010.08.031. PMID: 20839902. Exclusion Code: X2.21109085
133 Laske RD, Roosli C, Pfiffner F, . Functional results and subjective benefit of a transcutaneous bone conduction device in patients with single-sided deafness. Otol Neurotol. 2015 Aug;36(7):1151–6. doi: 10.1097/mao.0000000000000791. PMID: 26065403. Exclusion Code: X3.26111077
134 Lavie L, Attias J, Karni A. Semi-structured listening experience (listening training) in hearing aid fitting: influence on dichotic listening. Am J Audiol. 2013 Dec;22(2):347–50. doi: 10.1044/1059-0889(2013/12-0083). PMID: 23739775. Exclusion Code: X2.24096865
135 Leensen MC, de Laat JA, Dreschler WA. Speech-in-noise screening tests by internet, part 1: test evaluation for noise-induced hearing loss identification. Int J Audiol. 2011 Nov;50(11):823–34. doi: 10.3109/14992027.2011.595016. PMID: 21812631. Exclusion Code: X1.21988504
136 Leensen MC, de Laat JA, Snik AF, . Speech-in-noise screening tests by internet, part 2: improving test sensitivity for noise-induced hearing loss. Int J Audiol. 2011 Nov;50(11):835–48. doi: 10.3109/14992027.2011.595017. PMID: 21988504. Exclusion Code: X1.21970351
137 Leensen MC, Dreschler WA. The applicability of a speech-in-noise screening test in occupational hearing conservation. Int J Audiol. 2013 Jul;52(7):455–65. doi: 10.3109/14992027.2013.790565. PMID: 23906989. Exclusion Code: X1.23772828
138 Leterme G, Bernardeschi D, Bensemman A, . Contralateral routing of signal hearing aid versus transcutaneous bone conduction in single-sided deafness. Audiol Neurootol. 2015;20(4):251–60. doi: 10.1159/000381329. PMID: 25594387. Exclusion Code: X4.26021779
139 Lin FR, Ferrucci L. Hearing loss and falls among older adults in the United States. Arch Intern Med. 2012 Feb 27;172(4):369–71. doi: 10.1001/archinternmed.2011.728. PMID: 22371929. Exclusion Code: X2.22371929
140 Lin L-M, Bowditch S, Anderson MJ, . Amplification in the rehabilitation of unilateral deafness: speech in noise and directional hearing effects with bone-anchored hearing and contralateral routing of signal amplification. Otol Neurotol. 2006;27(2):172–82. Exclusion Code: X1.16436986
141 Linssen AM, Anteunis LJ, Joore MA. The cost-effectiveness of different hearing screening strategies for 50- to 70-year-old adults: a Markov Model. Value Health. 2015 Jul;18(5):560–9. doi: 10.1016/j.jval.2015.03.1789. PMID: 25652341. Exclusion Code: X6.26297083
142 Linssen AM, Joore MA, Theunissen EJ, . The effects and costs of a hearing screening and rehabilitation program in residential care homes for the elderly in the Netherlands1. Am J Audiol. 2013;22(1):186–9. Exclusion Code: X3.23800817
143 Liu CF, Collins MP, Souza PE, . Long-term cost-effectiveness of screening strategies for hearing loss. J Rehabil Res Dev. 2011;48(3):235–43. doi: 10.1682/JRRD.2010.03.0041. Exclusion Code: X3.21480098
144 Liu XY, Han Y, Yang SM. A hearing self-reported survey in people over 80 years of age in China by hearing handicap inventory for the elderly-complete version vs screening version. Acta Otolaryngol. 2016 Dec;136(12):1242–7. doi: 10.3109/00016489.2016.1157729. PMID: 24488749. Exclusion Code: X3.27126678
145 Lorens A, Zgoda M, Polak M, . FS4 for partial deafness treatment. Cochlear Implants Int. 2014 May;15 Suppl 1:S78–80. doi: 10.1179/1467010014z.000000000166. PMID: 24384079. Exclusion Code: X2.24869452
146 Louw C, Swanepoel W, Eikelboom RH. Self-Reported Hearing Loss and Pure Tone Audiometry for Screening in Primary Health Care Clinics. J Prim Care Community Health. 2018 Jan–Dec;9:2150132718803156. doi: 10.1177/2150132718803156. PMID: 29530429. Exclusion Code: X9.30278815
147 Louw C, Swanepoel W, Eikelboom RH, . Smartphone-based hearing screening at primary health care clinics. Ear Hear. 2017 Mar/Apr;38(2):e93–e100. doi: 10.1097/aud.0000000000000378. PMID: 27764002. Exclusion Code: X1.27764002
148 Maclennan-Smith F, Swanepoel de W, Hall JW, 3rd. Validity of diagnostic pure-tone audiometry without a sound-treated environment in older adults. Int J Audiol. 2013 Feb;52(2):66–73. doi: 10.3109/14992027.2012.736692. PMID: 22436020. Exclusion Code: X2.23140522
149 Mahmoudi E, Basu T, Langa K, . Can Hearing Aids Delay Time to Diagnosis of Dementia, Depression, or Falls in Older Adults? J Am Geriatr Soc. 2019;67(11):2362–9. doi: 10.1111/jgs.16109. PMID: 31486068. Exclusion Code: X10.31486068
150 Masalski M, Krecicki T. Self-test web-based pure-tone audiometry: validity evaluation and measurement error analysis. J Med Internet Res. 2013 Apr 12;15(4):e71. doi: 10.2196/jmir.2222. PMID: 23007720. Exclusion Code: X1.23583917
151 McCullagh MC. Validation of a questionnaire to identify hearing loss among farm operators. Noise Health. 2012 Jan–Feb;14(56):32–8. doi: 10.4103/1463-1741.93331. PMID: 22352092. Exclusion Code: X1.22387711
152 McCullagh MC, Raymond D, Kerr MJ, . Prevalence of hearing loss and accuracy of self-report among factory workers. Noise Health. 2011 Sep–Oct;13(54):340–7. doi: 10.4103/1463-1741.85504. PMID: 22353676. Exclusion Code: X1.21959114
153 McDaniel DM, Motts SD, Neeley RA. Effects of bilateral hearing aid use on balance in experienced adult hearing aid users. Am J Audiol. 2018 Mar 8;27(1):121–5. doi: 10.1044/2017_aja-16-0071. PMID: 29222555. Exclusion Code: X1.29357393
154 McInerney M, Walden P. Evaluating the use of an assistive listening device for communication efficiency using the Diapix task: a pilot study. Folia Phoniatr Logop. 2013;65(1):25–31. doi: 10.1159/000350490. PMID: 23570290. Exclusion Code: X3.23711727
155 McMahon CM, Schneider J, Dunsmore M, . Screening, education, and rehabilitation services for hearing loss provided to clients with low vision: measured and perceived value among participants of the vision-hearing project. Ear Hear. 2017 Jan/Feb;38(1):57–64. doi: 10.1097/aud.0000000000000351. PMID: 27556525. Exclusion Code: X2.27556525
156 Meinke DK, Norris JA, Flynn BP, . Going wireless and booth-less for hearing testing in industry. Int J Audiol. 2017;56(sup1):41–51. doi: 10.1080/14992027.2016.1261189. PMID: 27765530. Exclusion Code: X1.27976975
157 Melin L, Scott B, Lindberg P, . Hearing aids and tinnitus--an experimental group study. Br J Audiol. 1987;21(2):91–7. Exclusion Code: X1.3594019
158 Mick P, Kawachi I, Lin FR. The association between hearing loss and social isolation in older adults. Otolaryngol Head Neck Surg. 2014 Mar;150(3):378–84. doi: 10.1177/0194599813518021. PMID: 24384545. Exclusion Code: X6.24384545
159 Monini S, Biagini M, Atturo F, . Esteem(R) middle ear device versus conventional hearing aids for rehabilitation of bilateral sensorineural hearing loss. Eur Arch Otorhinolaryngol. 2013 Jul;270(7):2027–33. doi: 10.1007/s00405-012-2252-8. PMID: 23743741. Exclusion Code: X1.23143506
160 Moore BC, Popelka GR. Preliminary comparison of bone-anchored hearing instruments and a dental device as treatments for unilateral hearing loss. Int J Audiol. 2013 Oct;52(10):678–86. doi: 10.3109/14992027.2013.809483. PMID: 24131608. Exclusion Code: X1.23859058
161 Moser S, Luxenberger W, Freidl W. The influence of social support and coping on quality of life among elderly with age-related hearing loss. Am J Audiol. 2017 Jun 13;26(2):170–9. doi: 10.1044/2017_aja-16-0083. PMID: 27632707. Exclusion Code: X4.28445580
162 Mosnier I, Sterkers O, Bouccara D, . Benefit of the Vibrant Soundbridge device in patients implanted for 5 to 8 years. Ear Hear. 2008;29(2):281–4. Exclusion Code: X4.18595192
163 Mueller YK, Monod S, Locatelli I, . Performance of a brief geriatric evaluation compared to a comprehensive geriatric assessment for detection of geriatric syndromes in family medicine: a prospective diagnostic study. BMC Geriatr. 2018 Mar 13;18(1):72. doi: 10.1186/s12877-018-0761-z. PMID: 23027734. Exclusion Code: X4.29534680
164 Mulrow CD, Lichtenstein MJ. Screening for hearing impairment in the elderly: rationale and strategy. J Gen Intern Med. 1991 May–Jun;6(3):249–58. PMID: 2066832. Exclusion Code: X7.2066832
165 Murray M, Popelka GR, Miller R. Efficacy and safety of an in-the-mouth bone conduction device for single-sided deafness. Otol Neurotol. 2011 Apr;32(3):437–43. doi: 10.1097/MAO.0b013e3182096b1d. PMID: 20808225. Exclusion Code: X1.21221045
166 Nelissen RC, Stalfors J, de Wolf MJ, . Long-term stability, survival, and tolerability of a novel osseointegrated implant for bone conduction hearing: 3-year data from a multicenter, randomized, controlled, clinical investigation. Otol Neurotol. 2014 Sep;35(8):1486–91. doi: 10.1097/mao.0000000000000533. PMID: 23771321. Exclusion Code: X4.25080037
167 Newman CW, Sandridge SA, Oswald LM. Relationship between expectations and satisfaction for Baha implant system in patients with single-sided deafness. Semin Hear. 2010;31(1 DOI - 10.1055/s-0029-1246321 SRC - BaiduScholar):15–27. Exclusion Code: X1.
168 Newman CW, Sandridge SA, Wodzisz LM. Longitudinal benefit from and satisfaction with the Baha system for patients with acquired unilateral sensorineural hearing loss. Otolo Neurotol. 2008;29(8):1123–31. Exclusion Code: X1.
169 Nolte A, Coninx F, Muller F, . Frequency-specific Animal Sound Test (FAST) 4: a valid method for hearing screening. Int J Pediatr Otorhinolaryngol. 2016 Feb;81:68–79. doi: 10.1016/j.ijporl.2015.12.004. PMID: 27099104. Exclusion Code: X1.26810294
170 Ou H, Perreau A, Tyler RS. Development of a shortened version of the Spatial Hearing Questionnaire (SHQ-S) for screening spatial-hearing ability. Am J Audiol. 2017 Sep 18;26(3):293–300. doi: 10.1044/2017_aja-17-0030. PMID: 28409842. Exclusion Code: X1.28738135
171 Paglialonga A, Grandori F, Tognola G. Using the speech understanding in noise (SUN) test for adult hearing screening1. American J Audiol. 2013;22(1):171–4. PMID: 23800813. Exclusion Code: X6.23800813
172 Peer S, Fagan JJ. Hearing loss in the developing world: evaluating the iPhone mobile device as a screening tool. S Afr Med J. 2015 Jan;105(1):35–9. PMID: 24754265. Exclusion Code: X1.26046161
173 Pok SM, Schlogel M, Boheim K. Clinical experience with the active middle ear implant Vibrant Soundbridge in sensorineural hearing loss. Adv Otorhinolaryngol. 2010;69:51–8. doi: 10.1159/000318522. PMID: 20601918. Exclusion Code: X4.20610914
174 Potgieter JM, Swanepoel de W, Myburgh HC, . Development and validation of a smartphone-based digits-in-noise hearing test in South African English. Int J Audiol. 2015 Jul;55(7):405–11. doi: 10.3109/14992027.2016.1172269. PMID: 25318685. Exclusion Code: X1.27121117
175 Potgieter JM, Swanepoel W, Myburgh HC, . The South African English Smartphone Digits-in-Noise Hearing Test: Effect of Age, Hearing Loss, and Speaking Competence. Ear Hear. 2018 Jul/Aug;39(4):656–63. doi: 10.1097/aud.0000000000000522. PMID: 29914318. Exclusion Code: X1.29189432
176 Potgieter JM, Swanepoel W, Smits C. Evaluating a smartphone digits-in-noise test as part of the audiometric test battery. S Afr J Commun Disord. 2018 May 21;65(1):e1–e6. doi: 10.4102/sajcd.v65i1.574. PMID: 29211163. Exclusion Code: X2.29211163
177 Ranganathan B, Counter P, Johnson I. Validation of self-reported hearing loss using television volume. J Laryngol Otol. 2011 Jan;125(1):18–21. doi: 10.1017/s0022215110001210. PMID: 22154204. Exclusion Code: X1.20831845
178 Ray J, Popli G, Fell G. Association of Cognition and Age-Related Hearing Impairment in the English Longitudinal Study of Ageing. JAMA Otolaryngol Head Neck Surg. 2018 Oct 1;144(10):876–82. doi: 10.1001/jamaoto.2018.1656. PMID: 30193368. Exclusion Code: X6.30193368
179 Rigters SC, van der Schroeff MP, Papageorgiou G, . Progression of Hearing Loss in the Aging Population: Repeated Auditory Measurements in the Rotterdam Study. Audiol Neurootol. 2018;23(5):290–7. doi: 10.1159/000492203. PMID: 30537711. Exclusion Code: X4.30537711
180 Rosso M, Agius R, Calleja N. Development and validation of a screening questionnaire for noise-induced hearing loss. Occup Med (Lond). 2011 Sep;61(6):416–21. doi: 10.1093/occmed/kqr059. PMID: 22292257. Exclusion Code: X1.21846812
181 Rumalla K, Karim AM, Hullar TE. The effect of hearing aids on postural stability. Laryngoscope. 2015 Mar;125(3):720–3. doi: 10.1002/lary.24974. PMID: 25490724. Exclusion Code: X1.25346316
182 Sacco G, Gonfrier S, Teboul B, . Clinical evaluation of an over-the-counter hearing aid (TEO First(R)) in elderly patients suffering of mild to moderate hearing loss. BMC Geriatr. 2016 Jul 9;16:136. doi: 10.1186/s12877-016-0304-4. PMID: 27040356. Exclusion Code: X4.27392722
183 Saliba I, Calmels M-N, Wanna G, . Binaurality in middle ear implant recipients using contralateral digital hearing AIDS. Otology & neurotology : official publication of the American Otological Society, American Neurotology Society [and] European Academy of Otology and Neurotology. 2005;26(4):680–5. Exclusion Code: X4.
184 Salonen J, Johansson R, Karjalainen S, . Relationship between self-reported hearing and measured hearing impairment in an elderly population in Finland. Int J Audiol. 2011;50(5):297–302. doi: 10.3109/14992027.2010.549517. Exclusion Code: X10.21303228
185 Samelli AG, Rabelo CM, Sanches SGG, . Tablet-Based Hearing Screening Test. Telemed J E Health. 2017;23(9):747–52. doi: 10.1089/tmj.2016.0253. PMID: CN-01604685. Exclusion Code: X1.28328389
186 Sandstrom J, Swanepoel de W, Carel Myburgh H, . Smartphone threshold audiometry in underserved primary health-care contexts. Int J Audiol. 2016;55(4):232–8. doi: 10.3109/14992027.2015.1124294. PMID: 27383734. Exclusion Code: X1.26795898
187 Saunders GH, Frederick MT, Silverman SC, . Hearing Screening in the Community. J Am Acad Audiol. 2019;30(2):145–52. doi: 10.3766/jaaa.17103. PMID: 30461404. Exclusion Code: X4.30461404
188 Saunders GH, Smith SL, Chisolm TH, . A randomized control trial: supplementing hearing aid use with listening and communication enhancement (LACE) auditory training. Ear Hear. 2016 Jul–Aug;37(4):381–96. doi: 10.1097/aud.0000000000000283. PMID: 26542290. Exclusion Code: X1.26901263
189 Schmuziger N, Schimmann F, àWengen D, . Long-term assessment after implantation of the Vibrant Soundbridge device. Otol Neurotol. 2006;27(2):183–8. Exclusion Code: X4.16436987
190 Schneider J, Dunsmore M, McMahon CM, . Improving access to hearing services for people with low vision: piloting a “hearing screening and education model” of intervention. Ear Hear. 2014;35(4):e153–e61. doi: 10.1097/AUD.0000000000000038. Exclusion Code: X1.24852681
191 Sheikh Rashid M, Dreschler WA. Accuracy of an internet-based speech-in-noise hearing screening test for high-frequency hearing loss: incorporating automatic conditional rescreening. Int Arch Occup Environ Health. 2018 Oct;91(7):877–85. doi: 10.1007/s00420-018-1332-5. PMID: 30198461. Exclusion Code: X1.29959525
192 Sheikh Rashid M, Leensen MC, de Laat JA, . Cross-sectional evaluation of an internet-based hearing screening test in an occupational setting. Scand J Work Environ Health. 2017 May 1;43(3):279–86. doi: 10.5271/sjweh.3629. PMID: 28445580. Exclusion Code: X1.28273319
193 Sheikh Rashid M, Leensen MCJ, de Laat J, . Laboratory evaluation of an optimised internet-based speech-in-noise test for occupational high-frequency hearing loss screening: occupational earcheck. Int J Audiol. 2017 Nov;56(11):844–53. doi: 10.1080/14992027.2017.1333634. PMID: 29530429. Exclusion Code: X1.28587489
194 Smith PA, Davis AC, Pronk M, . Adult hearing screening: what comes next? Int J Audiol. 2011;50(9):610–2. doi: 10.3109/14992027.2011.585668. Exclusion Code: X7.21846168
195 Smits C, Kapteyn TS, Houtgast T. Development and validation of an automatic speech-in-noise screening test by telephone. Int J Audiol. 2004;43(1):15–28. Exclusion Code: X4.14974624
196 Smits C, Merkus P, Houtgast T. How we do it: the Dutch functional hearing-screening tests by telephone and internet. Clin Otolaryngol. 2006;31(5):436–40. Exclusion Code: X3.17014457
197 Snik AF, Cremers CW. Vibrant semi-implantable hearing device with digital sound processing: effective gain and speech perception. Arch Otolaryngol Head Neck Surg. 2001;127(12):1433–7. Exclusion Code: X4.11735810
198 Storey KK, Munoz K, Nelson L, . Ambient noise impact on accuracy of automated hearing assessment. Int J Audiol. 2014 Oct;53(10):730–6. doi: 10.3109/14992027.2014.920110. PMID: 24452772. Exclusion Code: X3.24909592
199 Strawbridge WJ, Wallhagen MI. Simple tests compare well with a hand-held audiometer for hearing loss screening in primary care. J Am Geriatr Soc. 2017 Oct;65(10):2282–4. doi: 10.1111/jgs.15044. PMID: 28799200. Exclusion Code: X4.28799200
200 Swanepoel de W, Mngemane S, Molemong S, . Hearing assessment-reliability, accuracy, and efficiency of automated audiometry. Telemed J E Health. 2010 Jun;16(5):557–63. doi: 10.1089/tmj.2009.0143. PMID: 19772907. Exclusion Code: X2.20575723
201 Szudek J, Ostevik A, Dziegielewski P, . Can Uhear me now? Validation of an iPod-based hearing loss screening test. J Otolaryngol Head Neck Surg. 2012 Apr;41 Suppl 1:S78–84. PMID: 23203954. Exclusion Code: X1.22569055
202 Thammaiah S, Manchaiah V, Easwar V, . Psychometric properties of the hearing handicap questionnaire: a Kannada (South-Indian) translation. Int J Audiol. 2017 Mar;56(3):194–201. doi: 10.1080/14992027.2016.1247500. PMID: 28332432. Exclusion Code: X1.27809619
203 Thirumala PD, Carnovale G, Habeych ME, . Diagnostic accuracy of brainstem auditory evoked potentials during microvascular decompression. Neurology. 2014 Nov 4;83(19):1747–52. doi: 10.1212/wnl.0000000000000961. PMID: 25354174. Exclusion Code: X1.25298303
204 Thodi C, Parazzini M, Kramer SE, . Adult hearing screening: follow-up and outcomes1. Am J Audiol. 2013 Jun;22(1):183–5. doi: 10.1044/1059-0889(2013/12-0060). PMID: 23886428. Exclusion Code: X4.23800816
205 Thompson GP, Sladen DP, Borst BJ, . Accuracy of a tablet audiometer for measuring behavioral hearing thresholds in a clinical population. Otolaryngol Head Neck Surg. 2015 Nov;153(5):838–42. doi: 10.1177/0194599815593737. PMID: 26810294. Exclusion Code: X1.26183518
206 Todt I, Seidl RO, Ernst A. Hearing benefit of patients after Vibrant Soundbridge implantation. ORL J Otorhinolaryngol Relat Spec. 2005;67(4):203–6. Exclusion Code: X4.16088247
207 Todt I, Seidl RO, Gross M, . Comparison of different vibrant soundbridge audioprocessors with conventional hearing AIDS. Otol Neurotol. 2002;23(5):669–73. Exclusion Code: X4.12218618
208 Tolson D, Swan I, Knussen C. Hearing disability: a source of distress for older people and carers. Br J Nurs. 2002 Aug 8–Sep 11;11(15):1021–5. doi: 10.12968/bjon.2002.11.15.10529. PMID: 12181509. Exclusion Code: X4.12181509
209 Two Pi Signalprocessing Applications. Study of selffit mobile medical app for hearing loss diagnostics and hearing device fitting / fine tuning (SelfFit). 2013 Jun 13. In ClinicalTrials.gov. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT01877317. ClinicalTrials.gov Identifier: NCT01877317. Exclusion Code: X3.
210 U. S. Department of Veterans Affairs. Audiology visits after screening for hearing loss: an RCT. 2006 Mar 17. In ClinicalTrials.gov. Bethesda, MD: National Library of Medicine. 2000-. Available from: https://ClinicalTrials.gov/show/NCT00105742. ClinicalTrials.gov Identifier: NCT00105742. Exclusion Code: X3.
211 Uy J, Forciea MA. In the clinic. Hearing loss. Ann Intern Med. 2013 Apr 2;158(7):ITC4–1; quiz ITC4-16. doi: 10.7326/0003-4819-158-7-201304020-01004. PMID: 23546583. Exclusion Code: X7.23546583
212 Uziel A, Mondain M, Hagen P, . Rehabilitation for high-frequency sensorineural hearing impairment in adults with the Symphonix Vibrant Soundbridge: a comparative study. Otol Neurotol. 2003;24(5):775–83. Exclusion Code: X1.14501456
213 van den Berg PJ, Prins A, Verschuure H, . Effectiveness of a single and a repeated screen for hearing loss in the elderly. Audiology : official organ of the International Society of Audiology. 1999;38(6):339–40. Exclusion Code: X2.10582536
214 van Tonder J, Swanepoel W, Mahomed-Asmail F, . Automated smartphone threshold audiometry: validity and time efficiency. J Am Acad Audiol. 2017 Mar;28(3):200–8. doi: 10.3766/jaaa.16002. PMID: 28025906. Exclusion Code: X1.28277211
215 Venail F, Legris E, Vaerenberg B, . Validation of the French-language version of the OTOSPEECH automated scoring software package for speech audiometry. Eur Ann Otorhinolaryngol Head Neck Dis. 2016 Apr;133(2):101–6. doi: 10.1016/j.anorl.2016.01.001. PMID: 26614048. Exclusion Code: X2.26879579
216 Vermiglio AJ, Soli SD, Freed DJ, . The relationship between high-frequency pure-tone hearing loss, hearing in noise test (HINT) thresholds, and the articulation index. J Am Acad Audiol. 2012 Nov–Dec;23(10):779–88. doi: 10.3766/jaaa.23.10.4. PMID: 21909024. Exclusion Code: X1.23169195
217 Vitale C, Marcelli V, Abate T, . Speech discrimination is impaired in parkinsonian patients: Expanding the audiologic findings of Parkinson’s disease. Parkinsonism Relat Disord. 2016 Jan;22 Suppl 1:S138–43. doi: 10.1016/j.parkreldis.2015.09.040. PMID: 27166767. Exclusion Code: X4.26421391
218 von Gablenz P, Otto-Sobotka F, Holube I. Adjusting Expectations: Hearing Abilities in a Population-Based Sample Using an SSQ Short Form. Trends Hear. 2018 Jan–Dec;22:2331216518784837. doi: 10.1177/2331216518784837. PMID: 28964301. Exclusion Code: X3.30022731
219 Vyskocil E, Riss D, Arnoldner C, . Dura and sinus compression with a transcutaneous bone conduction device - hearing outcomes and safety in 38 patients. Clin Otolaryngol. 2017 Oct;42(5):1033–8. doi: 10.1111/coa.12793. PMID: 27860393. Exclusion Code: X6.27860393
220 Wadhera R, Hernot S, Gulati SP, . A controlled comparison of auditory steady-state responses and pure-tone audiometry in patients with hearing loss. Ear Nose Throat J. 2017 Oct–Nov;96(10–11):E47–e52. PMID: 29121385. Exclusion Code: X1.29121385
221 Wattamwar K, Qian ZJ, Otter J, . Increases in the rate of age-related hearing loss in the older old. JAMA Otolaryngol Head Neck Surg. 2017 Jan 1;143(1):41–5. doi: 10.1001/jamaoto.2016.2661. PMID: 27751619. Exclusion Code: X3.27632707
222 Weener DJ, Zacharek MA, Malani PN. Evaluation and management of hearing loss in older adults. Clin Geriatr. 2010;18(10):20–6. Exclusion Code: X7.
223 Weineland SM, Andersson G, Lunner T, . Bridging the gap between hearing screening and successful rehabilitation: research protocol of a randomized controlled trial of motivational interviewing via Internet. Am J Audiol. 2015 Sep;24(3):302–6. doi: 10.1044/2015_aja-15-0012. PMID: 24060253. Exclusion Code: X3.26649535
224 Weinstein BE. Validity of a screening protocol for identifying elderly people with hearing problems. ASHA. 1986 May;28(5):41–5. PMID: 3718608. Exclusion Code: X10.3718608
225 Weinstein BE. Tool kit for screening otologic function of older adults. American J Audiol. 2013;22(1):179–82. Exclusion Code: X3.
226 Weinstein BE, Rasheedy D, Taha HM, . Cross-cultural adaptation of an Arabic version of the 10-item hearing handicap inventory. Int J Audiol. 2015 May;54(5):341–6. doi: 10.3109/14992027.2014.996827. PMID: 27176657. Exclusion Code: X9.25735202
227 Whitton JP, Hancock KE, Shannon JM, . Validation of a self-administered audiometry application: an equivalence study. Laryngoscope. 2016 Oct;126(10):2382–8. doi: 10.1002/lary.25988. PMID: 27414242. Exclusion Code: X2.27140227
228 Wilson RH. Clinical experience with the words-in-noise test on 3430 veterans: comparisons with pure-tone thresholds and word recognition in quiet. J Am Acad Audiol. 2011 Jul–Aug;22(7):405–23. doi: 10.3766/jaaa.22.7.3. PMID: 21812636. Exclusion Code: X2.21993048
229 Wilson RH, Watts KL. The Words-in-Noise Test (WIN), list 3: a practice list. J Am Acad Audiol. 2012 Feb;23(2):92–6. doi: 10.3766/jaaa.23.2.3. PMID: 20689028. Exclusion Code: X1.22353677
230 Wu YH, Bentler RA. Clinical measures of hearing aid directivity: assumption, accuracy, and reliability. Ear Hear. 2012 Jan–Feb;33(1):44–56. doi: 10.1097/AUD.0b013e3182292107. PMID: 22340749. Exclusion Code: X2.21826003
231 Wu YH, Ho HC, Hsiao SH, . Predicting three-month and 12-month post-fitting real-world hearing-aid outcome using pre-fitting acceptable noise level (ANL). Int J Audiol. 2016;55(5):285–94. doi: 10.3109/14992027.2015.1120892. PMID: 25975623. Exclusion Code: X2.26878163
232 Xu J, Galster J, Galster E, . Using the device-oriented subjective outcome (DOSO) scale to measure outcomes of different hearing aids. Int J Audiol. 2018 Aug;57(8):584–91. doi: 10.1080/14992027.2018.1449972. PMID: 31721925. Exclusion Code: X6.29621924
233 Yeung JC, Heley S, Beauregard Y, . Self-administered hearing loss screening using an interactive, tablet play audiometer with ear bud headphones. Int J Pediatr Otorhinolaryngol. 2015;79(8):1248–52. doi: 10.1016/j.ijporl.2015.05.021. PMID: CN-01085849. Exclusion Code: X1.26055197
234 Yimtae K, Kasemsiri P, Thanawirattananit P, . Validation of the Thai five-minute hearing test to screen hearing loss in the community. Audiol Neurootol. 2014;19(2):127–34. doi: 10.1159/000357492. PMID: 24047948. Exclusion Code: X3.24457423
235 Yu J, Ostevik A, Hodgetts B, . Automated hearing tests: applying the otogram to patients who are difficult to test. J Otolaryngol Head Neck Surg. 2011 Oct;40(5):376–83. PMID: 21206364. Exclusion Code: X1.22420392
236 Yueh B, Shekelle P. Quality indicators for the care of hearing loss in vulnerable elders. J Am Geriatr Soc. 2007 Oct;55 Suppl 2:S335–9. doi: 10.1111/j.1532-5415.2007.01340.x. PMID: 17910555. Exclusion Code: X6.17910555