# Appendix B Additional Methods Information

## Appendix B1 Original Search Strategies

PubMed, 2/8/2019

Total Unduplicated Yield = 3,680

Screening Benefits (KQ 1) and Harms (KQ 3) Searches

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Hearing Loss”[Mesh]) OR “Hearing Disorders”[Mesh])) AND “Mass Screening”[Mesh]) Sort by: Best Match | 2580 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((((“Randomized Controlled Trial” [Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Controlled Clinical Trial” [Publication Type]) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh])) OR “Cohort Studies”[Mesh]) OR “Comparative Study” [Publication Type] OR “Diagnostic Screening Programs”[Mesh]) Sort by: Best Match | 3808601 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #1 AND #2) Sort by: Best Match | 780 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #1 AND #2) Sort by: Best Match Filters: Publication date from 2010/01/01; Humans; English; Adult: 19+ years | 49 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)

Screening Test Accuracy (KQ 2)

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((((( “Hearing Tests/methods”[Mesh] OR “Hearing Tests/standards”[Mesh] )) OR “Presbycusis/diagnosis”[Mesh]) OR “Audiometry/methods”[Mesh]) OR “Hearing Loss/diagnosis”[Mesh]))) Sort by: Best Match | 18735 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Hearing Loss”[Mesh]) OR “Auditory Perception”[Mesh]) AND ((“Mass Screening/methods”[Mesh]) OR “Sensitivity and Specificity”[Mesh]) Sort by: Best Match | 2911 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Hearing Loss/diagnosis”[Mesh])) AND ((((“smartphone”[MeSH Terms]) OR “computers, handheld”[MeSH Terms]) OR “mobile applications”[MeSH Terms]) OR “telemedicine”[MeSH Terms)) Sort by: Best Match | 44 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #1 OR #2 OR #3) Sort by: Best Match | 20222 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 | Search ((((“Cross-Sectional Studies”[Mesh]) OR “Cohort Studies”[Mesh]))) OR ((“Comparative Study” [Publication Type]) OR “Validation Studies” [Publication Type]) Sort by: Best Match | 3599498 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 | Search ( #4 AND #5) Sort by: Best Match | 6210 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 | Search ( #4 AND #5) Sort by: Best Match Filters: Publication date from 2010/01/01; Humans; English; Adult: 19+ years | 1463 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)

Amplification Benefits (KQ 4) and Harms (KQ 5)

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((“Hearing Aids”[Mesh]) OR “Correction of Hearing Impairment”[Mesh]))) OR (((((“Hearing Loss”[Mesh]) OR “Hearing Disorders”[Mesh])))) OR “Auditory Perception”[Mesh])) Sort by: Best Match | 144450 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Treatment Outcome”[Mesh]) OR “Outcome Assessment (Health Care)”[Mesh]) OR “Treatment Failure”[Mesh])) OR ((((((“Health Status”[Mesh] OR “Health Status Indicators”[Mesh]) OR “Quality of Life”[Mesh])) OR “Mood Disorders”[Mesh]) OR “Social Isolation”[Mesh]) OR “Communication”[Mesh]) OR “Cognition”[Mesh] Sort by: Best Match | 1948313 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #14 AND #15) Sort by: Best Match | 30186 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((((“Randomized Controlled Trial” [Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Controlled Clinical Trial” [Publication Type]) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh])) OR ((“Comparative Study” [Publication Type]) OR ((((“Controlled Clinical Trial” [Publication Type]) OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh])))) Sort by: Best Match | 3984497 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#5 | Search ( #16 AND #17) Sort by: Best Match | 8942 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#6 | Search ( #16 AND #17) Sort by: Best Match Filters: Publication date from 2010/01/01; Humans; English; Adult: 19+ years | 2719 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)

### Cochrane Review, 2/8/2019

Yield: 9 results, 0 imported

### Cochrane Central Trials, 2/8/2019

Yield: 109 results, 18 imported

### Embase, 2/8/2019

Yield: 293 results, 109 imported

### Gray Literature Searches, 2/8/2019

ClinicalTrials.gov Searches

Yield: 46 results, 12 imported

### Update Searches

PubMed, 1/17/2020

Total Unduplicated Yield = 486

Screening Benefits (KQ 1) and Harms (KQ 3) Searches

Search | Query | Items Found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Hearing Loss”[Mesh]) OR “Hearing Disorders”[Mesh])) AND “Mass Screening”[Mesh]) Sort by: Best Match | 2671 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((((“Randomized Controlled Trial” [Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Controlled Clinical Trial” [Publication Type]) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh])) OR “Cohort Studies”[Mesh]) OR “Comparative Study” [Publication Type] OR “Diagnostic Screening Programs”[Mesh]) Sort by: Best Match | 3972502 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #1 AND #2) Sort by: Best Match | 809 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ( #1 AND #2) Sort by: Best Match Filters: Publication date from 2017/10/01; Humans; English; Adult: 19+ years | 13 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7) [underlined: (7 new)]

Screening Test Accuracy (KQ 2)

Search | Query | Items Found
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((((( “Hearing Tests/methods”[Mesh] OR “Hearing Tests/standards”[Mesh] )) OR “Presbycusis/diagnosis”[Mesh]) OR “Audiometry/methods”[Mesh]) OR “Hearing Loss/diagnosis”[Mesh])))) Sort by: Best Match | 19556 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Hearing Loss”[Mesh]) OR “Auditory Perception”[Mesh]) AND ((“Mass Screening/methods”[Mesh]) OR “Sensitivity and Specificity”[Mesh]) Sort by: Best Match | 3123 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Hearing Loss/diagnosis”[Mesh])) AND ((((“smartphone”[MeSH Terms]) OR “computers, handheld”[MeSH Terms]) OR “mobile applications”[MeSH Terms]) OR “telemedicine”[MeSH Terms)) Sort by: Best Match | 53 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #2 OR #3) Sort by: Best Match | 21154 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Cross-Sectional Studies”[Mesh]) OR “Cohort Studies”[Mesh]))) OR ((“Comparative Study” [Publication Type]) OR “Validation Studies” [Publication Type]) Sort by: Best Match | 3695778 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 AND #5) Sort by: Best Match Filters: Publication date from 2017/10/01; Humans; English; Adult: 19+ years | 382 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10) [underlined: (211 new)]

Amplification Benefits (KQ 4) and Harms (KQ 5)

Search | Query | Items Found
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((“Hearing Aids”[Mesh]) OR “Correction of Hearing Impairment”[Mesh]))) OR (((((“Hearing Loss”[Mesh]) OR “Hearing Disorders”[Mesh])))) OR “Auditory Perception”[Mesh])) Sort by: Best Match | 149817 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Treatment Outcome”[Mesh]) OR “Outcome Assessment (Health Care)”[Mesh]) OR “Treatment Failure”[Mesh])) OR ((((((“Health Status”[Mesh] OR “Health Status Indicators”[Mesh]) OR “Quality of Life”[Mesh])) OR “Mood Disorders”[Mesh]) OR “Social Isolation”[Mesh]) OR “Communication”[Mesh]) OR “Cognition”[Mesh] Sort by: Best Match | 2014572 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) Sort by: Best Match | 31713 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((((“Randomized Controlled Trial” [Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Controlled Clinical Trial” [Publication Type]) OR “Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh])) OR ((“Comparative Study” [Publication Type]) OR ((((“Controlled Clinical Trial” [Publication Type]) OR “Cohort Studies”[Mesh]) OR “Case-Control Studies”[Mesh])))) Sort by: Best Match | 4156939 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) Sort by: Best Match | 9370 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) Sort by: Best Match Filters: Publication date from 2017/10/01; Humans; English; Adult: 19+ years | 540 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9) (268 new)

### Cochrane Review, 1/17/2020

Yield: 14 results, 0 imported

### Cochrane Central Trials, 1/17/2020

Yield: 36 results, 12 imported

### Embase, 1/17/2020

Yield: 14 results, 11 imported

### Gray Literature Searches, 1/17/2020

ClinicalTrials.gov Searches

Yield: 4 results, 2 imported

## Appendix B2 Eligibility Criteria

| Include | Exclude
Populations | KQs 1-3: Adults age ≥50 years^*^ without diagnosed hearing loss, including those with comorbid depression, mild cognitive dysfunction, or diabetes; KQs 4, 5: Adults age ≥50 years^*^ diagnosed with screen-detected (or recently detected) sensorineural hearing loss or presbycusis | KQs 1-3: Adults age <50 years; adults with previously diagnosed hearing loss, adults who currently use a hearing aid (within the past 6 months), or adults with comorbid dementia; KQs 4, 5: Adults with conductive hearing loss, congenital hearing loss, sudden hearing loss, or hearing loss caused by recent noise, or adults with comorbid dementia
Screening test or intervention | KQs 1-3: Screening tests that are used, available, or feasible for use in primary care settings, including the whispered voice test, finger rub test, watch tick test, single-question screening regarding perceived hearing loss, hearing loss questionnaire, and screening audiometry (e.g., via handheld device or smartphone); KQs 4, 5: Amplification with hearing aids (any type), personal assistive listening devices, and personal sound amplification devices, with or without additional education or counseling | KQs 1-3: Screening tests that are not used or available in primary care settings; Rinne and Weber tests (i.e., tests used to distinguish between sensorineural and conductive hearing loss); evaluations of serial screening tests; KQs 4, 5: Nutritional pharmaceuticals, hearing rehabilitation alone (without amplification), and cochlear implants
Comparisons | KQs 1, 3: Screened vs. nonscreened groups; KQ 2: Eligible screening tests vs. diagnostic pure-tone audiometry testing; KQs 4, 5: Amplification vs. no intervention, wait-list control, or placebo amplification device | All KQs: No comparison; KQs 4, 5: Studies comparing two different amplification devices
Outcomes | KQs 1, 4: Hearing-related quality of life and/or function (e.g., Hearing Handicap Inventory for the Elderly), general health-related quality of life and/or function (e.g., 36-Item Short-Form Health Survey), cognitive impairment, depression, social isolation, and falls (including injuries attributed to falls); KQ 2: Sensitivity, specificity, positive and negative predictive value, positive and negative likelihood ratio, and diagnostic odds ratio; KQs 3, 5: False-positive results, overdiagnosis, labeling, anxiety, and any other significant harms | KQs 1, 4: Outcomes related to hearing aid performance and efficacy (e.g., speech intelligibility and quality of the listening experience)
Study designs | KQs 1, 4: Randomized, controlled trials and controlled cohort studies; KQ 2: Cross-sectional or cohort studies; KQs 3, 5: Randomized, controlled trials; controlled cohort studies; and case-control studies | All other study designs^†^
Setting | All KQs: Studies performed in settings generalizable to primary care, including nursing home settings; KQs 2, 4, 5: Studies performed in specialty clinics | Studies performed in occupational health settings
Country | Studies conducted in countries categorized as “Very High” on the 2018 Human Development Index (as defined by the United Nations Development Program); [underlined: “Very High” on Human Development Index]: Andorra, Argentina, Australia, Austria, Bahamas, Bahrain, Barbados, Belarus, Belgium, Brunei Darussalam, Bulgaria, Canada, Chile, Croatia, Cyprus, Czechia, Denmark, Estonia, Finland, France, Germany, Greece, Hong Kong China (SAR), Hungary, Iceland, Ireland, Israel, Italy, Japan, Kazakhstan, Korea (Republic of), Kuwait, Latvia, Liechtenstein, Lithuania, Luxembourg, Malaysia, Malta, Montenegro, Netherlands, New Zealand, Norway, Oman, Poland, Portugal, Qatar, Romania, Russian Federation, Saudi Arabia, Singapore, Slovakia, Slovenia, Spain, Sweden, Switzerland, United Arab Emirates, United Kingdom, United States, Uruguay | Studies conducted in countries not categorized as “Very High” on the 2018 Human Development Index
Language | Full text published in English | Non-English
Study quality | Good or fair | Poor (according to design-specific USPSTF criteria)

* For studies including older adults and those <50 years, we included studies that enrolled a sample with a mean age ≥50 years (or include a majority of participants ≥50 years, depending on how age is reported).

† Systematic reviews were excluded from the evidence review. However, separate searches were conducted to identify relevant systematic reviews, and the citations of all studies included in those systematic reviews were reviewed to ensure that database searches capture all relevant primary studies.

Abbreviations: KQ=key question; USPSTF=U.S. Preventive Services Task Force.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

#### Criteria

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

##### Definition of Ratings Based on Above Criteria

Good:: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair:: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.
Poor:: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^36^

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

##### Definition of Ratings Based on Above Criteria

Good:: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad-spectrum patients with and without disease.
Fair:: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor:: Has a fatal flaw, such as: uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^36^