# Appendix A Additional Background and Contextual Questions (CQs)

## Detailed Summary of Hearing Loss Prevalence

The National Health and Nutrition Examination Survey (NHANES) measures the prevalence of hearing loss among adults (ages 20 to 69 years) using audiometric measurements; based on 2011-2012 data (n=3,831), the prevalence of unilateral and bilateral speech-frequency hearing impairment (defined by pure-tone average of thresholds across 500, 1,000, 2,000, and 4,000 Hz >25 dB hearing level) was 14.1 percent.^1^ Men had nearly twice the prevalence of hearing impairment as women (18.6% vs. 9.6%, respectively). The prevalence of speech-frequency hearing loss increases significantly with age (Appendix A Table 1); prevalence was highest in adults ages 60 to 69 years (39.3%).

In adjusted multivariable analyses for bilateral speech-frequency hearing impairment, age was the major risk factor (Appendix A Table 1); compared with the reference age group (ages 20 to 29 years), the odds ratio (OR) for adults ages 60 to 69 years is 39.5 (95% confidence interval [CI], 10.5 to 149.4). Male sex (OR, 1.8 [95% CI, 1.1 to 3.0]), non-Hispanic white (OR, 2.3 [95% CI, 1.3 to 3.9]), non-Hispanic Asian race/ethnicity (OR, 2.1 [95% CI, 1.1 to 4.2]), lower educational level (less than high school: OR, 4.2 [95% CI, 2.1 to 8.5]), and heavy use of firearms (≥1,000 rounds fired: OR, 1.8 [95% CI, 1.1 to 3.0]) were also significant risk factors.^1^ Likewise, based on NHANES data from 2001-2010 (n=9,648), the prevalence of unilateral and bilateral speech-frequency hearing impairment (as defined above) increased with age regardless of severity level: mild (>25 to 40 dB), moderate (>40 to 60 dB), and severe (>60 to 80 dB) (Appendix A Table 2).^2^ Prevalence was highest in adults age ≥80 years (mild: 31.4%, moderate: 40.8%, and severe: 13.8%).

The National Health Interview Survey (NHIS) also measures prevalence of hearing loss in adults age 18 years or older based on self-reported difficulty hearing without the use of an assistive device.^3^ Estimates from the 2014-2016 NHIS data indicate that 15.9 percent of U.S. adults have hearing loss. The 2014 NHIS (N=35,697) also reports on prevalence by age category, and findings are consistent with estimates from NHANES data despite differences in measurement and age categorization.^4^ The prevalence of self-reported hearing loss was highest among adults age 70 years or older (43.2%) compared with adults age 40 to 69 years (19.0%) and 18 to 39 years (5.5%).

## Contextual Questions (CQs)

### CQ 1 Does Adherence to Hearing Aid Use Improve Health Outcomes in Adults With Screen-Detected Hearing Loss Who Are Prescribed Hearing Aids?

Older adults with hearing loss may not adhere to hearing aid use because of cosmetic or psychosocial reasons, difficulty using the hearing aids, discomfort, cost, or perceived lack of benefit. In large population-based cohort studies, among the approximately one third of older adults with hearing loss who had ever used hearing aids, 20 to 30 percent were no longer using them.^13,^ ^14^ Despite the high rate of nonuse or nonadherence to hearing aids, we found limited evidence on whether increased adherence to hearing aid use improves health outcomes among adults who are prescribed hearing aids. In one RCT (n=194) enrolling veterans (also included for KQ 4), adherence to hearing aid use was measured at 6 weeks and 4 months by self-reported hours of hearing aid use per day.^15^ At 6 weeks, 15 percent of the intervention group reported wearing their aids fewer than 4 hours daily, and 30 percent reported more than 8 hours of daily use. Participants who reported greater hours of use had greater improvements on HHIE scores (but not Quantified Denver Scale of Communication Function [QDS] scores).^15^

### CQ 2 Do Interventions to Improve Hearing Aid Adherence Improve Health Outcomes?

We identified one Cochrane review assessing RCTs of interventions designed to improve or promote hearing aid use in adults with acquired hearing loss.^16^ Primary outcomes were hearing aid use (measured as adherence or daily hours of use) and adverse effects (inappropriate advice or clinical practice, or patient complaints); secondary outcomes included quality of life, hearing handicap, hearing aid benefit, and communication. Thirty-seven RCTs (4,129 participants) were included; interventions were heterogeneous, and few (k=6) followed participants for longer than 1 year. Included studies primarily focused on self-management skills and service-delivery interventions and not specifically on increasing adherence. Two included self-management interventions reported on adherence, and neither reported on health outcomes. One included trial enrolling veterans (n=644) randomized participants to receive hearing aid visits in an individual versus group format; over 6 months, there were no significant differences in Inner EAR scores or in the number of hours per day hearing aids were worn.^17^

### CQ 3 In Adults Who Are Prescribed Hearing Aids, What Are the Potential Barriers to Obtaining Hearing Aids and Reasons for Low Uptake?

This question was motivated by the low uptake of hearing aids in the elderly^18^: of those who are age 60 or older, only 20 percent with a self-reported hearing loss use hearing aids, and 75 percent of Medicaid beneficiaries who need a hearing aid do not have one. Moreover, the one study in our review that examined the benefits of hearing screening in the elderly, the Screening for Auditory Impairment—Which Hearing Assessment Test (SAI-WHAT) trial,^19,^ ^20^ found that fewer than half of the VA participants in any arm contacted audiology services, and fewer than 10 percent of participants across the arms were fit with hearing aids and used them at the 1-year followup.

To address this question, we first examined the applicability of studies that were included in our review. One study^21^ included help-seeking, uptake, use, or satisfaction with hearing aids as part of the trial examining benefits of hearing aids. In addition, as part of our abstract and full-text review, we identified six studies^22–27^ that were relevant to address this question. In addition, we did a hand search of references in the articles and a Google Scholar search of very recent articles using the terms “hearing aid uptake,” “hearing aid use,” and “hearing aid satisfaction.” Altogether, we included 12 studies to address this question.^18,^ ^22–32^

Two studies were systematic reviews,^29,^ ^30^ one was a scoping study,^31^ three used prospective designs,^22,^ ^26,^ ^32^ and the remainder were cohort or cross sectional.^23–25,^ ^27,^ ^28,^ ^33^ Studies comprised all older adults (>60 years), or the mean age was greater than 60 years. Studies were generally located in countries ranked as very high on the Human Development Index, including the United States, United Kingdom, Australia, Norway, and Israel. In five studies, all participants had received hearing aids; the remainder included samples without hearing aids or had subgroups that varied in their hearing aid status (i.e., not sought help hearing, received a recommendation for a hearing aid but had not received one, had a hearing aid but varied in the amount of time that they used it).

Failure to Seek Help. Yueh and colleagues^19^ found that fewer than half of any of the participants in any arm of their RCT contacted audiology services following screening. Several studies have addressed the issue of why those who fail a hearing screen do not seek audiology services. In one study,^22^ 36 percent of the 193 participants who failed the telephone-based hearing screening sought professional help. Results of a followup interview identified two factors that were more common in the help-seekers: correctly recalling failing the hearing screening and considering hearing aids prior to the screening. In contrast, of the 83 non-help-seeking participants, 64 percent indicated that their hearing difficulties were not severe enough to justify further evaluation. A retrospective study^34^ of individuals presenting with hearing loss included a group who had not sought help regarding hearing impairment and a group who had sought professional help but had not availed themselves of hearing aids. As others found,^22^ the primary reason that the nonconsulters (40%) indicated for not seeking help was that they did not perceive that their hearing difficulties were bad enough. Other reasons included the experiences of others, lack of time, expense, and not a priority. In contrast, the group who had consulted hearing professionals recognized more potential benefit of hearing aids and had more activity limitations due to hearing loss. However, activity limitations did not have much influence on hearing aid uptake. Finally, a systematic review of factors influencing help-seeking and other aspects of hearing aid behaviors^30^ reported that help seeking is related to social pressure by others, personality factors of individuals seeking help (e.g., less neurotic, more pragmatic, higher internal locus of control), greater hearing loss, and perception of an impact of the loss. Although neither gender nor age was related to help-seeking, those who experienced hearing loss before retirement were more likely to seek help.

Barriers to Hearing Aid Uptake. As the RCT of screening benefit reported,^19^ fewer than 10 percent of participants in all arms were fit for a hearing aid. Studies have offered a variety of reasons for failing to get hearing aids that are financial, attitudinal and belief based, and audiologist related. Cost is one barrier indicated in several studies and reviews,^29,^ ^33^ and it may be individuals’ perception of the cost-benefit of hearing aids as much as the actual cost. Importantly, not all the studies were from the United States, where hearing aids are not currently covered by Medicare. Studies and reviews also cited pre-fitting attitudes, especially stigma, as an often-cited reason for not getting hearing aids.^22,^ ^29,^ ^30,^ ^32,^ ^34^ Wallhagen’s qualitative study^32^ concluded that stigma was a function of three interrelated factors—altered self-perception, ageism, and vanity—that not only affect the uptake of hearing aids but also affect resistance to seeking help and wearing hearing aids. Further, the presence of supportive family can mitigate the stigma. One study^35^ reported that pre-fitting expectations regarding the benefit of hearing aids and stigma along with self-rated hearing discriminated between those who declined and accepted hearing aids. Finally, one study^25^ examined experiences of the participants during their hearing evaluation, finding that audiologists’ use of complex language was significantly associated with reduced odds for obtaining hearing aids.

Failure to Use Hearing Aids. Although the SAI-WHAT trial^19^ found that most individuals across all arms who were fit with a hearing aid used them at the 1-year followup, use was low in all groups, ranging from 3.3 to 7.4 percent. Similarly, Meyer and colleagues^22^ reported that 3 percent of their sample used hearing aids for more than 1 hour per day. Because of the considerable investment in hearing aids, it is important to know why individuals do not use their hearing aids.

Studies and systematic reviews that have examined reasons for not wearing hearing aids cite fit and comfort,^23,^ ^24,^ ^31^ which includes excessive amplification and noise. Other common reasons include care and maintenance, such as difficulty replacing batteries and the cost of repairs and batteries,^24,^ ^31^ and stigma.^31,^ ^32^ In contrast, research has found that those characterized as successful hearing aid users received positive support from family and significant others,^23,^ ^33^ were confident about their ability to use the device,^23,^ ^33^ and had greater hearing loss relative to nonusers.^23,^ ^29,^ ^30,^ ^33^ Moreover, among dually eligible for Medicaid and Medicare beneficiaries with hearing aids, 27 percent had a lot of trouble hearing with their aids, and only 29 percent of them received hearing aid services,^28^ indicating that cost (of additional services such as adjustments) continues to be an issue and may lead to nonuse. Not surprisingly, individuals who are satisfied with their hearing aids are more likely to use them more frequently.^24,^ ^27^

Appendix A Table 1 Estimated Prevalence of Mild or Worse Hearing Loss in the United States by Age Category^a^

Age Group | Prevalence^b^ (%); Unilateral and Bilateral | Prevalence^b^ (%); Bilateral | Adjusted^c^ OR (95% CI); Bilateral
All adults 20-65 years | 14.1 | 7.5 | -
Ages 20-29 years | 2.2 | 0.8 | reference group
Ages 30-39 years | 3.3 | 0.9 | 1.1 (0.3 to 4.4)
Ages 40-49 years | 7.8 | 3.4 | 3.3 (0.8 to 13.3)
Ages 50-59 years | 23.1 | 11.2 | 13.4 (2.8 to 63.5)
Ages 60-69 years | 39.3 | 24.7 | 39.5 (10.5 to 149.4)

a Estimates are from 2011-2012 NHANES data.^1^

b Prevalence refers to speech-frequency hearing impairment defined by pure-tone average of thresholds across 500, 1,000, 2,000 and 4,000 Hz >25 dB hearing level in either one ear (unilateral) or both ears (bilateral).

c Adjusted for sex, race/ethnicity, education, smoking, history of hypertension, history of diabetes, past noise exposure.

Abbreviations: CI=confidence interval; OR=odds ratio.

Appendix A Table 2 Estimated Prevalence of Unilateral and Bilateral Hearing Loss in the United States by Age Category and Severity^a^

Age Group | Prevalence^b^ (%); Mild (>25 to 40 dB) | Prevalence^b^ (%); Moderate (>40 to 60 dB) | Prevalence^b^ (%); Severe (>60 to 80 dB)
Ages 20-29 years | 2.3 | 0.6 | <0.1
Ages 30-39 years | 3.5 | 1.4 | 0.3
Ages 40-49 years | 10.0 | 2.0 | 0.9
Ages 50-59 years | 21.3 | 5.5 | 0.8
Ages 60-69 years | 29.4 | 12.1 | 2.1
Ages 70-79 years | 37.5 | 21.1 | 7.5
Age ≥80 years | 31.4 | 40.8 | 13.8

a Estimates are from 2001-2010 NHANES data.^2^

b Prevalence refers to speech-frequency hearing impairment defined by pure-tone average of thresholds across 500, 1,000, 2,000, and 4,000 Hz >25 dB hearing level in either one ear (unilateral) or both ears (bilateral).

Abbreviations: dB=decibels; Hz=Hertz.

Appendix A Table 3 Screening Tests Used in Primary Care to Detect Hearing Loss in Adults

Screening Test | Description/Example
Clinical tests; - Whispered voice; - Finger rub; - Watch tick; - Digits-in-noise; - Words-in-noise | - Assesses patients’ ability to repeat a combination of words (or series of numbers) correctly that were whispered by a provider standing at different distances from the patients, such as 6 inches or 2 feet away; - Assesses patients’ ability to hear a series of finger rubs 6 inches away; - Assesses patients’ ability to hear a series of watch ticks 6 inches away; - Assesses patients’ ability to repeat digits in different amounts of signal to noise; - Assesses patients’ ability to repeat multisyllabic words in background noise
Single-question screening | Asks patients: “Do you have difficulty hearing?” or “Would you say that you have any difficulty hearing?”^5^
Screening questionnaires; - HHIE-S; - HSAQ; - Revised Five Minute Hearing Test | - A 10-item self-administered questionnaire that assesses social and emotional factors associated with hearing loss and requires about 2 minutes to complete; - A 10-item self-administered scale that assesses functional and socioemotional consequences of hearing loss; - A 15-item self-administered questionnaire that assesses functional and social effects of hearing loss
Portable audiometric devices; - AudioScope; - Audiometer Screener; - EarTrumpet consumer app; - ShoeBox professional app; - uHear | - A handheld screening instrument consisting of an otoscope with a built-in audiometer that presents tones at 0.5, 1, 2, and 4 kHz at fixed hearing level; - A portable audiometer used to obtain pure-tone thresholds; - An iOS app for self-administration that obtains thresholds at 10 frequencies (0.25 to 8 kHz); - An automated iPad audiometer for self- or clinician administration that obtains thresholds at four frequencies; - A self-administered or clinician-administered iOS app to obtain automated pure-tone hearing thresholds at six frequencies (0.25 to 6 kHz)

Abbreviations: HHIE-S=Hearing Handicap Inventory for the Elderly-Screening version; HSAQ=Hearing Self-Assessment Questionnaire.

Appendix A Table 4 Recommendations Made by Organizations Regarding Screening for Hearing Loss

Organization, Year | Population | Recommendation
Academy of Doctors of Audiology, publication year NR^6^ | All adults | Screen annually for hearing loss in adults (regardless of age) presenting with a history of smoking or diabetes or who are at risk of developing diabetes, as well as adults >60 years old who present with dementia-like symptoms.
American Academy of Family Physicians, 2012^7^ | Adults ≥50 years | Supports the USPSTF’s 2012 recommendation: Insufficient evidence to either recommend for or against screening adults age 50 years or older for hearing loss.
American Speech-Language-Hearing Association, 2006^8^ | All adults | Screen adults at least every decade through age 50 and at 3-year intervals thereafter or more frequently on exposure to noise, toxic medications, or other risk factors associated with hearing loss.
Hearing Loss Association of America, 2015^9^ | All adults | A standardized approach to screening for hearing loss should be implemented in primary health care settings and include both a subjective and objective component in all adults during routine physicals, the “Welcome to Medicare” assessment, and annual Medicare risk assessments.
National Institute for Health and Care Excellence, 2018^10^ | All adults | Schedule an audiological assessment of adults who initially present with hearing difficulties or in whom hearing difficulties are suspected.; Consider proactively screening the following specific groups for hearing loss every 2 years: (1) adults with diagnosed or suspected dementia or mild cognitive impairment and (2) adults with a diagnosed learning disability.
Royal Australian College of General Practitioners, 2016^11^ | Older adults ≥65 years | Older adults should be screened annually for hearing loss. Recommended tests include the whispered voice test, finger rub test, and a single question about hearing difficulty.
UK National Screening Committee, 2016^12^ | Older adults ≥50 years | A national screening program for hearing loss in older adults is not recommended in the UK until further research is done in the UK.

Abbreviations: NR=not reported; UK=United Kingdom; USPSTF=United States Preventive Services Task Force.