# References

1 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 4th ed. Washington, DC: American Psychiatric Association; 1994.
2 Larson E B, Kukull W A, Katzman R L. Cognitive impairment: dementia and Alzheimer's disease. Annu Rev Public Health. 1992;13:431-449. [pmid: 1599598].
3 Breteler M M, Claus J J, van Duijn C M, Launer L J, Hofman A. Epidemiology of Alzheimer's disease. Epidemiol Rev. 1992;14:59-82. [pmid: 1289117].
4 Lyketsos C G, Sheppard J M, Steele C D, et al. Randomized, placebo-controlled, double-blind clinical trial of sertraline in the treatment of depression complicating Alzheimer's disease: initial results from the Depression in Alzheimer's Disease study. Am J Psychiatry. 2000;157:1686-1689. [pmid: 11007727].
5 O'Connor D, Pollitt P, Hyde J, Brook C, Reiss B, Roth M. Do general practitioners miss dementia in elderly patients?. Br Med J. 1988;297:1107-1110. [pmid: 3143447]. [pmcid: 1834835].
6 Cooper B, Bickel H, Schaufele M. Early development and progression of dementing illness in the elderly: a general-practice based study. Psycholog Med. 1996;26:411-419.
7 Lagaay A, van der Meij J, Hijmans W. Validation of medical history taking as part of a population based survey in subjects aged 85 and over. Br Med J. 1992;304:1091-1092. [pmid: 1586823]. [pmcid: 1881900].
8 IIiffe S, Mitchley S, Gould M, Haines A. Evaluation of the use of brief screening instruments for dementia, depression and problem drinking among elderly people in general practice. Brit J Gen Pract. 1994;44:503-507. [pmid: 7748646]. [pmcid: 1239047].
9 Ernst R L, Hay J W. The US economic and social costs of Alzheimer's disease revisited. Am J Public Health. 1994;84:1261-1264. [pmid: 8059882]. [pmcid: 1615456].
10 Evans D. Estimated prevalence of Alzheimer's disease in the United States. Milbank Q. 1990;68:267-289. [pmid: 2233632].
11 van Duijn C M, Clayton D, Chandra V, et al. Familial aggregation of Alzheimer's disease and related disorders: a collaborative re-analysis of case-control studies. EURODEM Risk Factors Research Group. Int J Epidemiol. 1991;20(Suppl 2):S13-S20. [pmid: 1833349].
12 Olafsdottir M, Skoog I, Marcusson J. Detection of dementia in primary care: the Linkoping study. Dement Geriatr Cogn Disord. 2000;11:223-229. [pmid: 10867449].
13 Sternberg S A, Wolfson C, Baumgarten M. Undetected dementia in community-dwelling older people: the Canadian Study of Health and Aging. J Am Geriatr Soc. 2000;48:1430-1434. [pmid: 11083319].
14 Valcour V, Masaki K, Curb J, Blanchette P. The detection of dementia in the primary care setting. Arch Intern Med. 2000;160:2964-2968. [pmid: 11041904].
15 US Preventive Services Task Force. Screening for Dementia. Guide to Clinical Preventive Services. 2nd Ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
16 Patterson C J, Gauthier S, Bergman H, et al. The recognition, assessment and management of dementing disorders: conclusions from the Canadian Consensus Conference on Dementia. Can Med Assoc J. 1999;160:S1-S15.
17 Canadian study of health and aging: study methods and prevalence of dementia. Can Med Assoc J. 1994;150:899-913. [pmid: 8131123]. [pmcid: 1486712].
18 Evans D, Funkenstein H, Albert M, et al. Prevalence of Alzheimer's disease in a community population of older persons. Higher than previously reported. JAMA. 1989;262:2551-2556. [pmid: 2810583].
19 Office of Technology Assessment. Losing a Million Minds: Confronting the Tragedy of AD and Other Dementias. Washington, DC: US Government Printing Office; 1987.
20 General Accounting Office. Estimates of prevalence in the United States. Washington DC: US General Accounting Office; 1998;Publication HEHS98-16.
21 Evans D, Smith L, Scherr P, Albert M, Funkenstein H, Hebert L. Risk of death from Alzheimer's disease in a community population of older persons. Am J Epidemiol. 1991;134:403-412. [pmid: 1877601].
22 Brookmeyer R, Gray S, Kawas C. Projections of Alzheimer's disease in the United States and the public health impact of delaying disease onset. Am J Public Health. 1998;88:1337-1342. [pmid: 9736873]. [pmcid: 1509089].
23 Hoyert D L, Kochanek K D, Murphy S L. Deaths: final data for 1997. Natl Vital Stat Rep. 1999;47:1-104. [pmid: 10410536].
24 Wolfson C, Wolfson D, Asgharian M, et al. A reevaluation of the duration of survival after the onset of dementia. N Engl J Med. 2001;344:1111-1116. [pmid: 11297701].
25 Ganguli M. The use of screening instruments for the detection of dementia. Neuroepidemiology. 1997;16:271-280. [pmid: 9430126].
26 Brodaty H, Clarke J, Ganguli M, et al. Screening for cognitive impairment in general practice: toward a consensus. Alzheimer Dis Assoc Disord. 1998;12:1-13. [pmid: 9539404].
27 Dunkin J, Anderson-Hanley C. Dementia caregiver burden: a review of the literature and guidelines for assessment and intervention. Neurology. 1998;51:S53-S60. discussion S65–S67.
28 Schulz R, O'Brien A, Bookwala J, Fleissner K. Psychiatric and physical morbidity effects of dementia caregiving: prevalence, correlates, and causes. Gerontologist. 1995;35:771-791. [pmid: 8557205].
29 Bedard M, Pedlar D, Martin N, Malott O, Stones M. Burden in caregivers of cognitively impaired older adults living in the community: methodological issues and determinants. Int Psychogeriatr. 2000;12:307-332. [pmid: 11081952].
30 Grafstrom M, Fratiglioni L, Sandman P, Winblad B. Health and social consequences for relatives of demented and non- demented elderly. A population-based study. J Clin Epidemiol. 1992;45:861-870. [pmid: 1624968].
31 Molloy D, Lever J, Bedard M, Guyatt G, Butt G. Burden and caregivers of older adults with impaired cognition: relationship with dysfunctional behavior. Daily living and mood. Ann R Coll Physicians Surg Can. 1996;29:151-154.
32 Newens A, Forster D, Kay D. Dependency and community care in presenile Alzheimer's disease. Br J Psychiatry. 1995;166:777-782. [pmid: 7663827].
33 Swearer J M, Drachman D A, O'Donnell B F, Mitchell A L. Troublesome and disruptive behaviors in dementia. Relationships to diagnosis and disease severity. J Am Geriatr Soc. 1988;36:784-790. [pmid: 3411060].
34 Rabins P, Mace N, Lucas M. The impact of dementia on the family. JAMA. 1982;248:333-335. [pmid: 7087127].
35 Cohen C A, Gold D P, Shulman K I, Wortley J T, McDonald G, Wargon M. Factors determining the decision to institutionalize dementing individuals: a prospective study. Gerontologist. 1993;33:714-720. [pmid: 8314097].
36 Gold D P, Reis M F, Markiewicz D, Andres D. When home caregiving ends: a longitudinal study of outcomes for caregivers of relatives with dementia. J Am Geriatr Soc. 1995;43:10-16. [pmid: 7806732].
37 McFall S, Miller B H. Caregiver burden and nursing home admission of frail elderly persons. J Gerontol. 1992;47:S73-S79. [pmid: 1538078].
38 Tsuji I, Whalen S, Finucane T E. Predictors of nursing home placement in community-based long-term care. J Am Geriatr Soc. 1995;43:761-766. [pmid: 7602027].
39 Brandt J. Mild cognitive impairment in the elderly. Am Fam Physician 2001;63:620, 622, 625–626
40 Hanninen T, Hallikainen M, Koivisto K, et al. A follow-up study of age-associated memory impairment: neuropsychological predictors of dementia. J Am Geriatr Soc. 1995;43:1007-1015. [pmid: 7657916].
41 Morris J, Storandt M, Miller J, et al. Mild cognitive impairment represents early-stage Alzheimer disease. Arch Neurol. 2001;58:397-405. [pmid: 11255443].
42 Jorm A, Jolley D. The incidence of dementia: a meta-analysis. Neurology. 1998;51:728-733. [pmid: 9748017].
43 Lautenschlager N, Cupples L, Rao V, et al. Risk of dementia among relatives of Alzheimer's disease patients in the MIRAGE study: What is in store for the oldest old?. Neurology. 1996;46:641-650. [pmid: 8618660].
44 Blacker D, Tanzi R. The genetics of Alzheimer disease: current status and future prospects. Arch Neurol. 1998;55:294-296. [pmid: 9520001].
45 Lai F, Williams R. A prospective study of Alzheimer disease in Down syndrome. Arch Neurol. 1989;46:849-853. [pmid: 2527024].
46 Longstreth W Jr, Bernick C, Manolio T, Bryan N, Jungreis C, Price T. Lacunar infarcts defined by magnetic resonance imaging of 3660 elderly people: the Cardiovascular Health Study. Arch Neurol. 1998;55:1217-1225. [pmid: 9740116].
47 Hofman A, Ott A, Breteler M, et al. Atherosclerosis, apolipoprotein E, and prevalence of dementia and Alzheimer's disease in the Rotterdam Study. Lancet. 1997;349:151-154. [pmid: 9111537].
48 Skoog I, Nilsson L, Palmertz B, Andreasson L A, Svanborg A. A population-based study of dementia in 85-year-olds. N Engl J Med. 1993;328:153-158. [pmid: 8417380].
49 Folstein M F, Folstein S E, McHugh P R. “Mini-mental state”. A practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res. 1975;12:189-198. [pmid: 1202204].
50 Schulman K. Clock-drawing: is it the ideal cognitive screening test?. Int J Geriatr Psychiat. 2000;15:548-561.
51 Pfeffer R, Kurosaki T, Harrah C J, Chance J, Filos S. Measurement of functional activities in older adults in the community. J Gerontol. 1982;37:323-329. [pmid: 7069156].
52 Fuh J L, Teng E L, Lin K N, et al. The Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE) as a screening tool for dementia for a predominantly illiterate Chinese population. Neurology. 1995;45:92-96. [pmid: 7824143].
53 Barberger-Gateau P, Commenges D, Gagnon M, Letenneur L, Sauvel C, Dartigues J F. Instrumental activities of daily living as a screening tool for cognitive impairment and dementia in elderly community dwellers. J Am Geriatr Soc. 1992;40:1129-1134. [pmid: 1401698].
54 Jorm A. Assessment of cognitive impairment and dementia using informant reports. Clin Psychol Rev. 1996;16:51-73.
55 Lovestone S. Early diagnosis and the clinical genetics of Alzheimer's disease. J Neurology. 1999;246:69-72.
56 McKhann G, Drachman D, Folstein M, Katzman R, Price D, Stadlan E M. Clinical diagnosis of Alzheimer's disease: report of the NINCDS-ADRDA Work Group under the auspices of Department of Health and Human Services Task Force on Alzheimer's Disease. Neurology. 1984;34:939-944. [pmid: 6610841].
57 Cunha U G. An investigation of dementia among elderly outpatients. Acta Psychiatr Scand. 1990;82:261-263. [pmid: 2248054].
58 Ames D, Flicker L, Helme R D. A memory clinic at a geriatric hospital: rationale, routine and results from the first 100 patients. Med J Aust. 1992;156:618-622. [pmid: 1625615].
59 Massoud F, Devi G, Moroney J T, et al. The role of routine laboratory studies and neuroimaging in the diagnosis of dementia: a clinicopathological study. J Am Geriatr Soc. 2000;48:1204-1210. [pmid: 11037005].
60 Walstra G J, Teunisse S, van Gool W A, van Crevel H. Reversible dementia in elderly patients referred to a memory clinic. J Neurol. 1997;244:17-22. [pmid: 9007740].
61 Freter S, Bergman H, Gold S, Chertkow H, Clarfield A M. Prevalence of potentially reversible dementias and actual reversibility in a memory clinic cohort. Can Med Assoc J. 1998;159:657-662. [pmid: 9780965]. [pmcid: 1229695].
62 Clarfield A. The reversible dementias: do they reverse?. Ann Intern Med. 1988;109:476-486. [pmid: 3046450].
63 Conwell Y, Caine E. Rational suicide and the right to die. Reality and myth. N Engl J Med. 1991;325:1100-1103. [pmid: 1891013].
64 Rohde K, Peskind E, Raskind M. Suicide in two patients with Alzheimer's disease. J Am Geriatr Soc. 1995;43:187-189. [pmid: 7836647].
65 Harris R, Helfand M, Woolf S, et al. Current methods of the US Preventive Services Task Force: A review of the process. Am J Prev Med. 2001;2(3S):21-35.
66 Eefsting J, Boersma F, Van den Brink W, Van Tilburg W. Differences in prevalence of dementia based on community survey and general practitioner recognition. Psycholog Med. 1996;26:1223-1230.
67 Hendrie H, Osuntokun B, Hall K, et al. Prevalence of Alzheimer's disease and dementia in two communities: Nigerian Africans and African Americans. Am J Psychiatry. 1995;152:1485-1492. [pmid: 7573588].
68 White L, Petrovitch H, Ross G, et al. Prevalence of dementia in older Japanese-American men in Hawaii: The Honolulu-Asia Aging Study. JAMA. 1996;276:955-960. [pmid: 8805729].
69 Graves A, Larson E, Edland S, et al. Prevalence of dementia and its subtypes in the Japanese American population of King County, Washington state. The Kame Project. Am J Epidemiol. 1996;144:760-771. [pmid: 8857825].
70 Corrada M, Brookmeyer R, Kawas C. Sources of variability in prevalence rates of Alzheimer's disease. Int J Epidemiol. 1995;24:1000-1005. [pmid: 8557432].
71 Erkinjuntti T, Ostbye T, Steenhuis R, Hachinski V. The effect of different diagnostic criteria on the prevalence of dementia. N Engl J Med. 1997;337:1667-1674. [pmid: 9385127].
72 Breitner J C, Wyse B W, Anthony J C, et al. APOE-epsilon4 count predicts age when prevalence of AD increases, then declines: the Cache County Study. Neurology. 1999;53:321-331. [pmid: 10430421].
73 Gurland B, Wilder D, Lantigua R, et al. Rates of dementia in three ethnoracial groups. Int J Geriatr Psychiatry. 1999;14:481-493. [pmid: 10398359].
74 Larson E B, Reifler B V, Sumi S M, Canfield C G, Chinn N M. Diagnostic evaluation of 200 elderly outpatients with suspected dementia. J Gerontol. 1985;40:536-543. [pmid: 4031401].
75 Costa P T Jr,, Williams T, Somerfield M, et al. Early identification of Alzheimer's disease and related dementias. Clinical Practice Guideline, Quick Reference Guide for Clinicians, No. 19. Rockville, MD: AHCPR Publication No. 97-0703. 1996;19:1-28.
76 McDowell I, Kristjansson B, Hill G B, Hebert R. Community screening for dementia: the Mini Mental State Exam (MMSE) and Modified Mini-Mental State Exam (3MS) compared. J Clin Epidemiol. 1997;50:377-383. [pmid: 9179095].
77 Lindeboom J, Launer L J, Schmand B A, Hooyer C, Jonker C. Effects of adjustment on the case-finding potential of cognitive tests. J Clin Epidemiol. 1996;49:691-695. [pmid: 8656232].
78 Jitapunkul S, Lailert C, Worakul P, Srikiatkhachorn A, et al. Chula Mental Test: A screening test for elderly people in less developed countries. Int J Geriatr Psychiatry. 1996;11:714-720.
79 Braekhus A, Laake K, Engedal K. A low, ‘normal’ score on the Mini-Mental State Examination predicts development of dementia after three years. J Am Geriatr Soc. 1995;43:656-661. [pmid: 7775725].
80 Wilder D, Cross P, Chen J, et al. Operating characteristics of brief screens for dementia in a multicultural population. Am J Geriatric Psychiatry. 1995;3:96-107.
81 Heun R, Papassotiropoulos A, Jennssen F. The validity of psychometric instruments for detection of dementia in the elderly general population. Int J Geriatr Psychiatry. 1998;13:368-380. [pmid: 9658272].
82 Solomon P R, Brush M, Calvo V, et al. Identifying dementia in the primary care practice. Int Psychogeriatr. 2000;12:483-493. [pmid: 11263715].
83 Barberger-Gateau P, Fabrigoule C, Helmer C, Rouch I, Dartigues J. Functional impairment in instrumental activities of daily living: an early clinical sign of dementia?. J Am Geriatr Soc. 1999;47:456-462. [pmid: 10203122].
84 Law S, Wolfson C. Validation of a French version of an informant-based questionnaire as a screening test for Alzheimer's disease. Br J Psychiatry. 1995;167:541-544. [pmid: 8829727].
85 Hasselblad V, Hedges L. Meta-analysis of screening and diagnostic tests. Psychol Bull. 1995;117:167-178. [pmid: 7870860].
86 Jorm A F. Methods of screening for dementia: a meta-analysis of studies comparing an informant questionnaire with a brief cognitive test. Alzheimer Dis Assoc Disord. 1997;11:158-162. [pmid: 9305501].
87 Barberger-Gateau P, Dartigues J F, Letenneur L. Four Instrumental Activities of Daily Living Score as a predictor of one-year incident dementia. Age Ageing. 1993;22:457-463. [pmid: 8310892].
88 Stern R, Mohs R, Davidson M, et al. A longitudinal study of Alzheimer's disease: measurement, rate, and predictors of cognitive deterioration. Am J Psychiatry. 1994;151:390-396. [pmid: 8109647].
89 Weytingh M, Bossuyt P, van Crevel H. Reversible dementia: more than 10% or less than 1%? A quantitative review. J Neurol. 1995;242:466-471. [pmid: 7595679].
90 Cunha U G, Rocha F L, Peixoto J M, Motta M F, Barbosa M T. Vitamin B12 deficiency and dementia. Int Psychogeriatr. 1995;7:85-88. [pmid: 7579024].
91 Eastley R, Wilcock G K, Bucks R S. Vitamin B12 deficiency in dementia and cognitive impairment: the effects of treatment on neuropsychological function. Int J Geriatr Psychiatry. 2000;15:226-233. [pmid: 10713580].
92 Larson E B, Reifler B V, Featherstone H J, English D R. Dementia in elderly outpatients: a prospective study. Ann Intern Med. 1984;100:417-423. [pmid: 6696360].
93 Winblad B, Engedal K, Soininen H, et al. A 1-year, randomized, placebo-controlled study of donepezil in patients with mild to moderate AD. Neurology. 2001;57:489-495. [pmid: 11502918].
94 Devanand D, Marder K, Michaels K, et al. A randomized, placebo-controlled dose-comparison trial of haloperidol for psychosis and disruptive behaviors in Alzheimer's disease. Am J Psychiatry. 1998;155:1512-1520. [pmid: 9812111].
95 Mohs R, Doody R, Morris J, Rogers S, Pratt R. Donepezil preserves functional status in Alzheimer's disease patients: Results from a 1-year prospective placebo-controlled functional survival study. Neurology. 2001.
96 Wilcock G, Lilienfeld S, Gaens E. Efficacy and safety of galantamine in patients with mild to moderate Alzheimer's disease: multicentre randomised controlled trial. Galantamine International-1 Study Group. Be Med J. 2000;321:1445-1449.
97 Raskind M, Peskind E, Wessel T, Yuan W. Galantamine in AD: A 6-month randomized, placebo-controlled trial with a 6-month extension. The Galantamine USA-1 Study Group. Neurology. 2000;54:2261-2268. [pmid: 10881250].
98 Tariot P, Solomon P, Morris J, Kershaw P, Lilienfeld S, Ding C. A 5-month, randomized, placebo-controlled trial of galantamine in AD. The Galantamine USA-10 Study Group. Neurology. 2000;54:2269-2276. [pmid: 10881251].
99 Burns A, Rossor M, Hecker J, et al. The effects of donepezil in Alzheimer's disease - results from a multinational trial. Dement Geriatr Cogn Disord. 1999;10:237-244. [pmid: 10325453].
100 Greenberg S, Tennis M, Brown L, et al. Donepezil therapy in clinical practice: a randomized crossover study. Arch Neurol. 2000;57:94-99. [pmid: 10634454].
101 Rosler M, Anand R, Cicin-Sain A, et al. Efficacy and safety of rivastigmine in patients with Alzheimer's disease: international randomised controlled trial. Br Med J. 1999;318:633-638. [pmid: 10066203].
102 McKeith I, Del Ser T, Spano P, et al. Efficacy of rivastigmine in dementia with Lewy bodies: a randomised, double-blind, placebo-controlled international study. Lancet. 2000;356:2031-2036. [pmid: 11145488].
103 Sano M, Ernesto C, Thomas R G, et al. A controlled trial of selegiline, alpha-tocopherol, or both as treatment for Alzheimer's disease. The Alzheimer's Disease Cooperative Study. N Engl J Med. 1997;336:1216-1222. [pmid: 9110909].
104 Pantoni L, Rossi R, Inzitari D, et al. Efficacy and safety of nimodipine in subcortical vascular dementia: a subgroup analysis of the Scandinavian Multi-Infarct Dementia Trial. J Neurol Sci. 2000;175:124-134. [pmid: 10831773].
105 Mulnard R A, Cotman C W, Kawas C, et al. Estrogen replacement therapy for treatment of mild to moderate Alzheimer disease: a randomized controlled trial. Alzheimer's Disease Cooperative Study. JAMA. 2000;283:1007-1015. [pmid: 10697060].
106 Le Bars P, Katz M, Berman N, Itil T, Freedman A, Schatzberg A. A placebo-controlled, double-blind, randomized trial of an extract of Ginkgo biloba for dementia. North American EGb Study Group. JAMA. 1997;278:1327-1332. [pmid: 9343463].
107 Maurer K, Ihl R, Dierks T, Frolich L. Clinical efficacy of Ginkgo biloba special extract EGb 761 in dementia of the Alzheimer type. J Psychiatr Res. 1997;31:645-655. [pmid: 9447569].
108 Aisen P, Davis K, Berg J, et al. A randomized controlled trial of prednisone in Alzheimer's disease. Alzheimer's Disease Cooperative Study. Neurology. 2000;54:588-593. [pmid: 10680787].
109 Scharf S, Mander A, Ugoni A, Vajda F, Christophidis N. A double-blind, placebo-controlled trial of diclofenac/misoprostol in Alzheimer's disease. Neurology. 1999;53:197-201. [pmid: 10408559].
110 Auchus A, Bissey-Black C. Pilot study of haloperidol, fluoxetine, and placebo for agitation in Alzheimer's disease. J Neuropsychiatry Clin Neurosci. 1997;9:591-593. [pmid: 9447502].
111 Petracca G, Teson A, Chemerinski E, Leiguarda R, Starkstein S. A double-blind placebo-controlled study of clomipramine in depressed patients with Alzheimer's disease. J Neuropsychiatry Clin Neurosci. 1996;8:270-275. [pmid: 8854297].
112 Wilkinson D, Murray J. Galantamine: a randomized, double-blind, dose comparison in patients with Alzheimer's disease. Int J Geriatr Psychiatry. 2001;16:852-857. [pmid: 11571763].
113 Teri L, Logsdon R G, Peskind E, et al. Treatment of agitation in AD: a randomized, placebo-controlled clinical trial. Neurology. 2000;55:1271-1278. [pmid: 11087767].
114 Asthana S, Baker L D, Craft S, et al. High-dose estradiol improves cognition for women with AD: results of a randomized study. Neurology. 2001;57:605-612. [pmid: 11524467].
115 Birks J, Iakovidou V, Tsolaki M. Rivastigmine for Alzheimer's disease (Cochrane Review). Cochrane Database Syst Rev. 2000;CD001191.
116 Birks J, Flicker L. Selegiline for Alzheimer's disease (Cochrane Review). Cochrane Database Syst Rev. 2000;CD000442.
117 Williams P, Rands G, Orrel M, Spector A. Aspirin for vascular dementia. Cochrane Database Syst Rev. 2000;CD001296.
118 Oken B, Storzbach D, Kaye J. The efficacy of Ginkgo biloba on cognitive function in Alzheimer disease. Arch Neurol. 1998;55:1409-1415. [pmid: 9823823].
119 Birks J, Melzer D, Beppu H. Donepezil for mild and moderate Alzheimer's disease (Cochrane Review). Cochrane Database Syst Rev. 2000;CD001190.
120 Qizilbash N, Birks J, Lopez A, Lewington S, Szeto S. Tacrine for Alzheimer's disease. [update of: 20257597] (Cochrane Review). Cochrane Database Syst Rev. 2000;CD000202.
121 Qizilbash N, Whitehead A, Higgins J, Wilcock G, Schneider L, Farlow M. Cholinesterase inhibition for Alzheimer disease: a meta-analysis of the tacrine trials. Dementia Trialists' Collaboration. JAMA. 1998;280:1777-1782. [pmid: 9842955].
122 Lanctot K, Best T, Mittmann N, et al. Efficacy and safety of neuroleptics in behavioral disorders associated with dementia. J Clin Psychiatry. 1998;59:550-561. quiz 562–563. [pmid: 9818639].
123 Burns A, Jacoby R, Levy R. Psychiatric phenomena in Alzheimer's disease. I: Disorders of thought content. Br J Psychiatry. 1990;157:72-76. 92–94. [pmid: 2397365].
124 Davidson M, Weiser M, Soares K. Novel antipsychotics in the treatment of psychosis and aggression associated with dementia: A meta-analysis of randomized controlled clinical trials. Int Psychogeriatr. 2000;12:271-277.
125 Kirchner V, Kelly C, Harvey R. Thioridazine for dementia (Cochrane Review). Cochrane Database Syst Rev. 2000;CD000464.
126 Demers L, Oremus M, Perrault A, Wolfson C. Review of outcome measurement instruments in Alzheimer's disease drug trials: introduction. J Geriatr Psychiatry Neurol. 2000;13:161-169. [pmid: 11128056].
127 Rosen W G, Mohs R C, Davis K L. A new rating scale for Alzheimer's disease. Am J Psychiatry. 1984;141:1356-1364. [pmid: 6496779].
128 Mohs R C, Knopman D, Petersen R C, et al. Development of cognitive instruments for use in clinical trials of antidementia drugs: additions to the Alzheimer's Disease Assessment Scale that broaden its scope. The Alzheimer's Disease Cooperative Study. Alzheimer Dis Assoc Disord. 1997;11(Suppl 2):S13-S21. [pmid: 9236948].
129 McDowell I, Newell C; Measuring Health. A Guide to Rating Scales and Questionnares. Second ed. Oxford: Oxford University Press; 1996.
130 Solomon P, Adams F, Groccia M, DeVeaux R, Growdon J, Pendlebury W. Correlational analysis of five commonly used measures of mental status/functional abilities in patients with Alzheimer disease. Alzheimer Dis Assoc Disord. 1999;13:147-150. [pmid: 10485573].
131 Doraiswamy P M, Bieber F, Kaiser L, Krishnan K R, Reuning-Scherer J, Gulanski B. The Alzheimer's Disease Assessment Scale: patterns and predictors of baseline cognitive performance in multicenter Alzheimer's disease trials. Neurology. 1997;48:1511-1517. [pmid: 9191757].
132 Vitaliano P P, Breen A R, Albert M S, Russo J, Prinz P N. Memory, attention, and functional status in community-residing Alzheimer type dementia patients and optimally healthy aged individuals. J Gerontol. 1984;39:58-64. [pmid: 6690588].
133 Perry R J, Hodges J R. Relationship between functional and neuropsychological performance in early Alzheimer disease. Alzheimer Dis Assoc Disord. 2000;14:1-10. [pmid: 10718199].
134 McLendon B M, Doraiswamy P M. Defining meaningful change in Alzheimer's disease trials: the donepezil experience. J Geriatr Psychiatry Neurol. 1999;12:39-48. [pmid: 10447153].
135 Reisberg B, Schneider L, Doody R, et al. Clinical global measures of dementia. Position paper from the International Working Group on Harmonization of Dementia Drug Guidelines. Alzheimer Dis Assoc Disord. 1997;11(Suppl 3):8-18. [pmid: 9305508].
136 Katz S, Downs T D, Cash H R, Grotz R C. Progress in development of the index of ADL. Gerontologist. 1970;10:20-30. [pmid: 5420677].
137 Lawton M P, Brody E M. Assessment of older people: self-maintaining and instrumental activities of daily living. Gerontologist. 1969;9:179-186. [pmid: 5349366].
138 Cohen-Mansfield J. Agitated behaviors in the elderly. II. Preliminary results in the cognitively deteriorated. J Am Geriatr Soc. 1986;34:722-727. [pmid: 3760436].
139 Nasr S, Osterweil D. The nonpharacologic management of agitation in the nursing home: a concensus approach. Annals of Long-Term Care. 1999;7:171-180.
140 Perrault A, Oremus M, Demers L, Vida S, Wolfson C. Review of outcome measurement instruments in Alzheimer's disease drug trials: psychometric properties of behavior and mood scales. J Geriatr Psychiatry Neurol. 2000;13:181-196. [pmid: 11128058].
141 Haupt M, Kurz A, Janner M. A 2-year follow-up of behavioural and psychological symptoms in Alzheimer's disease. Dement Geriatr Cogn Disord. 2000;11:147-152. [pmid: 10765045].
142 Devanand D P, Folz M, Gorlyn M, Moeller J R, Stern Y. Questionable dementia: clinical course and predictors of outcome. J Am Geriatr Soc. 1997;45:321-328. [pmid: 9063278].
143 Lyketsos C, Steinberg M, Tschanz J, Norton M, Steffens D, Breitner J. Mental and behavioral disturbances in dementia: findings from the Cache County Study on Memory in Aging. Am J Psychiatry. 2000;157:708-714. [pmid: 10784462].
144 Lyketsos C. Clincal Aspects of Aging , 5th Ed. Oxford : Oxford University Press; 1999.
145 Hamel M, Gold D, Andres D, et al. Predictors and consequences of aggressive behavior by community-based dementia patients. Gerontologist. 1990;30:206-211. [pmid: 2347502].
146 Kramer-Ginsberg E, Mohs R C, Aryan M, et al. Clinical predictors of course for Alzheimer patients in a longitudinal study: a preliminary report. Psychopharmacol Bull. 1988;24:458-462. [pmid: 3153508].
147 Brooks J O 3rd, Yesavage J A, Taylor J, et al. Cognitive decline in Alzheimer's disease: elaborating on the nature of the longitudinal factor structure of the Mini-Mental State Examination. Int Psychogeriatr. 1993;5:135-146. [pmid: 8292767].
148 Salmon D P, Thal L J, Butters N, Heindel W C. Longitudinal evaluation of dementia of the Alzheimer type: a comparison of 3 standardized mental status examinations. Neurology. 1990;40:1225-1230. [pmid: 2381530].
149 Food and Drug Administration; Peripheral and central nervous system drugs advisory committee meeting. Rockville, MD: Dept. of Health and Human Services, Public Health Service; 1989;227.
150 Mastey V, Wimo A, Winblad B, et al. An economic evaluation of donepezil in mild to moderate Alzheimer's disease; reults of a one-year, double-blind, randomized trial. Chicago: American Geriatric Society meeting ; 2001.
151 Forbes D. Strategies for managing behavioural symptomatology associated with dementia of the Alzheimer type: a systematic overview. Can J Nurs Res. 1998;30:67-86. [pmid: 9807289].
152 Friedman R, Tappen R M. The effect of planned walking on communication in Alzheimer's disease. J Am Geriatr Soc. 1991;39:650-654. [pmid: 2061529].
153 Rosswurm M. Attention-focusing program for persons with dementia. Clin Gerontologist. 1991;10(2):3-16.
154 Tappen R M. The effect of skill training on functional abilities of nursing home residents with dementia. Res Nurs Health. 1994;17:159-165. [pmid: 8184127]. [pmcid: 1952655].
155 Opie J, Rosewarne R, O'Connor D. The efficacy of psychosocial approaches to behaviour disorders in dementia: a systematic literature review. Aust N Z J Psychiatry. 1999;33:789-799. [pmid: 10619204].
156 Rovner B W, Steele C D, Shmuely Y, Folstein M F. A randomized trial of dementia care in nursing homes. J Am Geriatr Soc. 1996;44:7-13. [pmid: 8537594].
157 Hinchliffe A, Hyman I, Blizard B, Livingston G. Behavioural complications of dementia - can they be treated?. Int J Geriatr Psychiatry. 1995;10:839-847.
158 Burgener S C, Bakas T, Murray C, Dunahee J, Tossey S. Effective caregiving approaches for patients with Alzheimer's disease. Geriatr Nurs. 1998;19:121-126. [pmid: 9708136].
159 Robichaud L, Hebert R, Desrosiers J. Efficacy of a sensory integration program on behaviors of inpatients with dementia. Am J Occup Ther. 1994;48:355-60. [pmid: 8059869].
160 Koger S, Brotons M. Music therapy for dementia symptoms (Cochrane Review). Cochrane Database Syst Rev. 2000;CD001121.
161 Neal M, Briggs M. Validation therapy for dementia (Cochrane Review). Cochrane Database Syst Rev. 2000;2.
162 Spector A, Orrell M, Mavies S, Woods R. Reminiscence therapy for dementia.Cochrane Database Syst Rev. 2000;4.
163 Spector A, Orrell M, Davies S, Woods B. Reality orientation for dementia. Cochrane Database Syst Rev. 2000;CD001119.
164 Bedard M, Molloy D, Pedlar D, Lever J, Stones M. 1997 IPA/Bayer Research Awards in Psychogeriatrics. Associations between dysfunctional behaviors, gender, and burden in spousal caregivers of cognitively impaired older adults. Int Psychogeriatr. 1997;9:277-290. [pmid: 9513028].
165 George L, Gwyther L. Caregiver well-being: a multidimensional examination of family caregivers of demented adults. Gerontologist. 1986;26:253-259. [pmid: 3721232].
166 Kiecolt-Glaser J, Dura J, Speicher C, Trask O, Glaser R. Spousal caregivers of dementia victims: longitudinal changes in immunity and health. Psychosom Med. 1991;53:345-362. [pmid: 1656478].
167 Gallagher D, Rose J, Rivera P, Lovett S, Thompson L W. Prevalence of depression in family caregivers. Gerontologist. 1989;29:449-456. [pmid: 2521102].
168 Deimling G, Bass D. Symptoms of mental impairment among elderly adults and their effects on family caregivers. J Gerontol. 1986;41:778-784. [pmid: 3772056].
169 Pruchno R, Resch N. Aberrant behaviors and Alzheimer's disease: mental health effects on spouse caregivers. J Gerontol. 1989;44:S177-S182. [pmid: 2768777].
170 Cohen-Mansfield J, Werner P. Typology of disruptive vocalizations in older persons suffering from dementia. Int J Geriatr Psychiatry. 1997;12:1079-1091. [pmid: 9427092].
171 Mangone C, Sanguinetti R, Baumann P, et al. Influence of feelings of burden on the caregiver's perception of the patient's functional status. Dementia. 1993;4:287-293. [pmid: 8261026].
172 Thompson C, Briggs M. Support for carers of people with Alzheimer's type dementia (Cochrane Review). Cochrane Database of Sys Rev. 2000.
173 Mittelman M S, Ferris S H, Shulman E, Steinberg G, Levin B. A family intervention to delay nursing home placement of patients with Alzheimer disease. A randomized controlled trial. JAMA. 1996;276:1725-1731. [pmid: 8940320].
174 Marriott A, Donaldson C, Tarrier N, Burns A. Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer's disease. Br J Psychiatry. 2000;176:557-562. [pmid: 10974962].
175 McCurry S M, Logsdon R G, Vitiello M V, Teri L. Successful behavioral treatment for reported sleep problems in elderly caregivers of dementia patients: a controlled study. J Gerontol B Psychol Sci Soc Sci. 1998;53:122-P1299.
176 Brodaty H, Gresham M, Luscombe G. The Prince Henry Hospital dementia caregivers' training programme. Int J Geriatr Psychiatry. 1997;12:183-192. [pmid: 9097211].
177 Hebert R, Leclerc G, Bravo G, Girouard D, Lefrancois R. Efficacy of a support group programme for caregivers of demented patients in the community: a randomized controlled trial. Arch Gerontol Geriatr. 1994;18:1-14. [pmid: 15374309].
178 Hebert R, Girouard D, Leclerc G, Bravo G, Lefrancois R. The impact of a support group programme for care-givers on the institutionalization of demented patients. Arch Gerontol Geriatr. 1995;20:129-134. [pmid: 15374241].
179 Jorm A, Henderson A, Scott R, Mackinnon A, Korten A, Christensen H. Do mental health surveys disturb? Further evidence. Psychol Med. 1994;24:233-237. [pmid: 8208888].
180 Petersen R, Stevens J, Ganguli M, Tangalos E, Cummings J, DeKosky S. Practice parameter: Early detection of dementia: Mild cognitive impairment (an evidence-based review): Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2001;56:1133-1142. [pmid: 11342677].
181 Patterson C J, Gass D A. Screening for cognitive impairment and dementia in the elderly. Can J Neurol Sci. 2001;28(Suppl 1):S42-S51. [pmid: 11237310].
182 Drickamer M A, Lachs M S. Should patients with Alzheimer's disease be told their diagnosis?. N Engl J Med. 1992;326:947-951. [pmid: 1542346].
183 Jha A, Tabet N, Orrell M. To tell or not to tell-comparison of older patients' reaction to their diagnosis of dementia and depression. Int J Geriatr Psychiatry. 2001;16:879-885. [pmid: 11571768].
184 Forette F, Seux M L, Staessen J A, et al. Prevention of dementia in randomised double-blind placebo-controlled Systolic Hypertension in Europe (Syst-Eur) trial. Lancet. 1998;352:1347-1351. [pmid: 9802273].
185 Applegate W B, Pressel S, Wittes J, et al. Impact of the treatment of isolated systolic hypertension on behavioral variables. Results from the systolic hypertension in the elderly program. Arch Intern Med. 1994;154:2154-2160. [pmid: 7944835].
186 Prince M J, Bird A S, Blizard R A, Mann A H. Is the cognitive function of older patients affected by antihypertensive treatment? Results from 54 months of the Medical Research Council's trial of hypertension in older adults. Br Med J. 1996;312:801-805. [pmid: 8608285]. [pmcid: 2350726].
187 Dartigues J F, Commenges D, Letenneur D, et al. Cognitive predictors of dementia in elderly community residents. Neuroepidemiology. 1997;16:29-39. [pmid: 8994938].
188 Hughes C P, Berg L, Danziger W L, Coben L A, Martin R L. A new clinical scale for the staging of dementia. Br J Psychiatry. 1982;140:566-572. [pmid: 7104545].
189 Gottfries C G, Brane G, Gullberg B, Steen G. A new rating scale for dementia syndromes. Arch Gerontol Geriatr. 1982;1:311-30. [pmid: 7186327].
190 Brane G, Gottfries C G, Winblad B. The Gottfries-Brane-Steen scale: validity, reliability and application in anti-dementia drug trials. Dement Geriatr Cogn Disord. 2001;12:1-14. [pmid: 11125236].
191 Cummings J L, Mega M, Gray K, Rosenberg-Thompson S, Carusi D A, Gornbein J. The Neuropsychiatric Inventory: comprehensive assessment of psychopathology in dementia. Neurology. 1994;44:2308-2314. [pmid: 7991117].
192 DeJong R, Osterlund O W, Roy G W. Measurement of quality-of-life changes in patients with Alzheimer's disease. Clin Ther. 1989;11:545-54. [pmid: 2776169].