# Results

Our presentation of results is arranged chiefly in accordance with the 9 key questions (KQ) introduced in Chapter 2 and Table 1. Specifically, we address the following issues: efficacy of screening in terms of 6 major outcomes (KQ No. 1); prevalence of undiagnosed dementia and common causes of this disease (KQ No. 2); reliability and validity of screening tests (KQ No. 3); efficacy of pharmacologic treatments of dementia (KQ No. 4); efficacy of nonpharmacological interventions (KQ No. 5); efficacy of caregiver interventions (KQ No. 6); adverse effects of screening (KQ No. 7); costs or cost-effectiveness of screening (KQ No. 8); and adverse effects of treatment (KQ No. 9). For KQ Nos. 4, 5 and 6 on therapies, we organize the discussion in terms of the 6 major health outcomes—functioning, health care utilization, behavioral problems, caregiver stress, adverse events, and quality of life—specified in the analytic framework (Figure 1).

Studies meeting our inclusion criteria that provide data for the sections that follow appear in one or more of the 12 evidence tables in Appendix B. Those tables contain abstracted information on the following topics:

- Prevalence of undiagnosed dementia (KQ 2)(Evidence Table 1);
- Effectiveness of screening tools (KQ 3) (Evidence Tables 2a, 2b);
- Treatment studies (KQ 4) (Evidence Table 3–9);
- Systematic reviews of the efficacy of nonpharmacologic interventions for behavioral problems related to dementia including sensory, environmental, behavioral, and activity-directed programs(KQ 5) (Evidence Table 10);
- Studies of the efficacy of various caregiver interventions (KQ 6) (Evidence Table 11); and
- Adverse effects of dementia therapy (KQ 9) (Evidence Table 12).

## KEY QUESTION NO. 1: EFFICACY OF SCREENING

We were unable to locate any randomized controlled trial (RCT) or systematic review addressing the use of screening tools for dementia and the effects of screening on the outcomes of interest.

## KEY QUESTION NO. 2: PREVALENCE OF UNDIAGNOSED DEMENTIA AND THE COMMON CAUSES OF DEMENTIA

### Prevalence of Undiagnosed Dementia

Data for evaluating the yield of implementing a screening strategy for dementia in primary care settings are quite limited. To date, few studies have attempted to estimate the extent to which physicians simply do not recognize dementia syndrome.

We found 4 studies concerning the extent of undiagnosed dementia. Two were in European populations ^12,^ ^66^ 1 in Canada, ^13^ and 1 in a predominantly Asian-American population. ^14^ Prevalence estimates from these studies are shown in Table 2; more detailed information can be found in Evidence Table 1 (Appendix B).

Table 2. Estimates of Undiagnosed Dementia in Primary Care Practices

Study | Quality Rating | Setting | Age of Patient Population | Reference Standard* | Prevalence of Missed Dementia in All Patients
Eefsting et al. 1996 ^66^ | Fair | Community and general practices, Netherlands | ≥ 65 years | DSM-IIIR | 3.2%
Olafsdottir et al. 2000 ^12^ | Good | Primary health center, Sweden | > 70 years | DSM-IIIR | 12.0%
Sternberg et al. 2000 ^13^ | Fair | Community Canada | ≥ 65 years | DSM-IIIR | 1.8%
Valcour, et al. 2000 ^14^ | Fair | General internal medicine clinic, Hawaii, U.S. (Asian-Americans) | ≥ 65 years | DSM-IIIR | 5.7%

* DSM-III-R, Diagnostic and Statistical Manual III, Revised.

Eefsting et al. questioned rural Dutch general practitioners (GPs) as to the presence of dementia (defined by DSM-IIIR criteria) and cognitive impairment in each of their assigned patients who were 65 years or older. ^66^ The Dutch group compared these findings to data from a simultaneous community survey in which these same patients had been screened with the Mini-Mental State Examination (MMSE); they clinically evaluated patients with scores of less than 17 and a sample with scores between 18 and 27. The adjusted prevalence estimate of dementia among GP patients in the study was 5.2% (4.2% in men, 5.8% in women). Sensitivity for diagnosis of dementia by GPs was only 39% (28 of 71 cases); specificity was 99.3% (275 of 277 cases). This sensitivity increased to 69% (50 of 71 cases) and the specificity decreased to 94% (260 of 277) when the definition of physician detection was expanded to any awareness of cognitive impairment. In short, GPs missed dementia in 3.2% of all primary care patients over age 65.

Olafsdottir et al. evaluated a random sample of patients greater than 70 years of age from a primary care center in Sweden. ^12^ Although 12% met Diagnostic and Statistical Manual Third Version, Revised (DSM-IIIR) criteria for dementia syndrome, they had no reference to cognitive impairment on their medical records.

A third study did not evaluate undiagnosed cases among primary care physicians but rather looked at the prevalence of “undetected” dementia (patients who had not visited their primary care physicians). ^13^ This study estimated that, among 252 cases of dementia in 9,008 community-dwelling people living in Canada, 64% of patients (161/252) with dementia either did not see their physicians for memory problems or the physician visit had not yet occurred. These data yield a 1.8% prevalence rate (161/9,008) of undetected dementia cases in elderly community-dwelling people.

Valcour et al. determined the rate of undiagnosed dementia in a cross-sectional study of 297 Asian-American patients ages 65 years and older who had been followed for at least 1 year by a private internal medicine practice. ^14^ Using strict diagnostic tools similar to DSM-IIIR criteria for dementia diagnosis, the investigators found 26 cases of dementia in the entire study population. Of these cases, 65% were undocumented and 67% were unrecognized at the time of the clinic visit. These data yield a prevalence of undiagnosed dementia of 5.7%.

### Community-based Estimates of Dementia Prevalence

Even though studies of the prevalence of undiagnosed dementia are scarce, estimates of overall prevalence of dementia can provide supplemental information. Table 3 provides estimates of dementia prevalence among persons 65 years of age and older from 3 community-based cross-sectional studies published after 1994. ^67–69^

Table 3. Estimates of the Prevalence of Dementia (%)

Study and Population | Age Groups
| 65–69 | 70–74 | 75–79 | 80–84 | 85–89 | 90–94 | 95+
Hendrie et al., 1995 ^67^ | | 1.83* | | 6.73† | | 17.07‡
African-Americans in Indianopolis, Indiana
(n = 2,212)
White et al., 1996 ^68^ | NR | 2.1 | 6.2 | 12.9 | 33.4 | NR | NR
Asian-American men in Honolulu, Hawaii
(n = 3,734)
Graves et al., 1996 ^69^ | 0.76 | 1.35 | 6.26 | 12.67 | 29.69 | 50.20 | 74.28
Japanese-Americans in King County (Seattle), Washington
(n = 1,985)

NR, not reported.

* Ages 65–74 years

† Ages 75–84 years

‡ Ages 85+ years

Comparisons of estimates are hindered by the inconsistent classification of age groups. Nonetheless, the estimates vary widely even within comparable age groups. How much of this variation can be attributed to actual differences in the study populations and how much to methodological differences is not clear.

In a further review (data not shown in Table 3) Corrada et al. used a multivariable model to analyze methodological factors that determine variation in prevalence estimates of Alzheimer's disease. ^70^ Statistically significant factors included the inclusion of mild cases of dementia, adjustment for false negatives, random sampling versus entire population, mixed urban/rural community versus either population alone, use of computerized tomography scans, use of laboratory studies, and use of Hachinski Ischemic Score. These factors explained 76% of the model's variability.

Erkinjuntti et al. confirmed the importance of using standardized criteria for dementia diagnosis (data not shown). ^71^ Different criteria to determine cases of dementia led to substantial variability in prevalence estimates for the same study population. Their estimates ranged from 3.1% with International Classification of Disease-10 (ICD-10) criteria to 29.1% with DSM-III criteria.

Finally, the 1996 literature review for the US Preventive Services Task Force (USPSTF) had cited dementia prevalence estimates before 1994 of 0.8% to 1.6% for persons 65 to 74 years of age, 7% to 8% for persons 75 to 84 years of age, and 18% to 32% for persons 85 years of age and older. ^15^ These study populations were primarily white.

Since that time, prevalence studies have expanded to determining rates within primarily nonwhite populations and have revealed somewhat higher rates. Estimates are erratic for African-Americans; estimated rates of dementia syndrome have fluctuated between 1.83% to 9.1% for persons 65 to 74 years of age, 6.7% to 19.9% for persons 75 to 84 years of age, and 11.9% to 58.6% for persons over 85. In Asian-Americans, the rates are more consistent (between 2 studies): ^68,^ ^69^ 1.4% to 2.1% for persons 70 to 74, 6.2% to 6.3% for persons 75 to 79, 12.7% to 12.9% for persons 80 to 84, and 29.7% to 33.4% for persons 85 to 89. Graves et al. found an even higher prevalence for Japanese-Americans older than 90 years of age (50.2% for 90 to 94; 74.3% for 95 and older). ^69^

### Common Causes of Dementia

Several pathological conditions cause the dementia syndrome. The 1996 USPSTF review reported that the proportion of dementia cases attributed to Alzheimer's disease was between 50% and 85%, with vascular (multi-infarct) dementia contributing an additional 10% to 20% of cases. Most of the recent studies conducted in different ethnic groups have confirmed these estimates, although they demonstrate that the prevalence of Alzheimer's disease and vascular dementia varies among different ethnic groups. The percentage of dementia cases due to Alzheimer's disease is lower in the Asian-American populations studied by Graves et al. ^69^ and White et al.; ^68^ conversely, the proportion of cases due to vascular dementia is higher.

Table 4 shows the estimated subtypes of dementia syndrome as reported by 4 studies conducted since 1994. ^67,^ ^69,^ ^72,^ ^73^ The high prevalence of Alzheimer's disease and vascular dementia leads to a number of mixed cases (about 7% to 16% of all dementias). Approximately 5% to 17% of all people with the dementia syndrome have other types of dementia. The proportion of dementia cases that are truly reversible has been reported by 5 other studies to be less than 1.5%. ^58–61,^ ^74^

Table 4. Diagnostic Categories for Subtypes of Dementia

Study | Diagnostic Category for Subtypes of Dementia (% of cases)
| Alzheimer's Disease | Vascular Dementia | Mixed Alzheimer's Disease/Vascular Dementia | Other
Hendrie et al., 1995 ^67^ | 75.4 | 15.4 | NA | 16.9
Graves et al., 1996 ^69^ | 57.3 | 23.5 | NA | NA
Breitner et al., 1999 ^72^ | 60.0 | 16.4 | 6.9 | 16.7
Gurland et al., 1999 ^73^ | 74.1 | 4.8 | 15.6 | 5.4

NA, not available.

### Summary

The percentage of primary care patients over age 65 who have unrecognized dementia is between 2% and 12%. We estimate that one-half to two-thirds of cases of early dementia are not diagnosed by a routine history and physical examination. Considerable evidence shows that the prevalence of dementia increases with age; thus, the prevalence of missed dementia cases likely increases among older individuals.

In regard to the frequency of particular causes of dementia syndrome, Alzheimer's disease is a primary process for a majority of cases (about 60% of all dementias), but vascular dementia is the primary process for a significant proportion of cases (about 15%). The high prevalence of these etiologies leads to a number of mixed cases (7% to 16% of all dementias). Other etiologies account for 5% to 17% of all cases.

## KEY QUESTION NO. 3: VALIDITY AND RELIABILITY OF SCREENING TESTS

Researchers and practitioners in this clinical area have traditionally divided screening tests into cognitive tests and functional assessment. Our search yielded 1 meta-analysis that evaluated both cognitive and functional screening tools (Evidence Table 2a). ^75^ We also reviewed 7 studies that evaluated cognitive screening tools, ^76–82^ 1 study that evaluated functional screening tools, ^83^ and 1 study that was a comparison between cognitive and functional screening tools (Evidence Table 2b). ^84^

Recent advances in genetic technology have revealed familial linkages for some Alzheimer's disease cases that may lead to genetic screening tests. ^55^ However, no studies evaluating genetic screening tests met our inclusion criteria or were of sufficient methodological quality to review here.

### Cognitive Tests

Studies of screening tools for dementia have centered primarily on the MMSE. The Agency for Health Care Policy and Research (AHCPR) supported a systematic review and meta-analysis of studies (published primarily before 1994) that evaluated the MMSE for screening. ^75^ The AHCPR panel used mean effect size as the measure of effectiveness, as described by Hasselblad and Hedges. ^85^ The mean effect size for discrimination between patients with and without dementia was 1.78. This effect size corresponds to an equivalent sensitivity and specificity of 84% and a sensitivity of approximately 75%, for a fixed specificity of 90%.

Studies from 1994 to 2001 have had 2 usual orientations when evaluating the MMSE: primary investigations into its validity when adjusting for either cultural or educational factors (or both) and secondary investigations that compare the performance of newer screening tools to that of the MMSE. Table 5 compares the findings of 5 MMSE studies. ^76,^ ^78,^ ^80,^ ^81,^ ^84^ Three of these studies included cut-off levels on the basis of receiver-operator curve (ROC) analysis, and these are the usual values provided. Excluding the Wilder et al. study (evaluating specificity levels for 90% sensitivity), the MMSE sensitivity (71% to 92%) and specificity (77 % to 96%) fell into a moderate range and the percentage of falsely classified individuals (false negatives and false positives as a percentage of the total number of tested individuals) ranged from 4% to 18%. ^80^ The primary factors determining the rate of false diagnoses are likely to be related to cut-off values and the overall percentage of individuals with dementia in each study. This percentage may not reflect the actual prevalence of dementia in these populations, however, because some studies evaluated only a sub- sample of those with negative screens.

Table 5. Characteristics and Results of Six Studies Evaluating Properties of the Mini-Mental State Examination (MMSE)

Study | Number of Subjects | Cut-off Value* (Rationale) | Percentage with Dementia | Sensitivity | Specificity | False Positives (% of all subjects) | False Negatives (% of all subjects) | Notes
Law and Wolfson, 1995 ^84^ | 237 | 23 (“Conventional”) | 20.7 | 71 | 82 | 13.9 | 5.9 | French version
Wilder et al., 1995 ^80^ | 162 | 23/24 (90% sensitivity) | 24.0 | 90 | 56 | 33.3 | 2.5 | Firm 90% sensitivity
Jitapunkul et al., 1996 ^78^ | 212 | 16/18 (illiterate/ literate) | 8.0 | 76 | 92 | 7.1 | 1.9 | Thai version
| | (ROC)
McDowell et al., 1997 ^76^ | 1,600 | 25/26 | 23.0 | 86 | 77 | 17.7 | 3.3 | English and French versions
| | (ROC)
Heun et al., 1998 ^81^ | 291 | 24/25 | 12.7 | 92 | 96 | 3.4 | 1.0 | German version
| | (ROC)

* ROC, receiver-operator curve.

To determine the validity of the MMSE for predicting the ultimate development of dementia, Braekhus et al. analyzed the use of MMSE with a prospective approach that excluded prevalent cases of dementia syndrome in a Norwegian population. ^79^ As reported in Table 6, the authors found that a likelihood ratio for predicting dementia syndrome in the next 3 to 6 years was 2.3 for an MMSE cutpoint of 25 and 3.45 for a cutpoint of 24. Because of the small sample size for each MMSE score and the low follow-up rates, the conclusion from this study is limited.

Table 6. Likelihood Ratios (LR) for Prediction of Dementia Using the Mini-Mental State Examination (MMSE)

MMSE score | 3-Year Incidence of Dementia | LR for 3-Year Incidence Dementia (n = 215) | 3- to 6-Year Incidence of Dementia | LR for 3- to 6-Year Incidence of Dementia (n = 129)
30 | 0.024 | 0.20 | 0.182 | 0.77
29 | 0.018 | 0.15 | 0.270 | 1.28
28 | 0.083 | 0.76 | 0.174 | 0.73
27 | 0.103 | 0.96 | 0.167 | 0.69
26 | 0.154 | 1.51 | 0.222 | 0.99
25 | 0.421 | 6.07 | 0.4 | 2.30
24 | 0.375 | 5.01 | 0.5 | 3.45

Source: Braekus et al., 1996 ^79^

Folstein et al., in 1975, documented that the MMSE is a reliable instrument. ^49^ Two decades later, McDowell et al. provided additional reliability data (Table 7) that confirmed the earlier findings. ^76^

Table 7. Reliability Data for Mini-Mental Status Examination

MMSE Adminstration Language | Reliability Measure | Value
French | Alpha internal consistency | 0.78
| Split-half reliability | 0.76
English | Alpha internal consistency | 0.79
| Split-half reliability | 0.73

Source: McDowell et al., 1997 ^76^

In reviewing the current literature on the Clock-Drawing Test (CDT), Schulman reported that the mean for both sensitivity and specificity from various studies was 85%. ^50^ His review did not provide search terms or inclusion criteria; his quality appraisal called for only the presence of clearly defined methods and the presence of a comparator group. We examined all the individual studies ourselves, but none met our quality criteria for inclusion in this review. The primary weakness of most studies was that the investigators had not evaluated the CDT in either primary care or community-dwelling subjects.

Solomon et al. analyzed the use of the CDT as part of a larger battery of cognitive screening tests known as the 7-Minute Screen. ^82^ This tool also includes the Temporal Orientation test, the Enhanced Cued Recall test, and the Verbal Fluency test. The study reported a mean administration time of 7 minutes and 18 seconds. Of subjects classified as having a high probability of dementia, 85% (11/13) had dementia diagnoses. The remaining 15% of subjects refused follow-up. Of the sample of subjects classified as having a low probability of dementia, 96% (25/26) did not have a diagnosis of dementia; the remaining subjects had cognitive impairment without dementia. These results indicate this screening tool may be more effective at detecting cases of dementia while having greater clinical utility than most cognitive tests. However, these conclusions are limited by the lack of any evaluation of the 7-Minute Screen in larger and more diverse primary care populations.

Screening tools must achieve a balance between comprehensiveness and clinical utility. Many of these cognitive and functional assessment tools were initially intended to be a component of a battery of tests in the full assessment of the presence of dementia. Some researchers have sought to transplant some items for applications oriented more to screening than to diagnosis. To accomplish this objective, a balance must exist that minimizes length and complexity of a test, maintains comprehensiveness of questions in evaluating total cognitive function, and does not compromise test accuracy. ^25^

Costa et al., in the AHCPR review, evaluated 9 additional cognitive screening tests: the Blessed Orientation Memory Concentration Test (BOMC); the Blessed Information Memory Concentration (BIMC); the Short Test of Mental Status (STMS); the Modified Mini-Mental Status Exam (3MS); the Abbreviated Mental Test (AMT); the Chula Mental Test (CMT); the Mental State Questionnaire (MSQ); the Comprehensive Assessment and Referral Interview Cognitive Scale, Dementia Version (CARE-D); and the Short Portable Mental Status Questionnaire (SPMSQ). ^75^ Three other studies have examined at least 1 of these tests as well. ^76–78^ These tests were found to have a level of performance similar to that of the MMSE, as shown in Evidence Tables 2a and 2b.

In conclusion, of all studies that evaluate screening instruments for dementia, the proportion that meets acceptable methodological standards is low. However, a good degree of evidence is available on the MMSE. Administration within asymptomatic primary care or community populations, 4% to 21% of all screened individuals were falsely classified with positive or negative results. Valid data relevant to asymptomatic primary care populations for the CDT do not currently exist. Other instruments may have clinical utility, but the gaps in evidence as to whether these tests can screen elderly patients effectively for dementia diagnosis or progression are significant.

### Functional Assessments

Some researchers have evaluated informant-based functional assessments as screening tests for dementia. Advantages of these assessments include everyday relevance, acceptability by subjects, adaptability to difficult-to-evaluate patients, administrative ease, longitudinal perspective, and cross-cultural portability. Primary limitations are that some patients have no caretakers and that some functions are not assessed. ^54^

The Informant Questionnaire on Cognitive Decline in the Elderly (IQCODE) is the most widely researched functional tool, providing most of the data that Jorm used in a meta-analysis comparing functional assessments with cognitive tests. ^86^ However, this meta-analysis failed to meet our quality standards because it did not state inclusion/exclusion criteria or any appraisal of the quality of the studies in the analysis.

Barberger-Gateau et al. examined the use of the instrumental activities of daily living (IADL) in multiple French populations as a predictor of the subsequent development of dementia over 3 and 5 years in multiple French populations (Evidence Table 2b). ^87^ Likelihood ratios, calculated as the ratio of the probability of the IADL score in those who develop dementia and the probability of the IADL score in those who do not develop dementia, are shown in Table 8. According to Stern and Mohs, the likelihood ratio for developing dementia among those with a positive IADL test was 2.58. The low absolute incidence made the IADL a relatively modest predictor of dementia development. ^88^

Table 8. Likelihood Ratios (LR) for Prediction of Dementia with Instrumental Activities of Daily Living (IADL)

IADL Score | 3-year Incidence of Dementia | LR for 3-Year Incidence of Dementia (n = 1,574) | 5-Year Incidence of Dementia | LR for 5-Year Incidence of Dementia (n = 1,283)
0 | 0.016 | 0.38 | 0.016 | 0.63
1 | 0.083 | 2.19 | 0.061 | 2.44
2 | 0.143 | 4.01 | 0.071 | 2.91
3 | 0.258 | 8.38 | 0.059 | 2.36
4 | 0.200 | 6.02 | 0.077 | 3.16

Source: Barberger-Gateau et al., 1999. ^83^

### Summary

Several cognitive and functional screening tests have been evaluated in a limited number of primary care populations. A few studies that evaluated screening instruments for dementia met our methodological standards. Of these, the MMSE is the best studied, clinically feasible screening tool. Whether the MMSE is a good screening tool in an elderly, community-based population depends on the prevalence of dementia in this population and the cut-off point of the MMSE that will determine if the screening result is said to be positive or negative. A positive result on this screening test requires further diagnostic tests to confirm the diagnosis.

## KEY QUESTION NO. 4: EFFICACY OF PHARMACOLOGIC INTERVENTIONS

We looked at any randomized controlled trial that evaluated the efficacy of various pharmacologic therapies for potentially reversible, neurodegenerative, vascular, and other etiologies of dementia. Data are summarized in Evidence Tables 3–9.

### Yield of Literature Searches

#### Reversible Dementia

Our search of the MEDLINE, PsycINFO, EMBASE, and Cochrane Collaboration databases yielded no RCT that evaluated treatment for dementia caused by depression, drug side effects, metabolic disorders, vitamin B_12_ deficiency, infectious disease, neoplasm, normal pressure hydrocephalus, or subdural hematoma. We then expanded our search to include longitudinal studies that followed cohorts of dementia syndrome patients who received treatment for the aforementioned diseases or other potentially reversible conditions. We define the terms “partially reversible” and “fully reversible” causes of dementia based on the availability of follow-up data on the clinical outcome of dementia patients after the treatment of the potential cause.

Our search from 1994 to the present yielded 1 meta-analysis ^89^ and 5 additional studies. ^59–61,^ ^90,^ ^91^ We included 1 other meta-analysis published before 1994 and that had been characterized as an important study. ^62^ Most of the studies included in these 2 meta-analyses did not meet our inclusion criteria and were considered to be methodologically poor by the USPSTF methodological appraisal method. After evaluation of all the studies in both reviews, we included 7 studies that met our inclusion criteria and were considered to be of at least fair quality. ^57–61,^ ^74,^ ^92^ All 7 included studies were longitudinal treatment trials conducted in patients drawn from specialty referral populations. These studies are summarized in Evidence Table 3.

Three of the 7 studies reported no case of fully reversed dementia among a total of 305 patients with dementia. ^58–60^ The remaining 4 studies reported 1% to 3% fully reversed cases among a total of 588 patients with dementia. ^57,^ ^61,^ ^74,^ ^92^ In the studies that reported a higher proportion of fully reversed dementia, more than 50% of reversed cases were caused by drug toxicity. ^57,^ ^61,^ ^92^ It is likely that current diagnostic criteria would reclassify at least some of these patients as having delirium rather than dementia. After reviewing these 7 studies and adjusting for the presence of delirium as a primary diagnosis instead of dementia, we concluded that fully reversible dementia is no greater than 1.5% of all dementia syndrome cases.

An additional study assessed the prevalence of reversible dementia due solely to vitamin B_12_ deficiency (data not shown in Evidence Table 3). ^91^ Of 66 memory clinic patients with potentially reversible dementia from this condition, the investigators reported no case of fully reversed dementia syndrome after a mean follow-up period of 7.5 months.

#### Irreversible Dementia

Our search yielded 205 RCTs and 22 systematic reviews that evaluated treatment for irreversible neurodegenerative and vascular dementia. Among these, 23 RCTs ^4,^ ^93–114^ and 10 systematic reviews ^115–125^ met our inclusion criteria.

Four systematic reviews ^115,^ ^119–121^ and 9 RCTs ^93,^ ^95–101,^ ^112^ evaluated the efficacy of cholinesterase inhibitors in Alzheimer's disease (Evidence Tables 4a and 4b, respectively). One systematic review ^118^ and 1 RCT ^106^ evaluated the efficacy of ginkgo biloba in Alzheimer's disease (Evidence Table 5). One systematic review ^116^ and 1 RCT ^103^ evaluated the efficacy of selegiline in Alzheimer's disease; the same RCT also evaluated vitamin E and both drugs together (Evidence Table 6). Two RCTs evaluated the effect of estrogen in Alzheimer's disease (Evidence Table 6). ^105,^ ^114^ We identified 1 RCT for prednisone, ^108^ and diclofenac (Evidence Table 7), ^109^ and 1 RCT for nimodipine. ^104^ We also found 1 systematic review for aspirin in vascular dementia (Evidence Table 8). ^117^ Finally, we found 1 RCT that evaluated the efficacy of rivastigmine in Lewy body dementia. ^102^ Evidence Table 9a reports on 3 systematic reviews evaluating the efficacy of neuroleptics in healing dementia-related behavioral problems. ^122,^ ^124,^ ^125^ In addition, we identified several RCTs involving pharmacologic interventions for behavioral problems (Evidence Table 9b): 3 concerned neuroleptics; ^94,^ ^110,^ ^113^ 1 studied clomepramine; ^111^ and 1 dealt with sertraline. ^4^

The main target of drugs for the treatment of dementia is Alzheimer's disease; the most studied drugs are the cholinesterase inhibitors. In the next subsections, we describe common outcome measures used in the efficacy drug trials for Alzheimer's disease and comment on the natural history of Alzheimer's disease reflected in these outcome measures, including the translation of some of these outcome measures to clinically relevant change. We then present findings for each studied drug on cognition, global change scores, functional ability, behavioral scales, and other outcomes.

#### Outcome Measures in Dementia

Dementia syndrome in general and Alzheimer's disease in particular are characterized by progressive decline in 3 categories: cognition, functional ability, and behavior. Efficacious therapy might improve, delay, or reverse decline in some or all of these domains. Current standards from the Food and Drug Administration (FDA) for testing drugs in Alzheimer's disease trials require demonstration of “dual efficacy;” that is, trials must show improvement on a performance-based neuropsychologic measure and demonstrate clinically meaningful change. The FDA does not specify the actual tools or outcome measures to be used. Assessments in these studies vary widely, making comparisons across trials very difficult. When evaluating a published clinical trial, reviewers need to consider the selection of appropriate primary and secondary outcome scales, trial design, drug dosage, and inclusion/exclusion criteria.

A systematic review conducted by Demers and colleagues for the Canadian Coordinating Office for Health Technology Assessment assessed the psychometric properties of 50 scales used in 26 RCTs on Alzheimer's disease drug efficacy. ^126^ They categorized the scales based on the following outcome domains: cognition, global change scores, function/quality of life, and behavior/mood. The review concluded that the function/quality of life and behavior/mood scales have not achieved the same degree of reliability and validity as the cognitive scales.

#### Cognition

Currently, the cognitive part of the Alzheimer Disease Assessment Scale (ADAS-Cog) ^127^ is considered the reference standard for evaluating the efficacy of certain medications on the cognitive domain of Alzheimer's disease. ^126,^ ^128^ The ADAS-Cog consists of 11 items designed to assess the extent of impairment of memory, language, orientation, and praxis. Scores range from 0 to 70 according to the number of errors patients make. The higher the score, the more extensive is the impairment. Specific training is required to administer the test, which takes 30 to 45 minutes to complete.

The MMSE requires 5 to 10 minutes to complete. ^129^ It consists of 5 subtests in the domains of orientation, memory, attention, language, and praxis; the scoring range is 0 to 30, with 30 the optimal score. It tests domains similar to those of the ADAS-Cog and correlates strongly and significantly with ADAS-Cog (r of 0.81 and P < 0.001). For each 1 point drop in the MMSE, the ADAS-Cog drops approximately 2.5 points. ^130,^ ^131^

The scores of outcome measures on previous scales used in dementia drug trials are difficult to interpret unless one can connect the magnitude of changes in the scale scores and clinically relevant outcomes. The best way to understand the clinical relevance of certain scores on cognitive psychometric instruments is to evaluate their correlation with functional performance. Vitaliano et al. examined the relationship between 5 areas of cognition (memory recall, recognition, orientation, attention, and calculation) derived from subtests of the MMSE and the Dementia Rating Scale (DRS) and 3 functional domains (recreation, communication, and self-care). ^132^ The investigators found that functional competence could be predicted from scores of memory and attention. Perry and Hodges performed comprehensive cognitive and functional assessments on 24 community-dwelling subjects with Alzheimer's disease and their informal caregivers. ^133^ Functional assessment correlated well with overall severity as measured by MMSE (r = -0.733) and strongly with the cognitive domain of visuospacial and semantic memory (r = 0.843). The MMSE correlated significantly (P < 0.001) with the following everyday functional activities: telling the time correctly (r = -0.714), using a television or radio unassisted (r = -0.704), opening packages without difficulty (r = -0.643), writing with no mistakes (r = -0.624), and making a hot drink competently (r = -0.614). The MMSE did not correlate significantly with the following: taking messages, handling finances, repetitiveness, and maintaining conversational skills. ^133^

#### Global Change

Although either the ADAS-Cog or the MMSE can fulfill the FDA requirement for drug efficacy as a performance-based neuropsychological instrument, one must still demonstrate what constitutes clinically relevant change. Most drug trials use scales that measure the global change in dementia signs and symptoms as observed by health professionals or by family caregivers. The goal of measuring global change is to establish an overall impression of a patient's condition without focusing exclusively on a single function. ^134^ The International Working Group on Harmonization of Dementia Drug Guidelines states that global scales seek to assess clinically manifested change, based on comprehensive or multidimensional assessments that include cognitive, behavioral, and daily functional performance. ^135^

All global scales consist of a concise patient interview conducted by an experienced clinician; the premise is that the detection of change by an experienced clinician is likely to be clinically meaningful. These scales seek to mimic how physicians assess Alzheimer's disease patients in routine clinical practice. ^135^ The most common global scale is the Clinician's Interview Based Impression of Change plus caregiver input scale (CIBIC-plus). This scale includes information from both patient and caregiver interviews conducted by an experienced and independent clinician. The CIBIC-plus consists of a semi-structured baseline interview administered to both the patient and the informant caregiver, a follow-up interview with both the patient and the informant, and a clinician's rating of impression of change. The clinician is not informed of the patient's psychometric test score or adverse event reports. The clinician rates the patient on a 7-point scale: 1, very much better; 4, no change; and 7, very much worse. The CIBIC-plus has been shown to be a stable measure of global function and is sensitive to deterioration over time.

Table 9 summarizes the scoring system and interpretation of the 3 most common measurement tools used in the majority of clinical trials: ADAS-Cog, MMSE, and CIBIC-plus.

Table 9. Summary Description of Three Common Scales Used in Alzheimer's Disease Drug Trials

Scale | Assessment Domain | Range and Interpretation
Alzheimer's Disease Assessment Scale-Cognition (ADAS-Cog) | Cognition | [underlined: 0 to 70]
| | 70 = severe impairment
| | Untreated patients decline annually by 7 to 11 points
| | For example, 3 to 4 points improvement from baseline can mean patients remember who came to dinner last evening
Mini-Mental Status Examination (MMSE) | Cognition | [underlined: 0 to 30]
| | 30 = no impairment
| | Untreated patients decline annually by 2 to 4 points
| | For example, improvement of 2 points from baseline can mean patients are able to name common objects
| | 1.6 points on MMSE = 4 points on ADAS-Cog
Clinician Interview Based Impression of Change plus caregiver input (CIBIC-Plus) | Global measure of behavior, cognition, activities of daily living | [underlined: 1 to 7]
| | 1 = very much improvement
| | 4 = no change
| | 7 = very much deterioration

In the discussion of drug trials below, we will state the properties and the interpretation of each functional scale and other outcome measures used. For further details, Appendix C summarizes all the outcome measurement instruments that were used in our systematic evidence review.

#### Functional Performance

The second way to demonstrate clinically relevant changes in Alzheimer's disease drug trials is to measure functional performance. Investigators do not agree on the best way to evaluate functional changes. Because of this lack of universally accepted measures, investigators use a wide range of functional performance scales. The majority of these scales assess function by examining the patient's ability to perform independently both basic and instrumental activities of daily living (ADLs). ^126,^ ^129^ Basic ADLs include bathing, dressing, grooming, toileting, transferring, ambulation, continence, and feeding; ^136^ IADLs include the ability to go shopping, manage transportation, climb stairs, manage finances, do housework, use the telephone, do the laundry, manage medications, walk outdoors, drive, hold down a paying job, and prepare meals. ^137^

#### Behavior Related to Dementia

In addition to cognitive decline, patients with dementia suffer from noncognitive problems such as a decline in functional status and disturbed or agitated behaviors. Agitation, disturbed behavior, or behavioral problems related to dementia are different terms that have been used to denote the phenomenon defined as an inappropriate verbal, vocal, or motor activity not explained by needs or confusion. ^138^ Agitation in dementia is the final step of interplay between cognitive deficit, neurotransmitter deregulation, and environmental factors. It results from underlying distress experienced by the elderly person. This distress can stem from cognitive impairment, psychiatric and medical disorders, or functional impairments. ^139^ Although there is lack of consensus on the definition of behavioral problems related to dementia, ^140^ these disturbed behaviors can be described in four major categories: physical aggression, physical nonaggression, verbal aggression, and verbal nonaggression. ^138^

Agitated behaviors are common and are not different within the different types of dementia. Haupt et al. followed 60 patients with mild to severe Alzheimer's disease for a period of 2 years; all experienced agitation at some point. ^141^ In a prospective study of patients with Alzheimer's disease over a follow-up period of up to 5 years, Devanand et al. reported that agitated behaviors were common and persistent. ^142^ In a cross-sectional study of 5,092 elderly people in Cache County, Utah, Lyketsos et al. found that 61% of people with dementia had exhibited 1 or more mental or behavioral problems in the past month. ^143^ Among those behavioral problems, apathy constituted 27%; depression, 24%; and agitation/aggression, 24%. In the United Kingdom, a cross-sectional study estimated the prevalence of individuals with behavioral problems in 178 persons with Alzheimer's disease and reported the following estimates: apathy, 41%; major depression, 24%; agitation/aggression, 20%; wandering, 19%.delusion, 16%; hallucination, 17%; and mania, 3.5%. ^123^

Agitated behaviors are associated with earlier nursing home referral, worse prognosis, greater costs, and increased caregiver burden. ^144^ The behaviors adversely affect the quality of life of patients with dementia syndrome and their caregivers, complicate patient management, and precipitate institutionalization. ^138,^ ^145^ Before the advent of specific pharmacological treatment for Alzheimer's disease (cholinesterase inhibitors), the management of dementia in general and Alzheimer's disease in particular was based on a variety of nonpharmacological interventions that targeted both the cognitive and the noncognitive symptoms of dementia. Pharmacological therapy of severe behavioral problems or disorders related to dementia was based on methods similar to those for treating schizophrenia and bipolar disorder, with no specific attention to dementia itself as having a different pathophysiology. Over the past decade, however, dementia management has evolved somewhat and specific medications now exist for the treatment of the behavioral disorders. Measuring behaviors in dementia is usually generated by observational methods such as direct observation by the investigators, caregivers rating of the behaviors (staff and family members), or chart reviews. This type of outcome measurement is very subjective and can be biased by the relationship between the caregiver and the care recipient, the caregiver's general stress level, the amount of contact between the caregiver and the patient, and, if covering a long period of assessment such as weeks or months, can induce recall bias. Because of the lack of consensus on both the definition of behavioral problems in dementia and the approach to measure them, numerous instruments have been created that lack complete assessment of their psychometric properties and their responsiveness to clinical changes over time.

#### Natural History of Alzheimer's Disease

Interpreting the results of clinical trials of potential Alzheimer's disease treatments requires some understanding of the natural history of Alzheimer's disease. As the disease progresses, cognitive, physical and social functioning deteriorate. Patients gradually lose their ability to carry out both ADLs and IADLs (Table 10).

Table 10. Specific Domains of Basic and Instrumental Activities of Daily Living

Basic Activities of Daily Living | Instrumental Activities of Daily Living
Toileting | Use of telephone
Feeding | Household tasks
Dressing | Using household appliances
Personal hygiene and grooming | Managing money
Bathing | Shopping
Walking | Food preparation
| Ability to get around inside and outside home
| Hobbies and leisure activities
| Handling personal mail
| Grasp of situation or explanations

Source: McDowell and Newell, 1996 ^129^

Longitudinal studies have shown that the relationship between baseline disease severity and the rate of cognitive decline is not linear. ^88^ An expected rate of cognitive decline for untreated patient cohorts can be estimated given their baseline ADAS-Cog or MMSE scores. People with mild dementia (ADAS-Cog score = 15) and people with severe dementia (ADAS-Cog ≥ 55) show an average rate of decline of 5 or fewer ADAS-Cog points per year. Considering the full range of people with moderate dementia (ADAS-Cog >15 to < 55), longitudinal studies have found a decline in untreated clinic patients of 7 to 11 points annually. ^88,^ ^146^ This rate of decline is equivalent to 2 to 4 points annually on the MMSE. ^147,^ ^148^

On the ADAS-Cog, an improvement of 3 to 4 points from baseline can mean, for example, that the patient can now remember who came to dinner the previous evening or perform familiar tasks, such as dressing. ^149^ Given that untreated patients with mild to moderate dementia deteriorate annually by 5 to 11 points on the ADAS-Cog, an improvement of 4 points may be equivalent to a 5- to 10-month delay in the progression of the disease.

### Trials of Alzheimer's Disease Drugs

#### Efficacy of Cholinesterase Inhibitors

The FDA has approved 4 cholinesterase inhibitors: tacrine, donepezil, rivastigmine, and galantamine. We found 4 systematic reviews ^115,^ ^119–121^ that evaluated the efficacy of this class of medication on the cognition, global change and functional status of Alzheimer's disease in patients with mild to moderate stages of the disease (Evidence Table 4a). Our search also yielded 7 RCTs of 6 or less months' duration, ^96–101,^ ^112^ and 2 RCTs of 12 months' duration. ^93,^ ^95^ Two tacrine reviews, ^120,^ ^121^ 1 donepezil RCT, ^93^ and 1 galantamine RCT ^98^ also looked at the efficacy of cholinesterase inhibitors on the behavioral symptoms of Alzheimer's disease. One systematic review ^119^ and 1 RCT ^99^ evaluated the impact of donepezil on the quality of life of patients with Alzheimer's disease. One RCT conducted an economic evaluation and assessed the efficacy of donepezil on the time that caregivers spent assisting Alzheimer's disease patients with their activities of daily living. ^93^

Table 11 summarizes the effect of the 4 different cholinesterase inhibitors on various outcomes in Alzheimer's disease. These are discussed in detail below.

Table 11. Efficacy of Cholinesterase Inhibitors in Alzheimer's Disease

Drug | Cognitive Function | Clinician-assessed Global Function | Physical Function: Activities of Daily Living (ADLs) | Behavioral Symptoms | Quality of Life | Caregiver Burden
Tacrine | + | + | NS | NS | NT | NT
Donepezil | + | + | + | NS | NS | +
Rivastigmine | + | + | + | NS | NT | NT
Galantamine | + | + | + | NS | NT | NT

Key:

+ Statistically significant effect

NS No significant effect

NT Not tested

Tacrine. One systematic review evaluated the efficacy of tacrine in patients with mild to moderate Alzheimer's disease examined the data from 12 good quality RCTs with close to 2,000 subjects. ^121^ This study found that, compared to placebo, patients receiving 3 months of tacrine therapy showed the following: a mean difference of 2.1 points on the 70-point ADAS-Cog scale (see Table 9 for description of scale); an odds ratio (OR) of 1.58 (95% Confidence Interval [CI], 1.18–2.11) showing improvement on the Clinical Global Impression of Change (CGIC, range 1 to 7); no significant change in functional ability; and a mean difference of 0.58 points (P = 0.006) on the 50-point ADAS-noncognitive behavioral scale. A more recent review ^120^ looked only at 5 RCTs that were included in the previous review. The authors found that the mean difference of 0.14 on the ADAS-Cog and an OR of 1.15 on the CGIC, both in favor of treatment.

Donepezil. Birks et al. ^119^ summarized the efficacy of donepezil as studied in 4 RCTs with total of 1,100 patients with mild to moderate Alzheimer's disease. The authors found that 6 months of donepezil therapy produced a mean difference of 3 points on the 70-points ADAS-Cog scale and an OR of 2.63 (95% CI, 1.79–3.85) for showing improvement on the CIBIC-plus (range 1 to 7). According to this systematic review, donepezil had no effect on either functional ability or patients' self-rated quality of life.

We found 4 additional RCTs that were not included in the Birks et al. review. These 4 trials also demonstrate that donepezil offers small improvements in cognition and global change scores when compared to placebo. Burns and colleagues assessed the efficacy of 6 months of donepezil therapy in 818 Alzheimer's disease patients. ^99^ In addition to cognitive and global change, this trial evaluated the effect of donepezil on functional status as measured by the Interview for Deterioration in Daily living in Dementia (IDDD) scale. The investigators found that, compared to patients receiving placebo, those receiving 10 mg of donepezil for 6 months produced the following: a mean improvement of 2.9 points on the 70-point ADAS-Cog scale; 11% more patients considered improved on the global CIBIC-plus scale; a mean difference of 1 point on the 233-point functional IDDD; and no effect on the patient's quality of life.

Greenberg et al conducted double-blind placebo-controlled crossover study that evaluated the effect of a 3-month 5 mg dose of donepezil therapy in 60 patients. ^100^ This study found that donepezil produced a mean improvement of 2.1 points on the 70-point ADAS-Cog scale, with no improvement on the global CGIC scale.

In a third study, an RCT conducted in Northern European countries, Winblad and colleagues evaluated the efficacy of 12 months of 10 mg donepezil therapy in 286 patients with mild to moderate dementia. ^93^ The primary outcome measure in this trial was The Gottfries-Brane-Steen (GBS) scale, a 162-point measure of global change. The secondary outcome measures were the MMSE, a 30-point measure of cognition; the Progressive Deterioration Scale (PDS), a measure of functional status; the NeuroPsychiatry Inventory (NPI), a measure of behavior; caregiver time spent assisting patients in ADLs; and Resource Utilization in Dementia Questionnaire (RUD), a measure of the cost of care.

The investigators found that, compared to patients receiving placebo, 12 months of treatment with donepezil produced statistically significant improvement in global change, cognition and functional status measures. ^93^ The magnitude of these changes are the following: a mean improvement of 1.9 points on the 30-point MMSE cognitive scale; a mean improvement of 4 points on the 162-point GBS global scale (see Table 9 for description of scale); and a mean improvement of 3.5 points on the 100-point PDS functional performance scale. There was no significant effect on the behavioral symptoms of Alzheimer's disease. On average, the caregiver in the donepezil group spent 1.1 fewer hours per day giving care than those in the placebo group. This daily difference could not be judged for statistical significance (data were not available). At 12-month follow-up, 6% of the caregivers in the placebo group spent 16 hours or more daily assisting the patient with their functional performance compared to 2% of the caregivers in the donepezil group. This difference was not statistically significant.

Mastey et al. conducted an economic evaluation of donepezil among the patients who enrolled in this study. ^150^ The authors found that the average annual cost per patient was $1,100 (US dollars) more in the placebo group than in the donepezil group.

The fourth study by Mohs and colleagues was a 1-year, double-blind, placebo-controlled study evaluating the ability of donepezil to preserve or slow the functional decline in 431 community- dwelling patients with mild to moderate Alzheimer's disease who were able to perform 5 out of 6 basic ADLs and 8 out of 10 IADLs. ^95^ The primary outcome measure was the time to reach a clinically evident decline in functional performance. This decline was defined the patient reaching one of the following criteria: (1) a decline in ability to perform 1 or more basic ADLs; (2) a decline in ability to perform 2 or more IADLs; or (3) an increase in the global Clinical Dementia Rating scale (CDR) of 1 or more points compared to baseline. The authors found that 10 mg donepezil therapy produced a median time to clinically evident decline of 6.9 months for the placebo group versus 11.9 months for the donepezil group, a mean change of 1 point on the 30-point MMSE scale, and mean change of 1.6 points on the 54-point ADFACS functional scale.

Rivastigmine. Birks et al. evaluated the efficacy of rivastigmine by reviewing 7 RCTs with total of 3,370 patients with Alzheimer's disease. ^115^ The authors found that, compared to patients receiving placebo, 4 months of 6 mg to 12 mg of rivastigmine therapy produced the following: a mean improvement of 2.4 points on the 70-point ADAS-Cog scale; a mean improvement of 2.4 points on the 100-point Progressive Deterioration Scale (PDS); and no statistically significant effect on the global scale.

An additional RCT assessed the efficacy of 6.5 months of high-dose rivastigmine (6 mg to12 mg daily) in 725 Alzheimer's disease patients. ^101^ Rivastigmine produced the following: a mean improvement of 2.3 points on the 70-point ADAS-Cog scale; 18% more patients in the treatment group than in the placebo group with an improvement on the global CIBIC-plus scale (P = 0.001); and a mean improvement of 3.6 points on the 100-point PDS scale. None of the previous studies evaluated the efficacy of rivastigmine on both the behavioral symptoms of Alzheimer's disease and patients' quality of life.

Rivastigmine was the only drug evaluated in the treatment of Lewy body dementia (LBD) in an RCT of 120 patients. ^102^ Rivastigmine improved the behavioral symptoms as measured by mean difference of 3.8 points on the 120-point NPI scale (NPI-10) and 2.3 points on the 48-point 4 item-sub-scale (NPI-4) (Appendix C). This effect, although not detected on the global scale, was accompanied by a mean improvement of 1.6 points (P = 0.072) on the MMSE.

Galantamine. This new FDA-approved cholinesterase inhibitor was evaluated in 4 RCTs with a total of 2,552 patients with Alzheimer's disease. ^96–98,^ ^112^ Across the 4 trials, compared to patients receiving placebo, patients receiving 24 mg of galantamine daily for 3 to 6 months had a mean difference of 3.3 points on the 70-point ADAS-Cog scale and 14% to 17% more intervention patients than placebo patients stabilized or improved on the 7-point CIBIC-plus global scale. Two trials showed some positive effect on functional performance. One used the Disability Assessment for Dementia scale (DAD: a 100-point scale) and detected a mean difference of 3.4 points. ^96^ Another used the Alzheimer's Disease Cooperative Study-Activity of Daily Living (ADCS-ADL: a 78-point scale) and detected a mean difference of 2.3 points. ^98^ Finally, one trial (978 patients) evaluated the effect of a 24 mg daily dose of galantamine for 5 months on the behavioral symptoms of Alzheimer's disease. This study demonstrated a mean difference of 2 points on the 120-point NeuroPsychiatry Inventory (NPI). Only 1 trial evaluates the impact of this drug on the patient's quality of life; it showed an insignificant effect. ^112^

In summary, RCTs of cholinesterase inhibitors for mild to moderate Alzheimer's dementia show modest benefit on measures of cognition and global change scores, but little or no improvements in functional status. Effects on behavior and other outcomes are rarely measured.

#### Efficacy of Other Medications

Gingko biloba special extract (EGb-761). This alternative medication was studied in 1 systematic review ^118^ and 1 RCT ^106^ (see Evidence Table 5) Oken et al. evaluated 5 RCTs with 424 Alzheimer's disease patients; all used a daily dose of 120 mg to 240 mg of gingko biloba for periods of 12 to 26 weeks. ^118^ They found that gingko biloba produced an improvement of 2.1 points on the 70-points ADAS-Cog scale. Le Bars et al. examined its effect in 309 Alzheimer's disease patients for a period of 13 months. ^106^ After 6 months, the attrition rate among the placebo and the treatment groups differed significantly, so we report here only the results from the 6-month phase. Gingko biloba had a mean improvement of 2.1 points on the 70-point ADAS-Cog scale. This trial showed no effect on clinical global functioning or on a caregiver rating of cognition, social function and mood.

Anti-oxidants (selegiline, vitamin E). One well-conducted systematic review evaluated 15 RCTs and found that 10 mg of selegiline produced a small improvement on cognitive testing (Evidence Table 6). ^116^ A statistically significant decrease occurred in behavioral symptoms as demonstrated by a small improvement of 2.4 points on the 126-point Behavioral Psychiatry Rating Scale (BPRS) and a moderate improvement of 9.6 points on Dementia Mood Assessment Scale (DMAS; range 0 to144 points). A combined global change scale, however, did not reflect this cognitive and behavioral improvement.

Because of the different outcomes measured and the comparison of multiple interventions in addition to selegiline, we also evaluated the Alzheimer's Disease Cooperative Study. In this 2-year RCT, Sano and colleagues tried to determine whether selegiline, vitamin E, or a combination of the 2 pharmacotherapies would slow the functional loss associated with Alzheimer's disease. ^103^ It enrolled 341 patients residing at home or in skilled-nursing facilities who had moderate Alzheimer's disease, based on a score of 2 on the CDR scale (Evidence Table 6). The primary outcome measured was the time to clinically evident decline in functional status, which was defined as the occurrence of 1 of the following: death, institutionalization, loss of the ability to perform at least 2 basic ADLs, or progression to 3 points (severe impairment). After adjusting for the 2-point difference in the MMSE baseline scores among the groups, the investigators found that the median time to clinically evident decline in functioning was 670 days for the vitamin E group, 655 days for the selegiline group, 585 days for the combined group, and 440 days for the placebo group. These differences were statistically significant. The groups did not differ on either the ADAS-Cog or the MMSE.

Estrogen. One trial evaluated the effect of estrogen (0.625 mg or 1.25 mg daily) in 120 Alzheimer's disease patients (Evidence Table 6). ^105^ The investigators found no positive effect on cognitive, global, or behavioral domains; they also reported a negative effect of small size on the global function. Another small trial evaluated the effect of Estraderm^®^ (estrogen patch) on specific cognitive domains of 20 women with Alzheimer's disease. ^114^ The investigators found that estrogen improved the memory and the attention of the treatment group but that it had no effect on any global cognitive test (MMSE and BMICT) or on functional status.

Anti-inflammatory medication. Two trials evaluated the role of anti-inflammatory medications (Evidence Table 7). ^108,^ ^109^ One studied the effect of 10 mg daily of prednisone for 12 months on 138 Alzheimer's disease patients. ^108^ The investigators found no effect on cognitive deficits and a negative effect on the behavioral symptoms of Alzheimer's disease. The other trial studied the effect of diclofenac in 41 Alzheimer's disease patients; ^109^ 50 mg of this nonsteroidal anti-inflammatory drug (NSAID) daily for 6 months had no effect on the cognitive, physical, global, or behavioral outcomes that were measured.

### Trials of Drug Therapy for Vascular Dementia

One systematic review evaluated the effect of aspirin on vascular dementia (Evidence Table 8). ^117^ This review included 70 patients who took 325 mg of aspirin daily for 1 year. These patients demonstrated some improvement in cognitive function, but the change was not statistically significant.

One RCT evaluated the effect of nimodipine in 251 patients with vascular dementia. ^104^ In this study, 90 mg of nimodipine daily for 6 months produced no effect on measures of global change, cognition, or functional status (Evidence Table 8). The study did not assess the impact of nimodipine on the behavioral symptoms of vascular dementia.

### Trials of Drug Therapy for Behavioral Problems Related to Dementia

#### Efficacy of Neuroleptics

Lanctot et al. systematically reviewed the literature about the role of typical neuroleptics in dementia management (Evidence Table 9a). ^122^ Their meta-analysis pooled data from 13 RCTs on the proportion of 295 patients who showed clinically significant behavioral improvement. Patients who took any type of neuroleptic had a 26% greater response in their behavioral and psychological symptoms than those taking a placebo.

In 2000, Davidson et al. published a systematic review assessing the role of the atypical neuroleptics (resperidone and olanzepine) in dementia management (Evidence Table 9a). ^124^ The authors pooled data on the proportion of patients with clinically significant improvement in their behavioral problems from 3 RCTs with 911 subjects. These atypical neuroleptics had modest efficacy compared to placebo (OR, 0.59; 95% CI, 0.44–0.78; NNT, 8; 95% CI, 5–18) in treating behavioral problems related to dementia.

Kirchner et al. studied the efficacy of thioridazine (a typical neuroleptic) in dementia (Evidence Table 9a). ^125^ The authors found 10 RCTs and were able to perform a meta-analysis on 7 of these (though only 2 compared thioridazine to placebo) involving 670 subjects. Thioridazine treatment for 4 to 8 weeks decreased anxiety symptoms of demented patients (OR, 4.91; 95% CI, 3.21–7.5). However, the authors judged the improvement to be clinically insignificant and concluded that the available data do not support the use of thioridazine in dementia.

Because screening in primary care is likely to identify patients with early dementia, data on treatment of behavioral symptoms in early dementia are most relevant to the USPSTF concerns. In previous RCTs and reviews, patients did not always have mild to moderate dementia; many were in institutions that usually care for patients in the later stages of disease. In the Davidson et al. review, the mean MMSE was 7.3 of 30 possible points, indicating advanced disease. ^124^ In the Lanctot et al. review, only 70% of the RCTs included patients with primary dementia. ^122^ One of the 2 thioridazine RCTs reviewed by Kirchner et al. had 610 subjects living in a nursing home. ^125^

Three RCTs of neuroleptic therapy for behavioral problems in dementia met our inclusion criteria and had no fatal methodological flaws (Evidence Table 9b). Teri et al. compared the efficacy between haloperidol, trazodone, behavioral management techniques, and placebo on the behavioral problems related to dementia in 148 individuals who had moderate to severe stage of Alzheimer's disease and suffered from at least two types of disturbed behaviors that occurred once a week prior to the study start. ^113^ The investigators found no difference among the 4 previous groups. Devanand et al. studied the efficacy of a standard dose (2 mg to 3 mg daily) of haloperidol compared to a low dose (0.5 mg to 0.75 mg daily) or placebo in 66 memory clinic patients with Alzheimer's disease and disruptive behaviors or psychosis at baseline. ^94^ The standard dose of haloperidol produced a 33% greater improvement in disruptive behavior than those receiving placebo. However, 39% of the subjects had severe dementia. In a pilot study, Auchus et al. found no effect of a 3 mg daily dose of haloperidol compared to fluoxetine or placebo in improving agitation and caregiver stress in 15 community-dwelling patients with mild to moderate Alzheimer's disease with agitation at baseline. ^110^

In summary, neuroleptics improve the behavioral problems related to dementia syndrome among patients with moderate to severe stages and who are living in institutional settings.

### Efficacy of Antidepressants

In an RCT with a crossover design, Petracca et al. studied the efficacy of 6 weeks of therapy with clomipramine (a tricyclic antidepressant) compared to placebo in 21 patients who had mild to moderate Alzheimer's disease and major depression or dysthymia (Evidence Table 9b). ^111^ Of patients in the treatment arm, 82% entered remission from depressive symptoms at 6 weeks, compared to 30% of the placebo group (p = 0.02; NNT = 2). Clomipramine also decreased the cognition scores of patients but had no effect on functional status. In a more recent study, Lyketsos et al. evaluated the effect of sertraline in 22 individuals with both Alzheimer's disease and major depression (Evidence Table 9b). ^4^ The investigators found that, after 3 months, 75% of the sertraline group had a partial or full response compared to 20% of the placebo group. The caregivers of individuals who received sertraline reported an 11-point decrease on the Cornell Depression in Dementia Scale compared to only 2 points among those who received placebo.

In summary, 2 RCTs provide evidence that antidepressant medication is effective for mood symptoms in patients with Alzheimer's disease; antidepressants have not been studied for effect on cognition or other outcomes.

### Summary of Efficacy Evidence

Review of the evidence for drug treatment of dementia (found in Evidence Tables 4–9) found that full reversal of diseases often grouped as “reversible dementias” occurs in no more than 1.5% of dementia cases. For Alzheimer's disease, multiple RCTs indicate that 6-month and 12-month therapy with cholinesterase inhibitors produces positive effects on cognition and global change scores. The magnitude of the cognitive improvement was 2 to 3 points on the 70-point ADAS-Cog scale, which is equivalent to a delay of about 4 to 5 months in the natural course of the disease. Based on the results of 1 study, the anti-oxidants vitamin E and selegiline delayed the functional decline of patients with moderate Alzheimer's disease by an average of 7 months. Gingko biloba yielded small improvements in cognitive function. No evidence exists for benefit from anti-inflammatory drugs, estrogen, nimodipine, or aspirin in the treatment of dementia. Both typical and atypical antipsychotic medications have modest benefit in the treatment of agitated behavioral symptoms in patients with dementia. However, most of these medication trials have included patients with mild, moderate, and advanced dementia, limiting their relevance to a screening population of primary care outpatients. One RCT provided evidence that a tricyclic antidepressant reduced symptoms of depression in patients with early dementia and another showed that sertraline improved major depression in patients with mild to moderate Alzheimer's disease.

## KEY QUESTION NO. 5: EFFICACY OF NONPHARMACOLOGIC INTERVENTIONS

Our search yielded no study that met our inclusion criteria. Six systematic reviews evaluated a variety of nonpharmacological interventions for patients with dementia syndrome in long-term care settings (Evidence Table 11). These interventions can be categorized into 4 types: sensory, environmental modification, behavioral, and activity-directed interventions.

Forbes did a comprehensive systematic review for any type of interventions. ^151^ She rated the included articles using a methodology appraisal method that looked at the study design, inclusion criteria, attrition rate, confounders' adjustment, data collection, and statistical analysis. Applying an appraisal scale to the 45 articles, Forbes included only 1 strong and 6 moderate studies.

When we applied the USPSTF appraisal protocol to these 7 studies, we included only 3 RCTs with 132 subjects (no evidence table). Planned walking with conversation improved the communication functioning of the patient. ^152^ An attention-focused program improved the activity participation of the patients. ^153^ Finally, functional skills training increased patients' self-care ability. ^154^

Opie et al. looked specifically at behavioral disorders in dementia and evaluated the nonpharmacologic interventions that had been used to manage these disorders or symptoms. ^155^ The authors searched the literature from 1989 through 1998; of 43 articles that met their inclusion criteria, 5 were RCTs (1 trial was rated poor). One trial found that a combination of an activity program and caregiver education significantly decreased physical aggression among demented patients. ^156^ Another trial found that a multidisciplinary team approach improved agitation in demented patients; it also met USPSTF quality standards. ^157^ The other 2 trials in this systematic review showed no efficacy for 2 separate interventions: caregiver education and an activity program treating general agitation. ^158,^ ^159^

We identified 4 systematic reviews that evaluated specific types of nonpharmacologic interventions. Koger and Brotons found no RCTs in a systematic review of music therapy, but they reviewed 126 articles that supported the use of music therapy in dementia. ^160^ Neal and Briggs identified 3 RCTs that evaluated the role of validation therapy in dementia, but this evidence was insufficient to support any conclusion about the efficacy of validation therapy. ^161^ The pooled data showed no effect on either the behavioral or the cognitive symptoms of dementia.

Spector et al. found 2 RCTs that evaluated the efficacy of life reminiscence in dementia. ^162^ The authors analyzed data on 15 participants with moderate to severe cognitive impairment and found no effect on cognitive or behavioral symptoms of dementia. Spector et al. also performed a meta-analysis of 6 RCTs that looked at the efficacy of reality orientation in dementia. ^163^ The authors found that no firm conclusions could be drawn about the effectiveness of reality orientation for dementia.

In summary, numerous studies have reported on various nonpharmacologic interventions to treat the behavioral symptoms of dementia. These interventions differ in type and content and may be difficult to replicate. Some evidence supports planned walking, attention-focused programs, functional skills training, activity programs, multidisciplinary team care, reality orientation, and caregiver education to control behavioral symptoms in advanced dementia. No evidence supports reminiscence therapy, music therapy, or validation therapy. These trials have been conducted in institutional settings. We found no trials of nonpharmacologic interventions in early dementia in a community setting.

## KEY QUESTION NO. 6: EFFICACY OF CAREGIVER INTERVENTIONS

### Rationale for Inclusion in this Review

Among individuals older than 65, 3% to 8% have dementia. Family members, usually elderly spouses, care for 66% to 75% of patients with dementia at home. ^27^ Caring for patients with dementia can be very challenging and burdensome. Dementia is a progressive syndrome marked by behavioral problems and impaired abilities in self-care. It has negative impacts on the caregiver and induces a significant level of caregiver burden. ^30–32,^ ^164^ This burden is defined as the financial, physical, and emotional effects of caring for an adult with a disabling condition. ^165^

Most studies have found high levels of anxiety and depressive symptoms and increased use of psychotropic medications in caregivers compared to age-matched controls or population means. ^28^ Reported rates of depression among dementia caregivers vary from 30% in a community sample to 46% of caregivers who sought help. ^166,^ ^167^ In 1 study, 80% of caregivers reported symptoms of chronic fatigue, depression, or anger. ^34^ Caring for patients with dementia can create a financial burden in addition to the mental and physical ones. Dunkin and Anderson-Hanley estimated that the total cost of caring for very impaired elders in the community, including reimbursable, non-reimbursable, and unpaid labor costs, can be as expensive as nursing home care, or close to $18,256 annually. ^27^

Recent data suggest that caregiver burden can be an important determinant of the demented patients' behavioral problems in addition to their need for institutionalization. ^27,^ ^164^ Caregiver burden appears to be mediated by many variables such as social support, financial resources, coping skills, gender, feelings of self efficacy, and ethnicity, as well as the patient's cognitive, functional, and behavioral impairment. ^27^ Some studies found that behavioral problems appeared to exert greater effects on caregiver burden than did cognitive or functional impairment. ^168–171^

### Yield of Literature Search

We identified 17 RCTs and 9 systematic reviews that met our screening criteria: patients with mild to moderate dementia syndrome based on DSM or ICD-10 criteria; an MMSE score of 10 or above or a CDR score of 1 or 2; and living at home with their informal caregivers. Of these, we rated 1 review good (Evidence Table 11a). ^172^ and 5 RCTs ^173–178^ fair to good (Evidence Table 11a). We combined 2 RCTs because they used the same participants. ^177,^ ^178^

The interventions that target caregivers of patients with dementia do not form mutually exclusive categories; they have varied components and target a diverse group of caregivers. Usually they offer 1 or a combination of the following components: support groups, individual or family counseling, skills training, or educational sessions. No study with our inclusion criteria evaluated respite care, although respite care was offered to control groups in some of our included studies. We categorized all study outcomes as either outcomes that target caregivers' stress and coping (depression, sleep problems, and reaction to behavioral problems of the patient) or those that target the patients' functioning (physical, cognitive, or social), behavioral problems, and institutionalization. No study looked at the effect on patients' quality of life, automobile crashes, falls, or other accidents.

### Effect on Caregivers' Outcomes

One good quality systematic review by Thompson and Briggs looked at 6 RCTs that met our inclusion criteria (Evidence Table 11a). ^172^ The authors evaluated the effects of 4 types of caregiver interventions: individualized service assessment and planning, technology-based interventions, caregiver education and training, and a multi-component program versus conventional care or support. They assessed the impact of the interventions on caregivers' burden, mental health, health care utilization, and knowledge of dementia. Thompson and Briggs found no significant differences between any of the intervention and control groups and concluded that little or no evidence exists that interventions to support caregivers of people with Alzheimer's disease yield quantifiable benefit.

In examining articles that had not been included in the Thompson and Briggs systematic review, we found 3 studies evaluating the effect of caregiver intervention on caregiver burden and depressive symptoms (Evidence Table 11b). Of these, 2 (with sample sizes of 36 to 45) found no effect, ^175,^ ^177,^ ^178^ and 1 found a positive effort. ^174^ This trial (42 subjects) found that a 14-session multi-component intervention decreased both the burden and depression among caregivers at 9 and 12 months from entry into the study. ^174^ The number-needed-to-treat (NNT) to convert a caregiver from being a person with significant psychological morbidity to one without such a level of morbidity was 3 directly at the end of the intervention and 2 at 3 months' follow-up.

To evaluate the effect of caregiver intervention on caregivers' sleep, McCurry et al. studied a multi-component intervention to manage sleep disturbance in 36 caregivers with significant sleep problems (Evidence Table 11b). ^175^ They were able to improve the quality of sleep among the intervention group and reported that 50% of the caregivers in the treatment arm were considered clinical responders with no more significant sleep problems at the end of the intervention. Two studies examined the effect of intervention on caregiver reaction to behavioral problems among patients with dementia. ^175^ The authors found no significant effect. ^177,^ ^178^ In the Hebert et al. study, the comprehensive intervention increased the caregivers' knowledge of Alzheimer's disease but did not affect the caregivers' level of stress. ^177,^ ^178^

In summary, most trials of caregiver interventions showed no benefit to caregivers. One multi-component intervention decreased burden and depression among caregivers. One caregiver intervention that focused on sleep problems showed benefit on this specific outcome.

### Effect on Patients' Outcomes

No systematic review evaluated the impact of caregiver interventions on patients' outcomes, but 3 studies examined the effect of caregiver interventions on patients' cognition, function, and behavioral problems. Marriott and colleagues found some effect on behavioral problems and functional status but failed to report whether caregivers perceived these changes as significant. ^174^ Two other studies (96 and 206 subjects) found that a comprehensive caregiver intervention enabled caregivers to maintain their care recipients at home for a substantially longer period of time (between 11 and 19 months) than those who did not receive the intervention. ^173,^ ^176^

The Mittelman et al. study looked at the effect of keeping the patient at home on caregiver stress (depression). ^173^ The authors concluded that depression decreased, but this part of the study was judged to be of poor quality because of a high attrition rate, no reported concealment of the outcome measures, and no intention-to-treat analysis. We found no report of the effect of the caregiver intervention on the caregivers' burden or depression in the Brodaty et al. study. ^176^ In a third study, Hebert et al. found that multi-component intervention had some effect on nursing home placement. ^177,^ ^178^ The treatment group had a 33% probability of being placed in a nursing home within 2 years compared with 45% probability for the control group, but this effect did not reach statistical significance because of the small sample size (45 subjects).

In summary, 3 studies of caregiver interventions showed a delay in nursing home placement for dementia patients. The procedural details of the interventions varied appreciably among the studies. All these interventions would be difficult to implement in primary care settings, as they require specific expertise and extensive staff training. Most of the outcomes, except time to nursing home placement, were assessed by small studies and with different measurement tools that lacked clinical and practical implementation.

A very comprehensive multi-component caregiver intervention that includes a support group, skills training, counseling, and education can keep the patient at home for a longer period of time. It may also decrease the burden on caregivers and improve their mood and sleep. Caregiver interventions do not affect patients' function (cognitive, physical, social), behavioral problems, quality of life, or auto crashes, falls or other accidents.

## KEY QUESTION NO. 7: ADVERSE EFFECTS OF SCREENING

Our search for articles under the term “Mass Screening” found scant literature on the adverse effects of screening for dementia, particularly in regard to conventional screening techniques. Most articles dealt primarily with the adverse effects of mass screening for genetic markers for an increased likelihood of Alzheimer's disease. The potential negative outcomes for all patients screened dealt primarily with the emotional distress caused by the interview and/or tests.

A 1994 survey by Jorm et al. of patients after they had completed an extensive mental health interview or questionnaire (greater than 110 minutes) found that a large majority reported that the experience had no adverse effect on their emotional state. ^179^ Less than 5% found the study interview distressing, intrusive, or depressing. The cognitive/dementia portion of the questionnaire administered included 6 of the 25 questions considered distressing. Those who were distressed had more anxiety symptoms and scored more poorly on the reading test administered. The authors concluded that the distress could likely be attributed to subjects feeling embarrassed when asked to do a particular task that they thought they would execute poorly.

Once screening identifies persons with low cognitive function, clinicians have some concern over the disclosure of information to patients regarding their dementia status. Two case reports of suicide in patients with newly diagnosed Alzheimer's disease by Rohde et al., ^64^ in addition to the highly publicized assisted suicide of a 54-year-old patient with possible Alzheimer's disease in 1990, ^63^ present an infrequent but significant potential adverse event. ^63^ The risk of such drastic measures may lessen as treatments improve and as clinicians and patients learn about their options.

A theoretical but unproven threat remains to particular patients' autonomy as a result of their being diagnosed with dementia. This danger arises because others may question the individuals' capacity to perform numerous tasks. In fact, questioning patients' capacities may extend to providers. When acting in the role of evaluator for government and other agencies (e.g., driving eligibility), the duty of providers to act on behalf of their patients and the public may come into conflict with their duty to preserve patients' autonomy when addressing issues such as patients' abilities to drive and perform other responsibilities.

All these issues become even more important if a significant number of those falsely identified as having dementia through screening do not have this diagnosis corrected through more comprehensive testing.

## KEY QUESTION NO. 8: COSTS OF SCREENING

We found no studies that evaluated the costs of screening for dementia in a primary care setting.

## KEY QUESTION NO. 9: ADVERSE EFFECTS OF TREATMENT

We extracted data about dropout rates attributed to adverse effects among demented patients treated with effective pharmacologic interventions in the RCTs and systematic reviews examined for Key Questions 4 and 5 (Evidence Tables 12a–12d). For cholinesterase inhibitors (Evidence Tables 12a, 12b), these included 9 RCTs ^93,^ ^95–102^ and 4 reviews. ^115,^ ^119–121^ We examined 3 reviews ^122,^ ^124,^ ^125^ and 1 RCT ^94,^ ^122,^ ^124^ on typical and the atypical neuroleptics (Evidence Table 12c). Finally, we reviewed trials or systematic reviews on several other therapies (Evidence Table 12d): 1 RCT ^106^ and 1 review ^118^ on gingko biloba; 2 RCTs ^103,^ ^116^ on selegiline; and 1 trial of the antidepressant clomipramine. ^111^

The more common side effects in patients who took any type of cholinesterase inhibitor (Evidence Tables 12a, 12b) were nausea, vomiting, weight loss, and diarrhea. The dropout rate due to adverse events among patients who took 24 mg of galantamine daily ranged from 10% to 23%; the average dropout rate among the placebo groups was 8%. The dropout rate for the effective dose of rivastigmine (6 mg to 12 mg per day) ranged from 12% to 27% compared to a rate of 7% among the placebo groups. Dropout rates did not differ for patients who took 5 mg of donepezil daily and those who took placebo. However, the 10 mg dose of donepezil led to a dropout rate of 18% compared to a rate of 10% for the placebo group. Tacrine has significant gastrointestinal and hepatic side effects. The odds ratio (OR) for dropout due to adverse events among patients who took tacrine compared to those on placebo was 5.7 (95% CI, 4.1–7.9).

Dementia syndrome causes significant behavior disturbances among its victims. The pharmacological treatment of these problems is based on the use of neuroleptics, benzodiazepines, antidepressants, and other agents. In 1 systematic review, Lanctot et al. evaluated patients' tolerance of the typical neuroleptics and found that the dropout rate between treatment and placebo groups did not differ significantly. ^122^ However, 51% of patients who took neuroleptics had some adverse effects, as did 25% of the placebo group; the number needed to harm (NNH) was 4 (range 3 to 8).

Davidson et al. assessed the tolerance of the new atypical neuroleptics. ^124^ The investigators reported an OR for dropout of 1.3 (95% CI, 1–1.7), an OR of 2 for extra-pyramidal side effects (EPS) with an NNH of 13, and an OR of 1.7 for sedation with an NNH of 10. In a trial conducted by Devanand et al. in 1998, 20% of patients who took 2 to 4 mg of haloperidol daily developed moderate to severe EPS compared to 0% among a placebo group. ^94^

Tolerance rates did not differ between people who took gingko biloba and those who took placebo. Both groups had a similar dropout rate of 16%. People who took selegiline and those who took placebo both had dropout rates of 20%. In the only antidepressant trial that met our inclusion criteria, Petracca et al. studied the efficacy of clomipramine in the treatment of depression in dementia. ^111^ All patients who took the drug developed some type of adverse event, but none of these effects led patients to stop the medication.